# Appendix D - Federal Resource Panel

- James R. Allen, M.D.
- Director
- National AIDS Program Office
- Office of the Assistant Secretary of Health

- Karen Allen, Ph.D., R.N., C.A.R.N
- Director
- National Nurses Society on Addictions
- University of Maryland of Baltimore
- School of Nursing
- Baltimore, Maryland

- Marietta Anthony, Ph.D.
- Office of the Forum
- Agency for Health Care Policy Research

- James Brennan
- Staff Associate
- National Association of Social Workers

- William Butynski, Ph.D.
- Executive Director
- National Association of State Alcohol and Drug Abuse Directors

- James Callahan, D.P.A.
- Executive Vice President
- American Society of Addiction Medicine

- Olivia Carter-Pokras, M.H.S., Ph.D.
- Public Health Analyst
- Office of Minority Health
- Office of the Assistant Secretary for Health
- Department of Health and Human Services

- Shirley Clark, M.M.H.
- Health Scientist Administrator
- Center for Substance Abuse Prevention

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical and Professional Affairs
- Division of Clinical Research
- National Institute on Drug Abuse

- Maureen Deely, R.N.
- Dennis Avenue Health Center
- Silver Spring, Maryland

- Beth Dillon, M.P.H.
- Public Health Advisor
- National Center for Prevention Services
- Division of STD and HIV Prevention
- Program Development/Technical Support Section
- Centers for Disease Control and Prevention

- Walter L. Faggett, M.D.
- National Medical Association

- Beverly L. Fleming
- Street Health Outreach Program
- Whitman-Walker Clinic
- Washington, D.C.

- Paul Gaist, M.P.H.
- Senior Advisor
- Office of AIDS Research
- National Institutes of Health

- Judith Greenberg, Ph.D.
- Health Scientist
- Division of STD/HIV Prevention
- Behavioral and Prevention Research Branch
- Centers for Disease Control and Prevention

- John Gregrich
- Acting Assistant Director for Treatment
- Office of National Drug Control Policy
- Executive Office of the President

- John Heath
- Chief
- STD Epidemiology Services
- STD Control
- Washington, D.C.

- T. Steven Jones, M.D.
- Special Assistant for Substance Abuse and
- HIV Prevention
- Office of the Deputy Director (HIV)
- Centers for Disease Control and Prevention

- Ruth H. Carlsen Kahn, D.N.Sc.
- Health Manpower Education Specialist
- Bureau of Health Professionals
- Health Resources and Services Administration

- Richard H. Needle, Ph.D., M.P.H.
- Chief
- Community Research Branch
- Division of Clinical Research
- National Institute on Drug Abuse

- Deidrea Roach, M.D.
- Acting Medical Director
- Alcohol and Drug Abuse Services Administration

- Maria Segarra, M.D.
- Office of Minority Health
- Office of the Assistant Secretary for Health
- Department of Health and Human Services

- Kevin Shipman. M.H.S., C.A.C.
- Public Health Educator
- Alcohol and Drug Abuse Services Administration

- Marvin Snyder
- Acting Deputy Director
- National Institute on Drug Abuse

- Sarah Stanley, M.S., R.N., C.N.A., C.S.
- Senior Policy Analyst
- American Nurses Association

- Sylvia D. Trent, R.N., B.S.N., M.S.A.
- Public Health Analyst
- Health Resources Services Administration

- Ken C. Winters, Ph.D.
- Director
- Center for Adolescent Substance Abuse
- University of Minnesota
- Minneapolis, Minnesota

- Randolph F. Wykoff, M.D., M.P.H.T.M.
- Director
- Office of AIDS Coordination
- Food and Drug Administration

- Jonathan M. Zenilman, M.D.
- Assistant Professor
- Division of Infectious Diseases
- Johns Hopkins University School of Medicine
- Baltimore, Maryland