# Appendix C - Cultural Competence

Two articles on cultural competence are included here. The first article, "Cultural Sensitivity: Treatment for Diversity," was published in the July/August 1992 issue of The Counselor, a publication of the National Association of Alcoholism and Drug Abuse Counselors. For the article, the association invited several treatment professionals to share their views on prejudice and cultural sensitivity.

The second article, "Self-Instruction to Prevent HIV Infection Among African-American and Hispanic-American Adolescents," was published in 1990 (vol. 58, no. 4) in the Journal of Consulting and Clinical Psychology, a publication of the American Psychological Association. The authors report the results of a study in which different interventions were used to instruct adolescents about avoiding behavioral risks for HIV infection.

Both articles are reprinted with permission.

The articles reproduced in Appendix C are not available electronically. A copy of the entire TIP containing Appendix C can be ordered from the National Clearinghouse of Drug and Alcohol Information (NCADI). The order number for TIP 11: Simple Screening Instruments for Outreach for Alcohol and Other Drug Abuse and Infectious Diseases is BKD143. It is free and can be ordered from NCADI's electronic catalog at http://www.health.org/pubs/catalog/ordering.htm" (http://www.health.org/pubs/catalog/ordering.htm) or by calling 1-800-729-6686.