# Appendix A - References

American Thoracic Society. Control of tuberculosis in the United States. American Review of Respiratory Diseases. 1992;146:1623-1633.
Centers for Disease Control. Public Health Service statement on management of occupational exposure to human immunodeficiency virus, including considerations regarding zidovudine postexposure use. Morbidity and Mortality Weekly Report. 1990;39(RR1):1-14.
Centers for Disease Control. Recommendations for prevention of HIV transmission in health-care settings. Morbidity and Mortality Weekly Report. 1987;36(2S):1s-18s.
Institute of Medicine. Broadening the Base of Treatment for Alcohol Problems. Washington, D.C.: National Academy Press, 1990.
Kirby P.K., Munyao, T., Kreiss, J., and Holmes, K.K. The challenge of limiting the spread of HIV by controlling other STDs. Archives of Dermatology. 1991;127:237-242.
Moore, R.D., Bone, L.R., Geller, G., Mamon, J.A., Stokes, E.J., and Levine, D.M. Prevalence, detection, and treatment of alcoholism in hospitalized patients. Journal of the American Medical Association. 1989;261:403-407.
Wasserheit, J.N. Epidemiological synergy. Journal of Sexually Transmitted Diseases. 1992;19:61-67.