# References

American Psychiatric Association. 1987.
American Psychiatric Association. 1994.
Ball, J.C., and Ross, A. 1991.
Barthwell, A., and Gastfriend, D.R. Treating multiple substance abuse. In: Center for Substance Abuse Treatment. State Methadone Treatment Guidelines. Treatment Improvement Protocol (TIP) Series. Rockville, MD: U.S. Department of Health and Human Services. 1993:pp. 73-84.
Beck, A.T.; Rush, A.J.; Shaw, B.F.; and Emery, G. 1979.
Beeder, A.B., and Millman, R.B. Treatment of patients with psychopathology and substance abuse. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams and Wilkins. 1992:pp. 675-690.
Bernal, G.; Sorensen, J.L.; Wortman, R.; and Wermuth, L. 1985.
Bloomfeld, H. 1975.
Bohlen, C. Support groups are offering embrace to cocaine's victims. New York Times. 1989;, January 29.
Borant, D. Long-term outpatient support groups for dual diagnosis patients. Substance Abuse. 1992;13(1):21-27.
Brown, L.S.; Ajuluchukwu, D.C.; Gonzalez, V.; and Chu, A.F. 1992.
Brown, L.S., and Alterman, A.I. African-Americans. In: Lowinson, J.; Ruiz P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore, MD: Williams & Wilkins. 1992:pp. 861-866.
Bullock, M.L.; Culliton, P.D.; and Olander, R.T. Controlled trial of acupuncture for severe recidivist alcoholism. Lancet. 1989;1(8652):1435-1439. [pmid: 2567439].
Butler, J.P. Of kindred minds: The ties that bind. In: Orlandi, M.A., ed. Cultural Competence for Evaluators. Rockville, MD: U.S. Department of Health and Human Services. 1992:pp. 23-54.
Carroll, K.M. Psychotherapy for cocaine abuse: Approaches, evidence, and conceptual models. In: Kosten, T.R., and Kleber, H.D., eds. Clinician's Guide to Cocaine Addiction. New York: Guilford Press. 1992:pp. 290-313.
Center for Substance Abuse Treatment. 1993.
Center for Substance Abuse Treatment. 1993.
Center for Substance Abuse Treatment. 1994.
Center for Substance Abuse Treatment. 1994.
Chaisson, R.E.; Baccheti, Bacchetti, R.; Osmond, D.; Brodie, B.; Sande, M.A.; and Moss, A.R. Cocaine use and HIV infection in intravenous drug users in San Francisco. Journal of the American Medical Association. 1989;261:561-565.
Childress, A.R.; Ehrman, R.; Rohsenow, D.J.; Robbins, S.J.; and O'Brien, C.P. Classically conditioned factors in drug dependence. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 56-69.
Condelli, W.S.; Fairbank, J.A.; Dennis, M.L.; and Rachal, J.V. Cocaine use by clients in methadone programs: Significance, scope, and behavioral interventions. Journal of Substance Abuse Treatment. 1991;8:203-212.
Crosby, R.D.; Halikas, J.A.; and Carlson, G. Pharmacotherapeutic interventions for cocaine abuse: Present practices and future directions. Journal of Addictive Diseases. 1991;10(4):13-30. [pmid: 1685672].
Dackis, C.A., and Gold, M.S. Psychiatric hospitals for treatment of dual diagnosis. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 467-485.
Daley, D.C., and Marlatt, G.A. Relapse prevention: Cognitive and behavioral interventions. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams and Wilkins. 1992:pp. 533-542.
D'Aunno, T., and Vaughn, T. Variations in methadone treatment practices: Results from a national study. Journal of the American Medical Association. 1992;267(2):253-258. [pmid: 1727522].
Dolan, M.P.; Black, J.L.; Penk, W.E.; Robinowitz, R.; and DeFord, H.A. Contracting for treatment termination to reduce illicit drug use among methadone maintenance treatment failures. Journal of Consulting and Clinical Psychology. 1985;53(4):549-551. [pmid: 4031215].
Dolan, M.P; Black, J.L.; Penk, W.E.; Robinowitz, R.; and DeFord, H.A. Predicting the outcome of contingency contracting for drug abuse. Behavior Therapy. 1986;17:470-474.
Dole, V.P. Implications of methadone maintenance for theories of narcotic addiction. Journal of the American Medical Association. 1988;260(20):3,025-3,029.
Donahue, J.G.; Nelson, K.E.; Munoz, A; Rennie, L.L.; Taylor, E.L.; Saah, A.F.; Cohn, S.; Odaka, N.J.; and Farzadegan, H. Antibody to hepatitis C virus among cardiac surgery patients, homosexual men, and intravenous drug users in Baltimore, Maryland. American Journal of Epidemiology. 1991;134:1,200-1,211.
Dunteman, G.H.; Condelli, W.S.; and Fairbank, J.A. Predicting cocaine use among methadone patients: Analysis of findings from a national study. Hospital and Community Psychiatry. 1992;43(6):608-611. [pmid: 1318260].
Ewing, J.A. Detecting alcoholism . . . the CAGE question. Journal of the American Medical Association. 1984;152(14):1,905-1,907.
Finnegan, L.P., and Kandall, S.R. Maternal and neonatal effects of alcohol and drugs. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 628-656.
Gawin, F.H., and Ellinwood, E.H. Cocaine and other stimulants. New England Journal of Medicine. 1988;318:1,173-1,182.
Gawin, F.H., and Kleber, H.D. Abstinence symptomologysymptomatology and psychiatric diagnosis in cocaine abusers: Clinical observations. Archives of General Psychiatry. 1986;43:107-113.
Gerstein, D.R., and Harwood, H.J., eds. 1990:pp. 11-19.
Gold, M.S. Cocaine (and crack): Clinical aspects. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 205-221.
Grace, C.A. Practical considerations for program professionals and evaluators working with African-American communities. In: Orlandi, M.A., ed. Cultural Competence for Evaluators. Rockville, MD: U.S. Department of Health and Human Services. 1992:pp. 55-74.
Hartel, D.M.; Schoenbaum, E.E.; Selwyn, P.A.; Drucker, E.; and Friedland, G.H. 1989.
Higgins, S.T.; Delaney, D.D.; Budney, A.J.; Bickel, W.K.; Hughes, J.R.; Foerg, F.; and Fenwick, J.W. A behavioral approach to achieving initial cocaine abstinence. American Journal of Psychiatry. 1991;148(9):1,218-1,224.
Hoffman, N.G.; Halikas, J.A.; Mee-Lee, D.; and Weedman, R.D. 1991.
Hubbard, R.L. Evaluation and treatment outcome. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 596-611.
Hunt, D.; Spunt, B.; Lipton, D.; Goldsmith, D.; and Strug, D. The costly bonus: Cocaine-related crime among methadone treatment clients. Advances in Alcohol and Substance Abuse. 1986;6(2):107-122. [pmid: 3604786].
Hunt, D.E.; Strug, D.L.; Goldsmith, D.S.; Lipton, D.S.; Spunt, B.; Truitt, L.; and Robertson, K.A. An instant shot of "aah": Cocaine use among methadone clients. Journal of Psychoactive Drugs. 1984;16:217-227.
Iguchi, M.Y.; Stitzer, M.L.; Bigelow, G.E.; and Liebson, I.A. Contingency management in methadone maintenance: Effects of reinforcing and aversive consequences on illicit polydrug use. Drug and Alcohol Dependence. 1988;22:1-8.
Jaffe, J.H. Opiates: Clinical aspects. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 186-194.
Johnson, B.D., and Muffler, J. Sociocultural aspects of drug use and abuse in the 1990s. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 118-137.
Joint Commission on Accreditation of Healthcare Organizations (JCAHO). Monitoring and evaluation: Alcoholism and other drug dependence services. In: Fromberg, R., ed. JCAHO Monitoring and Evaluation Series. Chicago: the Commission. 1987.
Joseph, H. Substance abuse and homelessness within the inner cities. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 875-889.
Juliana, P., and Goodman, C. Children of substance abusing parents. In: Lowinson, J.; Ruiz,P., and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 808-815.
Kadden, R.; Carroll, K.; Donovan, D.; Cooney, N.; Monti, P.; Abrams, D.; Litt, M.; and Hester, R., eds. 1992.
Kleber, H.D. Concomitant use of methadone with other psychoactive drugs in the treatment of opiate addicts with other DSM-III diagnoses. In: Cooper, J.R.; Altman, F.; Brown, B.S.; and Czechowicz, D., eds. Research on the Treatment of Narcotic Addiction: State of the Art. Treatment Research Monograph Series, National Institute on Drug Abuse, DHHS Pub. No. (ADM)87-1281. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1983:pp. 119-148.
Kleber, H.D., and Gawin, F.H. Cocaine abuse: A review of current and experimental treatment. Journal of Clinical Psychiatry. 1984;45(12):18-23. [pmid: 6438067].
Klerman, G.L.; Weissman, M.M.; Rounsaville, B.J.; and Chevron, E. 1984.
Kolar, A.F.; Brown, B.S.; Weddington, W.W.; and Ball, J.C. A treatment crisis: Cocaine use by clients in methadone maintenance programs. Journal of Substance Abuse Treatment. 1990;7:101-107.
Kosten, T.A.; Kosten, T.R.; and Rounsaville, B.J. Personality disorders in opiate addicts show prognostic specificity. Journal of Substance Abuse Treatment. 1989;6(3):163-168. [pmid: 2795705].
Kosten, T.R. Client issues in drug abuse treatment: Addressing multiple drug abuse. In: Pickens, R.W.; Leukefeld, C.G.; and Schuster, C.R., eds. Improving Drug Abuse Treatment. DHHS Pub. No. (ADM)91-1754. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1991:pp. 136-147.
Kosten, T.R. Pharmacotherapies. In: Kosten, T.R., and Kleber, H.D., eds. Clinician's Guide to Cocaine Addiction. New York: Guilford Press. 1992:pp. 273-289.
Kosten, T.R.; Gawin, F.H.; Morgan, C.; Nelson, J.C.; and Jatlow, P. Evidence for altered desipramine disposition in methadone-maintained patients treated for cocaine abuse. American Journal of Drug and Alcohol Abuse. 1990;16:329-336.
Kosten, T.R.; Gawin, F.H.; Rounsaville, B.J.; and Kleber, H.D. Abuse of cocaine with opioids: Psychological aspects of treatment. In: Harris, L., ed. Proceedings of the 47th Annual Scientific Meeting. DHHS Pub. No. (ADM)88-1448. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1986:a. pp. 278-282.
Kosten, T.R.; Gawin, F.H.; Rounsaville, B.J.; and Kleber, H.D. Cocaine abuse among opioid addicts: Demographic and diagnostic factors in treatment. American Journal of Drug and Alcohol Abuse. 1986;12(1,2):1-16.
Kosten, T.R.; Gawin, F.H.; and Schuman, B. Treating cocaine abusing methadone maintenance patients with desipramine. In: Harris, L., ed. Proceedings of the 49th Annual Scientific Meeting. DHHS Pub. No. (ADM)88-1564. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1987:a. pp. 237-241.
Kosten, T.R.; Kleber, H.D.; and Morgan, C.H. Role of opioid antagonists in treating intravenous cocaine abuse. Life Sciences. 1989;44:887-892.
Kosten, T.R.; Kleber, H.D.; and Morgan, C.H. Treatment of cocaine abuse with buprenorphine. Biological Psychiatry. 1989;26(6):637-639. [pmid: 2790101].
Kosten, T.R.; Morgan, C.M.; Falcione, J.; and Schottenfeld, R.S. Pharmacotherapy for cocaine abusing methadone-maintained patients using amantadine or desipramine. Archives of General Psychiatry. 1992;49:894-899.
Kosten, T.R.; Morgan, C.H.: and Schottenfeld, R.S. Amantadine and desipramine in the treatment of cocaine abusing methadone-maintained patients. In: Harris, L., ed. Proceedings of the 52nd Annual Scientific Meeting. DHHS Pub. No. (ADM)91-1753. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1990:pp. 510-511.
Kosten, T.R.; Rounsaville, B.J.; and Kleber, H.D. A 2.5-year follow-up of cocaine use among treated opioid addicts: Have our treatments helped?. Archives of General Psychiatry. 1987;44:281-284.
Kosten, T.R.; Rounsaville, B.J.; and Kleber, H.D. Antecedents and consequences of cocaine abuse among opioid addicts. A 2.5-year follow-up. Journal of Nervous and Mental Diseases. 1988;176:176-181.
Kosten, T.R.; Schottenfeld, C.H.; Morgan, C.H.; Falcioni, J.; and Ziedonis, D. Buprenorphine vs. methadone for opioid and cocaine dependence. In: Harris, L., ed. Proceedings of the 53rd Annual Scientific Meeting. DHHS Pub. No. (ADM)92-1888. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1992.
Kosten, T.R.; Schumann, B.; and Wright, D. Bromocriptine treatment of cocaine abuse in patients maintained on methadone. American Journal of Psychiatry. 1988;145:381-382.
Kosten, T.R.; Schumann, B.; Wright, D.; Carney, M.K.; and Gawin, F.H. A preliminary study of desipramine in the treatment of cocaine abuse in methadone maintenance patients. Journal of Clinical Psychiatry. 1987;48:442-444.
Kreek, M.J. Health consequences associated with the use of methadone. In: Cooper, J.R., ed. Research on the Treatment of Narcotic Addiction: State of the Art. Rockville, MD.: National Institute on Drug Abuse. 1993.
Kreek, M.J. Using methadone effectively: Achieving goals by application of laboratory, clinical, and evaluation research and by development of innovative programs. In: Pickens, R.W.; Leukefeld, C.G.; and Schuster, C.R., eds. Improving Drug Abuse Treatment. DHHS Pub. No. (ADM)91-1754. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1991:pp. 245-263.
Krystal, H., and Raskin, H.A. 1970.
Langrod, J. Admissions policies and procedures. In: Center for Substance Abuse Treatment. State Methadone Treatment Guidelines. Treatment Improvement Protocol (TIP) Series. Rockville, MD: U.S. Department of Health and Human Services. 1993:pp. 33-46.
Larson, D.: Hohmann, A.; Kessler, L.; Meador, K.; Boyd, J.; and McSherry, E. The couch and the cloth: The need for linkage. Hospital and Community Psychiatry. 1988;39(10):1064-1069. Cited in Muffler, J.; Langrod, J.G.; and Larson, D. "There is a balm in Gilead": Religion and substance abuse treatment. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore, MD: Williams & Wilkins, 1992. pp. 584-595. [pmid: 3229739].
Legal Action Center. 1988.
Levy, R. Suicide, homicide, and other psychiatric emergencies. In: Goldman, H.H., ed. Review of General Psychiatry. East Norwalk, CT: Appleton & Lange. 1988.
Ling, W., and Wesson, D.R. Drugs of abuse-opiates. Addiction Medicine, Western Journal of Medicine. 1990;(Special Issue) 152:565-572, May. Cited in Zweben J.E., and Payte J.T., eds. Readings on Methadone Maintenance Treatment. Rockville, MD: U.S. Department of Health and Human Services, 1992. pp. 15-22.
Magura, S.; Casriel, C.; Goldsmith, D.S.; Strug, D.L.; and Lipton, D.S. Contingency contracting with polydrug-abusing methadone patients. Addictive Behaviors. 1988;13(1):113-118. [pmid: 3284282].
Magura, S.; Siddiqi, Q.; Freeman, R.C.; and Lipton, D.S. Changes in cocaine use after entry to methadone treatment. Journal of Addictive Diseases. 1991;10(4):31-45. [pmid: 1777498].
Marlatt, G.A., and Gordon, J.R. Determinants of relapse: Implications of the maintenance of behavior change. In: Davidson, P.O., and Davidson, S.M., eds. Behavioral Medicine: Changing Health Lifestyles. New York: Brunner/Mazel. 1980:pp. 410-452.
Marlatt, G.A., and Gordon, J.R., eds. 1985.
Marzuk, P., and Mann, J. Suicide and substance abuse. Psychiatric Annals. 1988;18(11):639-645.
McLellan, A.T., and Alterman, A.I. Patient treatment matching: A conceptual and methodological review with suggestions for future research. In: Pickens, R.W.; Leukefeld, C.G.; and Schuster, C.R., eds. Improving Drug Abuse Treatment. DHHS Pub. No. (ADM)91-1754. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1991:pp. 114-135.
McLellan, A.T.; Arndt, I.; Metzger, D.; Woody, G.; and O'Brien, C.P. Effects of psychosocial services in substance abuse treatment. Journal of the American Medical Association. 1993;269(15):1,953-1,959.
McLellan, A.T.; Childress, A.R.; Griffith, J.; and Woody, G.E. The psychiatrically severe drug abuse patient: Methadone maintenance or therapeutic community?. American Journal of Drug and Alcohol Abuse. 1984;10(1):77-95. [pmid: 6731399].
McNeil, D.G. Why there's no methadone for crack. The New York Times. 1992;, June 14, sect. 4, p. 7.
Mello, N.K.: Mendelson, J.H.; Bree, M.P.; and Lucas, S.E. Buprenorphine suppresses cocaine self-administration by rhesus monkeys. Science. 1989;245:859-862.
Metzger, D.; Woody, G.; De Philippis, D.; McLellan, A.T.; O'Brien, C.P.; and Platt, J.J. Risk factors for needle sharing among methadone-treated patients. American Journal of Psychiatry. 1991;148(4):636-640.
Meyer, R.E. How to understand the relationship between psychopathology and addictive disorders: Another example of the chicken and the egg. In: Meyer, R.E., ed. Psychopathology and Addictive Disorders. New York, NY: Guilford Press. 1986:pp. 3-16.
Miller, W.R., and Rollnick, S. 1991.
Millman, R.B. Evaluation and clinical management of cocaine abusers. Journal of Clinical Psychiatry. 1988;49(2) (Suppl):27-33.
Muffler, J.; Langrod, J.G.; and Larson, D. "There is a balm in Gilead": Religion and substance abuse treatment. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore, MD: Williams & Wilkins. 1992:pp. 584-595.
Mulé, S.J. Psychological, neurochemical, and behavioral correlates of cocaine abuse. In: McArthur, L. ed. Cocaine Symposium Update. New York: New York State Division of Substance Abuse Services. 1985:pp. 16-17.
National Institute on Drug Abuse. 1993.
National Institute on Drug Abuse. 1993.
National Institute on Drug Abuse. 1993.
Nebelkopf, E. Holistic programs for the drug addict and alcoholic. Journal of Psychoactive Drugs. 1981;13(4):345-351. [pmid: 7040618].
Neshin, S.F. HIV and other infectious diseases. In: Center for Substance Abuse Treatment. State Methadone Treatment Guidelines. Treatment Improvement Protocol (TIP) Series. Rockville, MD: U.S. Department of Health and Human Services. 1993:pp. 95-118.
Novick, D.M.; Pascarelli, E.F.; Joseph, H.; Salsitz, E.A.; Richman, B.L.; Des Jarlais, D.C.; Anderson, M.; Dole, V.P.; and Nyswander, M.D. Methadone maintenance patients in general medical practice. Journal of the American Medical Association. 1988;259(22):3,299-3,302.
Nunes, E.V.; Quitkin, F.M.; Brady, R.; and Stewart, J.W. Imipramine treatment of methadone maintenance patients with affective disorder and illicit drug use. American Journal of Psychiatry. 1991;148(5):667-669. [pmid: 2018172].
Nurco, D.N.; Stephenson, P.; and Hanlon, T.E. Contemporary issues in drug abuse treatment linkage with self-help groups. In: Pickens, R.W.; Leukefeld, C.G.; and Schuster, C.R., eds. Improving Drug Treatment. DHHS Pub. No. (ADM)91-1754. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1991:pp. 338-347.
O'Brien, C.P.; Ehrman, R.N.; and Ternes, J.W. Classical conditioning in human opioid dependence. In: Goldberg, S., ed. Behavioral Analysis of Drug Dependence. San Diego, CA: Academic Press, Inc. 1986.
O'Connell, D.F. The use of transcendental meditation in relapse prevention counseling. Alcoholism Treatment Quarterly. 1991;8(1):53-68.
O'Malley, S.S.; Jaffe, A.J.; Chang, G.; Schottenfeld, R.S.; Meyer, R.E.; and Rounsaville, B. Naltrexone and coping skills therapy for alcohol dependence: A controlled study. Archives of General Psychiatry. 1992;49:881-887.
Payte, J.T., and Khuri, E.T. Treatment duration and patient retention. In: Center for Substance Abuse Treatment. State Methadone Treatment Guidelines. Treatment Improvement Protocol (TIP) Series. Rockville, MD: U.S. Department of Health and Human Services. 1993:pp. 119-124.
Phillips, C.; Hubbard, R.; Dunteman, G.; Fountain, D.; Czechowicz, D.; and Cooper, J. Measuring treatment using in-treatment outcomes: An illustration. Journal of Mental Health Administration. 1994;, in press.
Pond, S.M.; Kreek, M.J.; Tong, T.G.; Raghunath, J.; and Benowitz, N.L. Altered methadone pharmacokinetics in methadone maintained pregnant women. Journal of Pharmacology and Experimental Therapeutics. 1985;233:1-6.
Prochaska, J.O.; and DiClemente, C.C. Transtheoretical therapy: Toward a more integrative model of change. Psychotherapy: Theory, Research, and Practice. 1982;19:276-288.
Rational Recovery Systems.
Rawson, R.A.; Obert, J.L.; McCann, M.J.; Smith, D.P.; and Ling, W. Neurobehavioral treatment for cocaine dependency. Journal of Psychoactive Drugs. 1990;22(2):159-171, April-June.
Regier, D.A.; Farmer, M.E.; Rae, D.S.; Locke, B.Z.; Keith, S.J.; Judd, L.L.; and Goodwin, F.K. Comorbidity of mental disorders with alcohol and other drug abuse. Journal of the American Medical Association. 1990;19(264):2,511-2,518.
Rounsaville, B.J.; Anton, S.F.; Carroll, K.; Budde, D.; Prusoff, B.A.; and Gawin, F.H. Psychiatric diagnosis diagnoses of treatment seeking cocaine abusers. Archives of General Psychiatry. 1991;48:43-51.
Rounsaville, B.J.; and Carroll, K.M. Individual psychotherapy for drug abusers. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 496-507.
Rounsaville, B.J.; Gawin, F.H.; and Kleber, H.D. Interpersonal psychotherapy (IPT) adapted for ambulatory cocaine abusers. American Journal of Alcohol Abuse. 1985;11:171-191.
Rounsaville, B.J.; Glazer, W.; Wilber, C.H.; Weissman, M.M.; and Kleber, H.D. Short-term interpersonal psychotherapy in methadone-maintained opiate addicts. Archives of General Psychiatry. 1983;40:629-636.
Rounsaville, B.J.; Weissman, M.M.; and Kleber, H.D. The significance of alcoholism in treated opiate addicts. Journal of Nervous and Mental Diseases. 1982;170:479-488.
Rounsaville, B.J.; Weissman, M.M.; Kleber, H.; and Wilber, C. Heterogeneity of psychiatric diagnosis in treated opiate addicts. Archives of General Psychiatry. 1982;39:161-166.
Ruiz, P., and Langrod, J.G. Substance abuse among Hispanic-Americans: Current issues and future perspectives. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 868-873.
Schottenfeld, R.S.; Kosten, T.R.; Pekas, J.; Ziedonis, D.; and Oliveto, A. Problems of drug dependency, 1993. In: Proceedings of the 55th Annual Scientific Meeting. Toronto, Canada: The College on Problems of Drug Dependence, Inc., in press. 1993.
Selwyn, P.A.; and O'Connor, P.G. Diagnosis and treatment of substance users with HIV infection. AIDS and HIV Infection in Office Practice. 1992;19(1):119-156.
Senay, E.C. Diagnostic Interview and mental status examination. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 416-424.
Senay, E.C.; Barthwell, A.G.; Marks, R.; Bokos, P.; Gillman, D.; and White, R. Medical maintenance: A pilot study. Journal of Addictive Diseases. 1993;12(4):59-76. [pmid: 8292640].
Shamise, Shamsie, S.J. Antisocial adolescents: Our treatments do not work. Where do we go from here?. Canadian Journal of Psychiatry. 1981;26:357-364.
Shoptaw, S.; Rawson, R.A.; McCann, M.J.; and Obert, J.L. 1993.
Smith, D.E. Cocaine-alcohol abuse: Epidemiological, diagnostic and treatment considerations. Journal of Psychoactive Drugs. 1986;18(2):117-128. [pmid: 3734954].
Smith, D.E., and Wesson, D.R. Cocaine abuse and treatment: An overview. In: Smith, D.E., and Wesson, D.R., eds. Treating Cocaine Dependency. Center City, MN: Hazelden Foundation. 1988:pp. 5-20.
Sorenson, J.L., and Batki, S.L. Management of the psychosocial sequelae of HIV infection among drug abusers. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore, MD: Williams & Wilkins. 1992:pp. 788-792.
Stanton, M.D.; Todd, T.C., and Associates. 1982.
Stark, M.J., and Campbell, B.K. A psychoeducational approach to methadone maintenance treatment: A survey of client reactions. Journal of Substance Abuse Treatment. 1991;8:125-131.
Stine, S.M.; Freeman, M.; Burns, B.; and Kosten, T.R. Effect of methadone dose contingency treatment on cocaine abuse in a methadone program. In: Harris, L., ed. Proceedings of the 53rd Annual Scientific Meeting. DHHS Pub. No. (ADM)92-1888. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1992.
Stitzer, M.L.; Bickel, W.K.; Bigelow, G.E.; and Liebson, I.A. Effect of methadone dose contingencies on urinalysis test results of polydrug-abusing methadone-maintenance patients. Drug and Alcohol Dependence. 1986;18:341-348.
Stitzer, M.L.; Iguchi, M.Y.; and Felch, L.J. Contingent take-home incentive: Effects on drug use of methadone maintenance patients. Journal of Consulting and Clinical Psychology. 1992;60(6):927-934. [pmid: 1460154].
Stitzer, M.L., and Kirby, K.C. Reducing illicit drug use among methadone patients. In: Pickens, R.W.; Leukefeld, C.G.; and Schuster, C.R., eds. Improving Drug Abuse Treatment. DHHS Pub. No. (ADM)91-1754, Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1991:pp. 178-198.
Trachtenberg, M.C., and Blum, K. Improvement of cocaine-induced neuromodulator deficits by the neuronutrient tropamine. Journal of Psychoactive Drugs. 1988;29(3)(July-Sept.):315-331.
Verebey, K. Diagnostic laboratory: Screening for drug abuse. In: Lowinson, J.; Ruiz, P., and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 425-436.
Walker, R. Substance abuse and B-cluster disorders I: Understanding the dual diagnosis patient. Journal of Psychoactive Drugs. 1992;24(3)(July-Sept.):223-232.
Wallace, B.C. Treating crack cocaine dependence: The critical role of relapse prevention. Journal of Psychoactive Drugs. 1992;42(2):213-221. [pmid: 1507002].
Wallace, R.; Fullilove, M.T.; and Wallace, D. Family systems and deurbanization: Implications for substance abuse. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 944-955.
Washton, A.M. Cocaine abuse and compulsive sexuality. Medical Aspects of Human Sexuality. 1989;. (Dec):32-39.
Washton, A.M. Nonpharmacological Nonpharmacologic treatment of cocaine abuse. Psychiatric Clinics of North America. 1986;9:513-571.
Washton, A.M. Preventing relapse to cocaine. Journal of Clinical Psychiatry. 1988;49(2)(Suppl):34-38.
Weddington, W.W.; Brown, B.S.; Cone, E.J.; Haertzen, C.A.; Dax, E.M.; Herning, R.I.; and Michaelson, B.S. Changes in mood, craving and sleep during acute abstinence reported by male cocaine addicts. In: Harris, L., ed. Proceedings of the 52nd Annual Scientific Meeting, DHHS Pub. No. (ADM)91-1753. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1991:pp. 453-454.
Weiss, R.D.; Mirin, S.M.; Michael, J.L.; and Sollogub, A.C. Psychopathology in chronic cocaine abusers. American Journal of Drug and Alcohol Abuse. 1986;12:17-29.
Wen, H.L., and Cheung, S.Y.C. Treatment of drug addiction by acupuncture and electrical stimulation. Asian Journal of Medicine. 1973;9:138.
Westermeyer, J. Cultural perspectives: Native Americans, Asians, and new immigrants. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 890-895.
Winick, C. Substances of use and abuse and sexual behaviors. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams and Wilkins. 1992:pp. 722-732.
Woody, G.E.; and Cacciola, J. Diagnosis and classification: DSM-III-R and ICD-10. In: Lowinson, J.; Ruiz, P.; and Millman, R., eds. Substance Abuse: A Comprehensive Textbook. Baltimore: Williams & Wilkins. 1992:pp. 398-402.
Woody, G.E.; Luborsky, L.; McLellan, A.T.; O'Brien, C.P. Beck, A.T.; Blaine, J.; Herman, I.; and Hole, A. Psychotherapy for opiate addicts. Does it help?. Archives of General Psychiatry. 1983;40:639-645.
Woody, G.E.; McLellan, A.T.; Luborsky, L.; and O'Brien, C.P. Sociopathy and psychotherapy outcome. Archives of General Psychiatry. 1985;42:1,081-1,086.
Woody, G.E.; McLellan, A.T.; O'Brien, C.P.; and Luborsky, L. Addressing psychiatric comorbidity. In: Pickens, R.W.; Leukefeld, C.G.; and Schuster, C.R., eds. Improving Drug Treatment. DHHS Pub. No. (ADM)91-1754. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1991:pp. 152-166.
Yancovitz, S.R.; Des Jarlais, D.C.; Peyser, N.P.; Drew, E.; Friedman, P.; Trigg, H.C.; and Robinson, J.W. A randomized trial of an interim methadone maintenance clinic. American Journal of Public Health. 1991;81(9):1,185-1,191.
Ziedonis, D.M. Comorbid psychopathology and cocaine addiction. In: Kosten, T.R., and Kleber, H.D., eds. Clinician's Guide to Cocaine Addiction. New York: Guilford Press. 1992:pp. 335-358.
Ziedonis, D.M., and Kosten, T.R. Depression as a prognostic factor for pharmacological treatment of cocaine dependency. Psychopharmacology Bulletin. 1991;27(3):337-343. [pmid: 1775608].
Zweben, J.E. Recovery-oriented psychotherapy: Facilitating the use of 12-step programs. Journal of Psychoactive Drugs. 1987;19(3), (July-Sept.):243-251.
Zweben, J.E. Review of clinical issues. In: Center for Substance Abuse Treatment. State Methadone Treatment Guidelines. Treatment Improvement Protocol (TIP) Series, No. 1. DHHS Pub. No. (SMA) 93-1991. Rockville, MD: Center for Substance Abuse Treatment. 1993:pp. 25-32.
Zweben, J.E., and Payte, J.T. Methadone maintenance in the treatment of opioid dependence. In: Zweben, J.E., and Payte, J.T., eds. Readings on Methadone Maintenance Treatment. Rockville, MD: U.S. Department of Health and Human Services. 1992:pp. 588-599.