# Note From the Chair

Patients who abuse opioids and cocaine present a unique challenge to substance abuse treatment providers. Traditional treatment strategies have focused on one addiction or the other without noting the implications of opioid treatment on the use of cocaine or cocaine treatment on the use of opioids. ^1^ In many treatment settings, the problem of multidrug dependence creates pressures on providers to work with patients through more intensified approaches than those required for patients abusing one substance. The combination of opioids and cocaine is particularly difficult because treatment approaches developed for opioids and cocaine individually have not been successful in helping concurrently dependent persons.

1 Use of the word "opioids" in this TIP usually refers to heroin, although other opioid agonists are also included in this category. The discussion also includes all routes of administration.

This Treatment Improvement Protocol (TIP) is intended to examine the physical and psychosocial sequelae associated with the abuse of opioids in combination with cocaine and offer assessment and treatment planning protocols for staff to use in substance abuse treatment programs.

To the extent possible, the document is based on available research information. However, many of the clinical issues facing providers of treatment to concurrently dependent persons have yet to be fully assessed. Few data exist on treating concurrent cocaine abuse, and even less information exists on treating concurrent abuse of other stimulants. This TIP is a reflection of the treatment modalities that are being used in various treatment centers throughout the Nation and should be viewed as such, rather than as a document that purports to have definitive solutions to what has become an extraordinarily difficult problem. Where clinical research is lacking, the TIP makes recommendations for treatment strategies based on clinical models developed by successful treatment programs. These recommendations should be considered guides, and their use should be tailored to the specific needs of an individual program's patient population.

Methadone patients with concurrent dependency on cocaine are often admitted for treatment in methadone treatment programs (MTPs). ^2^ Difficulties in determining whether cocaine use increases once patients are enrolled in an MTP, or is unrelated to methadone use, have prompted studies of methadone treatment patients. At the same time, already overburdened programs are struggling to create treatment approaches effective for concurrently dependent persons. Because of these issues, much of the information in this document is directly applicable to MTPs.

2 Although the language used in the Federal regulations (21 CFR 291.505) refers to narcotic treatment programs (NTPs), most, if not all, NTPs are in fact methadone treatment programs (MTPs). The language of this TIP reflects that reality and will use the term "MTPs" when discussing programs.

Levo-alpha-acetylmethadol (LAAM) therapy may be an appropriate substitute for methadone maintenance treatment. Increasingly, methadone treatment centers are treating patients with LAAM as an alternative to methadone. It is important to read this TIP with the understanding that its recommendations may also apply to LAAM therapy, as well as other substitution therapies that are developed.

The Consensus Panel convened to create this document included some of the most distinguished clinicians, researchers, and policy officials in the field of substance abuse. All have a specific area of expertise in the problems of patients dependent on opioids or cocaine. Convening the group provided a unique opportunity to bring together substance abuse professionals from across the Nation to develop a document for the substance abuse treatment field that includes state-of-the-art information. We hope you find this TIP useful in exploring the treatment needs of methadone patients concurrently dependent on cocaine.

Herbert D. Kleber, M.D.

Chair, TIP Consensus Panel