# Foreword

The increasing complexity of the problems of cocaine-abusing patients in the substance abuse treatment system has created pressure on treatment providers to expand the scope of services to meet the complex needs of multidrug users. Narcotic treatment programs (NTPs) have been successful in treating opioid addicts for their narcotic addiction but in many instances have been less successful in treating patients who are also dependent on cocaine. The increasing prevalence of acquired immune deficiency syndrome (AIDS) and multidrug-resistant TB among drug users has further complicated treatment needs and heightened the urgency to provide effective drug treatment services. As the Federal office responsible for providing leadership in improving substance abuse treatment services, the Center for Substance Abuse Treatment (CSAT) of the Substance Abuse and Mental Health Services Administration has sponsored the development of this Treatment Improvement Protocol (TIP) to address the treatment needs of patients who are abusing opioids and stimulants, especially cocaine and crack cocaine.

CSAT is committed to assisting State policy officials and treatment providers with understanding current treatment issues and improving treatment for all substance abuse patients. This TIP is one of a series written with the assistance of substance abuse treatment experts throughout the United States that serve as guidelines to help substance abuse treatment providers meet treatment challenges of the 1990s. Furthermore, the TIP is intended to assist State alcohol and drug agencies in implementing 45 CFR, § Part 96, which requires States to provide for independent peer review to assess the quality, appropriateness, and efficacy of treatment services by entities that receive State Substance Abuse Prevention and Treatment Block Grant funds. This TIP provides guidelines to assist States in developing criteria for State independent peer review. The TIP was developed as an initiative of CSAT's Methadone Treatment Improvement Project (MTIP), which is designed to assist States and methadone treatment providers in effectively identifying and addressing technical assistance needs.

The problem of patients who are dependent on multiple drugs and stimulants has become increasingly apparent. This TIP provides recommendations for using effective treatment practices as demonstrated by the scientific community and treatment providers. While the issue of concurrent dependency on narcotics and cocaine is sometimes viewed as a concern specific to narcotic treatment programs, the strategies recommended herein may be applied to many other treatment settings.

We hope that the substance abuse treatment community will use this TIP and will join CSAT in our commitment to enhancing the quality and integrity of treatment services to drug-dependent patients.

- David J. Mactas
- Director
- Center for Substance Abuse Treatment