# Consensus Panel

- Peter Banys, M.D.
- Substance Abuse Programs
- VA Medical Center
- San Francisco, CA

- Addie Corradi
- Associate Commissioner
- Health and Planning Services Division
- New York State Office of Alcoholism and Substance Abuse Services
- Albany, NY

- Robert Galea, Ph.D.
- Chairman
- Spectrum Addiction Services, Inc.

- Westboro, MA
- Elizabeth Khuri, M.D.
- Medical Director
- Adolescent Development Program Clinic
- New York, NY

- Herbert D. Kleber, M.D., Chair
- Professor of Psychiatry and Director
- Division on Substance Abuse College of Physicians and Surgeons
- Columbia University
- New York State Psychiatric Institute
- New York, NY

- Thomas R. Kosten, M.D.
- Associate Professor of Psychiatry
- Division of Substance Abuse
- Department of Psychiatry
- Yale University School of Medicine
- New Haven, CT

- Frances Levin, M.D., Facilitator
- Assistant Professor of Psychiatry
- College of Physicians and Surgeons
- Columbia University
- New York State Psychiatric Institute
- New York, NY

- Ira J. Marion, M.A.
- Associate Executive Director
- Division of Substance Abuse
- Albert Einstein College of Medicine
- Bronx, NY

- Edward Nunes, M.D., Facilitator
- Research Psychiatrist
- College of Physicians and Surgeons
- Columbia University
- New York State Psychiatric Institute
- New York, NY

- J. Thomas Payte, M.D.
- Medical Director
- Drug Dependence Associates, Inc.
- San Antonio, TX

- Richard Rawson, Ph.D.
- Executive Director
- Matrix Institute on Addictions
- Los Angeles, CA

- Robert Ruiz, M.D.
- North Clinic Comprehensive Psychiatric Center
- Miami, FL

- Richard Schottenfeld, M.D.
- Director
- Substance Abuse Treatment Unit
- Connecticut Mental Health Center
- APT Foundation
- New Haven, CT

- Edward C. Senay, M.D.
- Professor of Psychiatry
- University of Chicago
- Chicago, IL

- Merritt Smith, M.D., M.P.H.
- Medical Director
- Community Substance Abuse Services
- Department of Public Health
- San Francisco, CA

- Maxine Stitzer, Ph.D.
- Behavioral Biological Research Center
- Johns Hopkins School of Medicine
- Baltimore, MD

- Barbara Wallace, Ph.D.
- Department of Health and Nutrition Education
- Teachers College Columbia University
- New York, NY

- Aaron Wells, M.D.
- Medical Director
- New York Hospital Adult Methadone Program
- Cornell Medical Center
- New York, NY

- Richard Wiesen, M.D. (deceased)
- Medical Director
- Chemical Dependency Programs
- Milwaukee County Mental Health Complex
- Milwaukee, WI

- Joan Ellen Zweben, Ph.D.
- Executive Director
- East Bay Community Recovery Project
- Berkeley, CA