# What Is a TIP?

Treatment Improvement Protocols (TIPs) are prepared by the Quality Assurance and Evaluation Branch of the Center for Substance Abuse Treatment (CSAT). Their purpose is to facilitate the transfer of state-of-the-art protocols and guidelines for treating alcohol and other drug (AOD) abuse from acknowledged clinical, research, and administrative experts to the Nation's AOD abuse treatment resources. Disseminating a TIP is the last step in a process that begins with the recommendation of an AOD abuse problem area for consideration by a panel of experts. Panel members include clinicians, researchers, and program managers, as well as professionals in related fields such as social services or criminal justice.

Once a topic has been selected, CSAT creates a Federal Resource Panel, composed of members of pertinent Federal agencies and national organizations, to review the state-of-the-art treatment and program management in the area selected. This Federal panel's recommendations are then transmitted to a second group of non-Federal experts who are intimately familiar with the topic. This group, known as a non-Federal Consensus Panel, meets for about 3 days, makes recommendations, defines protocols, and arrives at agreement on protocols. Its members represent AOD abuse treatment programs, hospitals, community health centers, counseling programs, criminal justice and child welfare agencies, and private practitioners. The panel chair is charged with ensuring that the resulting protocol reflects true group consensus.

The next step is a review of the proposed guidelines and protocol by a third group-the expert field reviewers. Once their recommendations and responses have been reviewed, the chair approves the document for publication. The result is a TIP reflecting the state of the art of AOD abuse treatment in public and private programs recognized for providing high-quality and innovative AOD abuse treatment.

This TIP on assessment and treatment planning for cocaine-abusing methadone-maintained patients represents another step by CSAT toward its goal of bringing national leadership to bear in the effort to improve AOD abuse treatment.