# Chapter 4-Treatment Interventions and Related Issues

Treating methadone patients concurrently dependent on cocaine presents complex demands for the treatment team. These patients often have a variety of medical and psychological problems and benefit from a broad range of comprehensive services. Yet, while this ideal is highly desirable, our limited knowledge and the scarcity of funding and other resources, including staff, may render it unachievable. Programs cannot be expected to deliver optimal services (e.g., transportation; child care; flexible medicating hours; and housing, vocational, and family counseling) in the absence of funding and other resources to carry them out. Whenever possible, however, comprehensive strategies that combine the best of existing models of care in the local community should be applied.

The challenge in developing effective treatment interventions for this population lies in the ability to address heroin and cocaine abuse issues in a compatible manner: the appropriate treatment model for a cocaine addict may be quite different than that for a heroin addict; therefore, determining the appropriate model for a concurrently dependent addict may be problematic (Kosten et al. 1986b). Similarly, interventions effective for reducing cocaine abuse may not be as effective when used with cocaine-abusing methadone treatment patients (Condelli et al. 1991).

Adequate methadone dosing levels are essential for achieving good treatment outcomes. Ball and Ross (1991) found that a significant number of addicts continued using heroin when their methadone dose was less than 70 mg. Conversely, those patients receiving more than 70 mg stopped using heroin. Adequate methadone dosing should provide the background for the concurrent delivery of psychosocial interventions.

The following information summarizes treatment interventions used with concurrently dependent opioid and cocaine abusers.

## Treatment Interventions

A variety of treatment strategies are available, including psychosocial interventions, biomedical interventions, self-help approaches, and other adjunct treatments. Nonpharmacological psychosocial interventions, when used effectively with or without pharmacological interventions, may contribute to treatment retention, promote compliance with treatment regimens, and address the broader range of social, behavioral, and psychiatric problems characteristic of drug abusers.

When providing treatment to methadone patients who concurrently abuse cocaine, it is important to keep in mind that the goal of rehabilitation may not be feasible for individuals who have never been habilitated. Addicts whose psychological, emotional, and social development have never approached that of mainstream society need to learn the values and social skills espoused by our society. Often these concepts are not being relearned-they are being learned for the first time. Clinicians should be prepared to introduce them to patients to give them a better chance of attaining treatment goals.

### Psychoeducation

Psychoeducation is the process of presenting information about addiction to the patient and his or her family and then addressing with them their attitudes and feelings about substance abuse. Psychoeducational treatment models, when used with other treatment approaches, may increase a patient's ability to function independently and meet his or her daily living needs outside the treatment setting. Psychoeducation programs can address the full range of patient needs, including academic education, personal development, recreation, health, vocation, and relationship needs (Stark and Campbell 1991).

Strategies for Psychoeducation Programs

The following strategies can be used when developing psychoeducation programs within an MTP:

- Introduce psychoeducation at the beginning of treatment. Here, the psychoeducation program can serve as an orientation to both the clinical and recovery processes.
- Target the patient, family members, and selected friends.
- Adapt educational strategies and materials to the culture of the community being served.
- Discuss and clarify information about methadone and the myths related to its use (e.g., "it rots the bones" or "it's impossible to get off methadone").
- Discuss continuing alcohol and other drug use. Question assumptions about alcohol and other drug use and clarify how it can undermine other therapy.
- Discuss sexual behaviors, including exchanging sex for crack, using cocaine to enhance sex, intimacy and/or sex while drug free, using cocaine to ensure normal sex, and continuing sexual behaviors (e.g., prostitution) that can trigger cocaine relapse.
- Provide psychoeducation to the families of substance abusers to provide guidance in how to support recovery efforts.
- Discuss the power of "triggers" with patients and families. For example, merely discussing cocaine can be a trigger to begin using again.
- Incorporate special groups to discuss parenting, child care, women's issues, and coping with HIV/AIDS. It is important to be aware of the stigma often attached to being identified with an HIV/AIDS group. Using a generic name for the groups is recommended (e.g., Health Care Issues Group.)

### Family Involvement

A difficult history of problems usually accompanies a patient's drug use. Relationships often deteriorate, including those between spouses, parents and children, siblings, and friends. The user, if employed, often experiences difficulties in the workplace, for example, lack of concentration, mistakes, tardiness, absences, an inability to get along with coworkers, on-the-job accidents, and increased workers' compensation claims. Financial difficulties are common as the user may spend money on drugs that is needed for rent, food, utilities, and other bills. Legal problems may also develop if the user resorts to crime to support his or her drug addiction.

The impact of drug use and the problems it causes the user's family cannot be underestimated. Family members can benefit from a psychoeducational program that teaches them about drug addiction and methadone and helps them cope with the methadone patient's stages of recovery.

One such program is the Community Network Project in San Francisco, a training program for families and friends of methadone patients designed to get them involved in the patient's treatment (Bernal et al. 1985). Based within the context of the methadone program, the Community Network Project works with patient-selected "sponsors," family members or friends who are drug free and want to help in the treatment. During the 18 hours of training, the sponsor does the following:

- Learns communication and coping skills designed to enhance his or her relationship with the patient
- Receives basic information about drug addiction, family dynamics, and therapy
- Benefits from the mutual support of others in the psychoeducational group

A followup meeting of participants occurs 3 months after completion of the training.

When provided early in treatment, it is also appropriate to address, during family psychoeducation, the family's feelings of resistance to psychiatric treatment for the patient. Other issues that can be discussed in family therapy include the following:

- Information about methadone and referrals
- Enabling
- Self-help groups (e.g., Alanon, Alateen, Co-Anon)

Related Research

Bernal and coworkers (1985) identify a training program for family members that incorporates four goals:

- To help family members participate in treating methadone patients
- To disseminate information and education about addiction and treatment
- To assist in developing coping and communication skills in sponsors

### Contingency Management

Contingency management, also commonly referred to as contingency contracting, is a well-known behavioral intervention used particularly with methadone patients, including those who abuse cocaine. Contingency management is a way to reinforce desired behavior by providing immediate consequences. It can be used to improve compliance with treatment components such as attendance at counseling sessions, as well as to promote abstinence from illicit drugs. This approach is useful for treatment planning since it sets concrete goals and emphasizes positive behavior change.

Strategies for Contingency Management Programs

- Pick a specific target behavior that can be easily measured (e.g., stopping cocaine use, measured by submission of cocaine-free urines).
- Pick a reward that can be given as soon as the desired behavior (e.g., abstinence) has been documented. The reward should not be exchangeable for monetary gain (e.g., nonrefundable movie passes, a take-home medication day).
- Specify the link between the targeted behavior and the reward. For example, a drug-free urine may earn 1 take-home medication day, with the understanding that other treatment and program variables must be taken into account, including Food and Drug Administration (FDA) regulations.
- Put the contract in writing, specifying its duration and any changes over time in contingencies (e.g., after 3 drug-free weeks, the patient can receive take-home privileges).

#### Importance of Urine Testing

When contingency management is used to address concurrent use of short-acting drugs like cocaine, it is important to base consequences on objective measures of recent drug use, such as urinalysis. There must be adequate frequency of urine testing (e.g., random testing at least once per week) to detect short-acting drugs.

#### Take-Home Incentive

With patients abusing cocaine, common techniques of contingency management in MTPs involve changing a patient's methadone take-home dose privileges contingent upon recent drug use status. Stitzer and coworkers (1992), in a well-controlled study with 54 patients, found successful results when patients could earn their first take-home methadone day after only 2 weeks of drug-free urines. ^3^ A total of 32 percent of the patients who had been abusing cocaine became drug free for at least 4 weeks during the study, and most were drug free for much longer (a mean of 9.4 weeks drug free). Magura and colleagues (1988) also found that 1-month contracting for contingent take-homes produced a favorable response (e.g., drug abstinence) in 34 percent of their multidrug-abusing subjects. The take-home privilege is one of the most popular rewards available for attempting to change behavior in contingency contracting procedures, but it only motivates some patients to abstain from cocaine use.

3 To treat patients using take-home dose privileges in a manner that is less restrictive than the Federal methadone rules, a practitioner or a program must apply for an exemption and receive approval from the FDA.

Methadone dose changes have sometimes been used in contingency management. Stine and coworkers (1992) found that contingent dose increases might be useful for deterring cocaine use. However, contingent dose decreases are not generally recommended, since adequate dosing needs to be maintained to deter heroin use (Kolar et al. 1990; Payte and Khuri 1993) and since dose decreases tend to result in patients dropping out of treatment (Iguchi et al. 1988; Stitzer et al. 1986).

Often, the right to remain in the treatment program is used as a contingency with substance abusers. Dolan and colleagues (1985, 1986) found that the threat to terminate treatment effectively motivated about half the methadone patients studied to remain drug free for 30 days. Condelli and coworkers (1991) also used withdrawal from methadone as the contingency when patients tested positive for cocaine. Out of 79 patients approached, 60 agreed to participate in the contracting study. After 2 months of the intervention, positive tests for cocaine use dropped from 75 to 38 percent. Thus, the intervention was effective for those who participated voluntarily. Practitioners in the field are divided on the efficacy of discharge from methadone treatment. It is important to be aware of both schools of thought and to fully understand the clinic's philosophy on this controversial treatment issue.

#### Application of Contingency Management

It has been recommended (for example, by Stitzer and Kirby 1991) that contingency incentives be incorporated into methadone treatment, either through individual treatment plans or clinicwide policy, even if they do not work with all patients, since contingent incentives can lead to periods of abstinence among multidrug abusers and can increase drug-free time in cases of poor prognosis for permanent abstinence. Further, some of the other treatments outlined in this chapter, for example, relapse prevention and psychotherapy, could be employed during such periods of abstinence to further improve the chances of long-term success.

In summary, research has demonstrated that incentive programs using positive rewards (e.g., movie passes or methadone take-homes) are effective for promoting cocaine abstinence. However, reduction in methadone dosage or withdrawal from methadone are not recommended as initial approaches to obtaining cocaine abstinence. Other interventions (e.g., relapse prevention) may be usefully implemented during periods of abstinence.

Related Research

assessed behavioral treatment for cocaine users living in Vermont who were not in methadone treatment. His contingency system used awards for negative urine tests. It was possible for patients to accumulate about $1,000 worth of points during a 12-week period if they remained abstinent. Points were then exchanged for retail items selected by the patient and approved by the counselor as being relevant to the individual treatment plan (e.g., recreational equipment or continuing education materials). A total of 85 percent of patients stayed in treatment for 3 months, and 77 percent remained continuously abstinent from cocaine for at least 4 weeks. These high percentages suggest that this approach holds promise, although the patient population in Vermont may not generalize to large urban settings.

### Relapse Prevention

Relapse prevention approaches seek to teach patients concrete strategies for avoiding drug use episodes. These include the following:

- Cataloging situations likely to lead to drug use (high-risk situations)
- Strategies for avoiding high-risk situations
- Strategies for coping with high-risk situations when encountered
- Strategies for coping with drug cravings
- Strategies for coping with lapses to drug use to prevent full-blown relapses

Classical relapse prevention approaches make a distinction between "slips" and relapses, with slips defined as mild episodes of use that are viewed as learning experiences. While this distinction prevails among treatment professionals, some clinicians believe that with cocaine-abusing methadone patients it may be counterproductive to discuss how to prevent a slip from turning into a full-blown relapse since this approach may implicitly encourage patients to use. However, no one has adequately researched this point regarding cocaine abusers.

A recent study using naltrexone (Trexan) to treat alcoholism also looked at relapse prevention approaches used in that treatment. The study found that those patients given supportive therapy with no specific relapse prevention coping skills had higher rates of overall abstinence. However, they were more likely to have a full-blown relapse if any drinking occurred than those patients given coping skills therapy with a specific relapse prevention component (O'Malley et al. 1992). Whether these results would occur with cocaine abusers requires further study.

Numerous relapse prevention treatment approaches have been developed and are currently in use. These are conceptually and therapeutically appealing. However, research that tests the effectiveness of relapse prevention approaches with drug abusers is lacking. While relapse prevention strategies use the same overall approach for all substance abuse, management of the multidrug user may require some modification and additional emphasis (Kosten 1991).

In particular, relapse prevention therapy with multidrug abusers may require specific interventions for each substance abused because the associated risks of relapse may be different for each drug (Marlatt and Gordon 1980). For instance, a methadone patient may associate heroin use with socializing and may associate cocaine use with alleviating depression. Also, the therapist should be aware that the multidrug abuser may attempt isolated uses of the abused substances that previously had been used together, which increases the chance of sequential lapses that can lead to full-blown relapse (Kosten 1991). For these reasons, States may do well not to set limits on the length of treatment-most patients will relapse to substance abuse at some point.

One of the most important components of relapse prevention is assisting the patient to identify the warning signs of relapse. To both empower the patient and to be able to confront him or her about denial, it is critical that the therapist be well educated on the warning signs that may contribute to a resumption of drug use. A patient's false or misleading beliefs can precede relapse and serve as intervention points for the therapist. Some of those beliefs include the following (Washton 1988):

- Having an illusion of feeling cured after a few weeks or months of abstinence
- Believing that one can become a controlled or social substance user
- Idealizing the drug high, remembering only the pleasurable effects and selectively forgetting the adverse effects
- Overreacting to urges and cravings, leading to a belief that the treatment was not effective or that abstinence is not sustainable
- Denying vulnerability and not accepting the possibility of relapse, leading to overreaction if a relapse occurs (frequently leading to dropping out of treatment)
- Entering high-risk situations in denial of the risk (self-sabotage)

Assisting Patients in Building Relapse Prevention Skills

The clinician can assist the patient with the following issues to help build relapse prevention skills:

- Developing new coping skills for handling high-risk situations
- Making lifestyle changes to decrease the need for the drug(s) of choice
- Increasing participation in healthy activities
- Understanding relapse as a process and an event
- Understanding and dealing with social pressures to use substances
- Developing a supportive relapse prevention network (e.g., with significant others)
- Developing methods of coping with negative emotional states
- Learning methods of coping with cognitive distortions
- Developing a plan to interrupt a slip or relapse
- Recognizing the warning signs of relapse, including making a list of personal internal and external triggers and warning signs
- Combating powerful memories of euphoria
- Reinforcing negative aspects of the drug
- Overcoming the desire to attempt to regain control over drug use
- Avoiding people, places, and things that may trigger drug urges
- Developing an array of pleasurable and rewarding alternatives to drug use

Additional emphasis should be placed on dealing with drug cravings of multidrug users who abuse cocaine; drug hunger among these users can be particularly intense because of the powerful memory of the euphoria (Gawin and Ellinwood 1988; Gold 1992). Almost any stimulus that can be associated with cocaine use can remind the addict of the drug, even talcum powder, snow, or bread crumbs. Depending on the patient, a song, money, or the smell of a match could be a trigger (O'Brien et al. 1986).

Extinction therapy has been useful in reducing cocaine use for some patients. The patient's route of administration (intranasal, injecting, or "freebase") should be considered when developing cues for extinction therapy. An injecting user, for example, may not be influenced by a cue affecting an intranasal user.

Cognitive and Behavioral Interventions for Relapse Prevention

A variety of cognitive and behavioral interventions for relapse prevention are appropriate (Childress et al. 1992; Daley and Marlatt 1992). They include the following:

- Using clinical assessment tools that cause patients to identify how they think about their drug-taking behavior and its effects
- Teaching patients specific relapse prevention skills (e.g., behavioral rehearsal or covert modeling), cognitive reframing (e.g., coping imagery or reframing reactions to a slip or relapse), and lifestyle interventions (e.g., meditation, exercise, or relaxation)
- Reviewing common relapse warning signs and connecting these to thoughts, feelings, events, or situations
- Using cue exposure (extinction) treatment as a behavioral intervention to help reduce the patient's reactions to cues associated with drug abuse
- Planning, practicing (role playing), and implementing coping strategies and skills to deal with social pressures as well as painful emotional states
- Teaching the patients to identify their cognitive distortions (e.g., all-or-none thinking, catastrophizing, overgeneralizing)

Four treatment stages for the extinction of conditioned craving are summarized below (Gawin and Ellinwood 1988):

- During the initiation of abstinence, enforced isolation from drug use is linked with strict avoidance of conditioned cues.
- The patient is partially reintroduced to stimuli and cues through mental images elicited in a psychotherapy process to develop strategies for managing the temptation to use cocaine.
- The patient gradually reenters the cue-rich environment under controlled conditions.
- Successful abstinence is supplemented with maintenance therapies.

Related Research

- Marlatt and Gordon (1985) (referenced in Daley and Marlatt 1992) summarized warning signs as either intrapersonal or interpersonal determinants of relapse. Intrapersonal determinants (within the individual) included coping with negative emotional and physical states, enhancing positive emotional states, testing personal control, and managing urges and temptations. Interpersonal determinants included coping with relationship conflict and the social pressure to use substances, as well as enhancing positive emotional states associated with some type of interaction with others.
- Shoptaw and coworkers (1993) developed a comprehensive outpatient program for cocaine abusers. Their neurobehavioral model encompassed individual counseling, relapse prevention groups, family education groups, and 12-step groups. It was found that the longer patients were retained in the program, the more likely they were to abstain from cocaine.

Pharmacotherapies aimed at reducing craving may be used as adjuncts to relapse prevention although their effectiveness is still not clearly established by controlled clinical trials. (See the section on pharmacological interventions starting on page 41.)

For patients in methadone treatment programs, retention in the program is a significant factor in preventing relapse because the goal is to have patients continue with pharmacotherapeutic treatment for an extended period. Retention in treatment refers to the patient's ability and willingness to remain in treatment over time. Discussions of continuing pharmacotherapy with methadone should be part of the ongoing process of assessing the efficacy of treatments provided to the patient (Payte and Khuri 1993). Medical staff should ensure that patients are receiving adequate doses of methadone based on their individual needs, potential for relapse to the use of illicit drugs, and desire to remain in treatment.

Related Research

In using the IPT model, the therapist must be able to relate each drug used to the interpersonal setting. These may be either primary or secondary to other drug effects and may be tension relievers or inducers. For example, the abuser may use cocaine to reduce social isolation, but use heroin to reduce the cocaine crash. In this case, it is the cocaine abuse that will benefit from the IPT.

- A specific psychotherapy adaptation for opioid and cocaine abusers was developed by Rounsaville and colleagues (1983, 1985): Interpersonal Psychotherapy (IPT). This model is based on the premise that an individual attempts to cope with problems in interpersonal functioning through multiple drug abuse. Kosten (1991) uses the IPT to address specific areas that help the patient stop cocaine and opioid use:
  - Compare the adverse effects of abused drugs with the benefits that the patient perceives.
  - Identify the thoughts and behaviors that precede drug use.
  - Develop strategies to deal with drug-related cues and high-risk situations.
  - Develop more productive means for achieving the desired social gratification.

- Compare the adverse effects of abused drugs with the benefits that the patient perceives.
- Identify the thoughts and behaviors that precede drug use.
- Develop strategies to deal with drug-related cues and high-risk situations.
- Develop more productive means for achieving the desired social gratification.

- Woody and coworkers (1983) examined the efficacy of supportive-expressive psychotherapy, another adaptation of psychotherapy for substance abusers, with patients in an MTP. Patients received either substance abuse counseling alone, counseling with supportive-expressive therapy, or counseling with cognitive- behavioral psychotherapy. Both psychotherapy groups showed greater improvement in more outcome domains than those who received the substance abuse counseling alone. Gains made by suts who received psychotherapy were sustained over a 12-month followup. The differences between treatments were most notable among patients having high levels of psychiatric symptoms. It was among this subgroup that psycbjechotherapy improved outcome over that obtained by drug counseling alone.

### Psychotherapy

Psychotherapy for drug abusers evolved out of methods initially developed to treat other conditions (Rounsaville and Carroll 1992). In general, an accurate definition of psychotherapy distinguishes it from counseling: psychotherapy focuses on intrapsychic processes that impair effective coping and damage relationships, while drug counseling historically has focused on external issues relating to the patient's life problems (Zweben 1993). Early versions of psychotherapy with substance abusers were found ineffective because they focused too heavily on intrapsychic conflict and not enough on symptom control (Rounsaville and Carroll 1992). The prevailing approach in substance abuse treatment programs is to emphasize reducing drug use while pursuing other goals only after drug use has been at least partially controlled. This strategy means either providing psychotherapy as part of a larger comprehensive program or employing techniques to reduce drug use as an integrated part of psychotherapy (Rounsaville and Carroll 1992).

Views differ on when to introduce psychotherapy. Some researchers indicate that psychodynamically oriented psychotherapy may not be useful either because it is ineffective or because in some patients it may precipitate relapse by stimulating feelings the patient is not yet able to handle. They suggest that exploratory psychotherapy should be used after 6-12 months of abstinence and only with those who wish to explore psychological problems in depth (Washton 1988). On the other hand, psychotherapy oriented to the stages of recovery is useful. For example, during the first 90 days to 6 months of treatment, patients need substantial support to manage painful emotions and interpersonal stress (Wallace 1992). In this context, psychotherapy can play a key role in helping patients deal with their emotional states instead of self-medicating with drugs.

Common Strategies for Psychotherapy

- Devoting a part of the session to monitoring the patient's most recent successes and failures in reference to his or her addiction
- Adopting a more active therapist role than would typically be required for treating other psychiatric disorders
- Working with the patient to bring about a resolve to stop using drugs instead of attempting to return to the days when drug use was enjoyable. (This strategy includes helping the patient develop a clear picture of life without drugs.)
- Teaching the patient to recognize the warning signs of potential relapse as well as develop new coping skills to help avoid relapse
- Supporting the patient in learning to rearrange priorities so that preoccupation with drug use no longer consumes time. (This strategy may involve acquiring new job skills, developing hobbies, and rebuilding relationships. The patient may need help with motivation and with exploring factors that interfere on a psychosocial level.)
- Assisting the patient in managing painful affects, since clinicians recognize that this discomfort is associated with compulsive drug use and relapse. (This strategy involves exploring the cause of such feelings.)
- Working with the patient to enhance interpersonal functioning and social supports to gain the rewards of friendships and relationships to replace drug use
- Exploring interpersonal relationships and the impact of substance abuse on these relationships
- Using psychotherapy only after a strong therapeutic alliance has been developed with the patient or within the context of other supportive structures that guard against relapse

### Cognitive and Behavioral Therapies

Trained substance abuse therapists can combine cognitive and behavioral therapies as one cognitive-behavioral therapy or use them as separate intervention techniques. When used as a combined technique, cognitive-behavioral therapy focuses on uncovering and understanding the relationship between automatic thoughts and underlying assumptions about problematic feelings and behaviors (Zweben 1993). When used separately, cognitive therapy focuses on restructuring self-destructive thought patterns to create healthy patterns of relating to oneself and others. Behavioral therapy focuses on modifying behaviors that lead to self-destructive ends and rewarding positive healthy behaviors that enhance self-care and lead to healthy relationships.

Behavioral therapies are generally used in substance abuse treatment programs to suppress antisocial behavior of patients. In this sense, the behavioral intervention takes the form of rules and regulations about standards of behavior while in treatment and includes sanctions for rule breaking (Woody et al. 1985).

With some patients who abuse cocaine, intense cravings can resurface weeks and sometimes months after abstinence has been achieved. If the patient is not aware of this phenomenon, relapse may be more likely (Carroll 1992). Behavior therapy using cue exposure treatment (extinction) is designed to reduce the drug-craving response. This therapy uses repeated exposure to such stimuli to help the patient master the experience without using drugs. For example, talcum powder can be used to provide a cocaine-like stimulus. The patient is helped to find a substitute image (e.g., a beach scene) to counter the drug craving experience, until he or she reports no more drug craving when exposed to that stimulus. Visual images can also be used as stimuli. The more authentic the stimulus is to the patient's experience, the more effective the technique. (Questionnaires to elicit information on both external and internal triggers can be found in appendix I.)

Cravings, or urges, are normal for a patient who is attempting to stop abusing drugs (Kadden et al. 1992). It is helpful to devise other methods for coping with cravings before they occur. Some examples follow:

- Becoming involved with a distracting activity such as exercising or going to a movie
- Talking through the craving with a friend or member of a self-help group
- Challenging and changing one's thoughts by keeping a list of the negative consequences of abuse and the positive reasons for being drug free
- "Urge surfing," a technique that likens urges to ocean waves; that is, they are small when they start, will grow in size, and then will break up and dissipate. Urge surfing is composed of three basic steps:
  - Taking an inventory of the craving experience as it affects the body
  - Focusing on one area where the urge is being felt and noticing what is occurring
  - Repeating the focusing process with each part of the body that experiences the craving

The purpose of urge surfing is to experience the cravings in a new way and to "ride them out" until they go away (Kadden et al. 1992).

Related Research

- The efficacy of a cognitive-behavioral approach was demonstrated by Woody and coworkers (1983, 1985), where both cognitive-behavioral and supportive-expressive therapies were related to the greatest number of positive patient changes.
- Beck and colleagues (1979) showed that cognitive therapies have been particularly appropriate with depressed patients. These can be modified for a substance-abusing population.
- Rawson and coworkers (1990) developed a neurobehavioral model for outpatient treatment for cocaine dependency. The model is a comprehensive, time-limited program combining a range of strategies, including relapse prevention and individual therapy procedures, family systems materials, 12-step programs, and urine testing. It is designed to address cocaine abusers' problems at the moment they enter treatment, with no assumptions about underlying psychopathology.

### Self-Help Programs

Self-help programs have been used for primary cocaine addiction. They are appropriate both during active participation in a treatment program and as a practical continuing care service for long-term, stabilized patients who no longer require intensive one-to-one primary care (Nurco et al. 1991). Historically, the most popular and widely used self-help model is that of 12-step recovery programs. Twelve-step recovery programs appropriate for multidrug abusers of opioids and cocaine include Narcotics Anonymous (NA), Cocaine Anonymous (CA), and Alcoholics Anonymous (AA). They can serve as a valuable source for social support, peer identification, and role modeling, and offer an effective conceptual framework for relapse prevention and successful recovery (Washton 1988). Members gain strength and security from meeting with others who understand and share their concerns and who can offer practical strategies for surviving "one day at a time" (Gold 1992). In addition to their effectiveness when used in conjunction with a treatment program, the ongoing nature, wide availability, and absence of fees of 12-step programs support the notion that recovery is a lifelong process involving permanent changes in attitude and lifestyle (Washton 1988).

The programs are based on 12 steps that help members focus on gaining strength toward lasting recovery. Examples of the steps' themes are admitting powerlessness over the abused drug(s), accepting help from a power greater than oneself, and taking a fearless moral inventory of oneself. By accepting and carrying out the 12 steps and attending meetings regularly (as often as daily for some), many recovering addicts are able to reduce their sense of isolation and demoralization, leading to a better chance of ceasing drug use and remaining abstinent (Millman 1988).

For methadone patients, 12-step programs can pose certain problems: since such programs espouse total abstinence and these patients are maintained on methadone, they often feel out of place and unwanted. As a result, they may try to hide the fact that they participate in an MTP (Nurco et al. 1991). The national office of AA maintains a clear position that people on appropriate medication are welcome (Zweben 1993). However, other 12-step programs (e.g., CA and NA) and some local AA groups may not welcome methadone patients. Clinics can help alleviate this problem by directing patients to meetings that are more accepting of them, by developing specialized 12-step meetings at the methadone treatment site, or by working with other methadone programs to establish a 12-step group (Zweben 1993).

A variant of this idea, Methadone Anonymous (MA), was developed at Man Alive Research, Inc., in Baltimore, MD, in response to discrimination that methadone patients perceived in other 12-step groups. Methadone Anonymous defines methadone as a tool for recovery, not an obstacle to it. Issues related to the recovery process and how to overcome the discrimination directed toward methadone patients are discussed in MA meetings in conjunction with how to achieve and maintain sobriety over illicit drugs and how to avoid relapsing. Methadone Anonymous now has chapters in 47 States.

Recovery-oriented psychotherapy (Zweben 1987) generally assumes 12-step participation by the patient while he or she is also receiving professional treatment. Recovery issues encountered in the 12-step program can be simultaneously addressed by the therapist, with the therapist's methods changing to match the evolving needs of the patient.

In chapters where methadone patients are accepted, CA may be an appropriate choice of 12-step groups. Cocaine Anonymous can provide support, strength, and hope for its members. Like AA, the program from which CA developed its structure, participation is free of charge and open to all who wish to stop using cocaine and other mind-altering substances. In many areas of the country, there are also Co-Anon chapters for families of cocaine addicts. Co-Anon, a sister organization of CA, offers support and friendship for individuals struggling to cope with the cocaine addiction of a loved one (Bohlen 1989). However, CA is less well established than AA, and in some areas of the country patients may have difficulty finding a cohesive CA group. Some patients may find that the CA meeting provides stimuli and may provoke use. If the patient reacts in this way, it may be more appropriate to attend AA meetings.

Several other self-help models have been developed, although they are not widespread. An example is the Clinically Guided Self-Help (CGSH) model, developed at the Social Research Center in Baltimore, MD, a viable and cost-effective adjunct to primary treatment (Nurco et al. 1991). Participation is voluntary and draws on patients' motivation to take greater responsibility and control of their lives. Staff members provide information and skills training necessary for the patients to run their own groups and set their own behavior standards. The groups are small (5-12 members) and are designed to provide stabilized patients with the following:

- A positive peer support network
- Constructive, non-drug-oriented social and recreational activities
- A means of reinforcing the growth achieved by primary treatment
- An opportunity to engage in outreach and advocacy projects to help others

Preliminary assessments of the program suggest that those participating in the self-help process have lower relapse rates, as reflected by urinalysis, and greater treatment retention rates than those not participating (Nurco et al. 1991).

Rational Recovery (RR) is a free self-help program that distinguishes itself from the traditional 12-step programs. Associated with the Institute for Rational-Emotive Therapy, RR stresses self-control and the power of the individual. It may appeal especially to those patients who do not accept the concept of the "higher power" that is the basis of AA, CA, and NA. Rational Recovery also differs from the traditional 12-step programs in its assertion that a person can recover from addiction, rather than always being in recovery (Rational Recovery Systems n.d.). Similar programs that have been advocated include Women for Sobriety and Secular Organization for Sobriety (SOS).

## Followup and Continuing Care

Patient followup and continuing care are critical to ensure the patient's success in remaining abstinent from heroin and cocaine abuse. Given the likelihood that some patients will relapse, it then becomes important for programs to educate patients about the relapse process and facilitate reentry into treatment quickly if relapse occurs. Followup and continuing care services create a continuum of support for the patient and need to be properly funded.

Strategies for Followup and Continuing Care Services

Strategies used to plan and implement followup and continuing care services include the following:

- Educating the patient about continuing care options, including pharmacotherapy
- Providing some continuing care services as an inhouse adjunct to the treatment program that incorporate some of the earlier program elements (e.g., individual counseling on a less frequent basis) and offer new elements (e.g., continuing care support group)
- Linking patients with relevant supportive services in the community at discharge when the program itself does not have these services available
- Following up with the patient at regular intervals following discharge (e.g., 30 days, 6 months, or 1 year) for a minimum of 1 year
- Collecting followup information by using a survey mailed to the patient or making an appointment for the patient to visit the therapist who provided earlier treatment

## Special Issues

### Detoxification

It is debatable whether detoxification is necessary or even helpful for treating withdrawal from cocaine. While development of tolerance and the presence of a withdrawal syndrome have been identified in individuals regularly using cocaine, most patients have little difficulty initially stopping the use of cocaine; detoxification may not be indicated. However, patients have difficulty in maintaining long-term abstinence. A variety of pharmacological approaches have been attempted during the early phases of abstinence from cocaine to promote the patient's ability to remain drug free and decrease chances of relapse. The efficacy of these approaches remains unclear (see chapter 7: Consensus Panel Recommendations for Further Research).

### Pharmacological Interventions

Some clinicians may be reluctant to prescribe medications for patients who need drug addiction treatment. Physicians in MTPs may have less difficulty with this concept, as they have accepted the notion that medication is appropriate for treating drug addiction. Yet, even doctors in MTPs may remain reluctant to give medications with addictive potential for problems other than for substance abuse.

In deciding whether to initiate pharmacotherapy, several factors must be considered (Kosten 1992):

- Motivation(s) for seeking treatment, including psychiatric comorbidity
- Phases of recovery
- Associated psychosocial problems
- Potential for relapse

When appropriate, it is clear that pharmaco- therapies should be used:

- Within a comprehensive program that blends medical, psychiatric, and social interventions and supports the patient in complying with medication dosing schedules
- Within the context of the multidisciplinary team approach where regularly scheduled meetings of the multidisciplinary team are necessary to ensure that all team members are aware of the patient's progress in treatment, including the pharmacotherapeutic component
- With a careful selection of prescription drugs because some substance abusers will attempt to "get high" on any medication prescribed. Some medications with little abuse potential in other populations may pose a significant risk of abuse in this population (Woody et al. 1991)

For those patients who do receive medications, the following procedures have been found to be useful:

- The duration of the prescription should be carefully monitored by the program physician and other interdisciplinary staff.
- The necessity of prescription renewals should be discussed with the multidisciplinary team.
- Patients receiving prescriptions should be seen once a week by their clinicians.
- All numbers should appear in both the figure and spelled-out forms (e.g., 42 [forty-two]).
- Incidents of patients requesting prescriptions significantly earlier or later than scheduled should be documented and discussed.

For methadone patients concurrently dependent on cocaine, a variety of pharmacotherapies are currently being evaluated for use in conjunction with opioid addiction, detoxification, or methadone treatment. Pharmacological treatment of cocaine abuse generally involves using antidepressants, dopamine agonists, increases in methadone dosage, or other pharmacologic agents that either block the acute effects of the cocaine, or reduce drug craving. Additionally, new long-acting maintenance agents for opioids, such as levo-alpha-acetylmethadol (LAAM) (recently approved by the FDA and marketed as Orlaam) and buprenorphine (Buprenex) are being explored. LAAM's effectiveness in reducing opioid drug craving and preventing opioid drug withdrawal is similar to that of methadone but does not require daily dosing. There is no information yet on LAAM's impact on concurrent cocaine abuse. Buprenorphine, which is being studied as an alternative to methadone, was originally thought to have some usefulness in treating cocaine abuse (Kosten 1991; Kosten et al. 1989b, 1989c; Mello et al. 1989), but the most recent research casts doubt on this finding (Schottenfeld et al. 1993). Some treatment successes have been documented for pharmacologic agents, but the efficacy of these medications is still being researched (see chapter 7). Of course, using such drugs to treat concurrent cocaine abuse is a different issue than using psychotropic medications for clearly comorbid conditions, for example, antidepressants for depressed cocaine/opioid abusers.

### Treatment Implications for Patients With Psychiatric Comorbidity

It is important to recognize psychiatric disorders in cocaine and heroin abusers because they are prevalent and are associated with poor treatment outcomes. The most commonly encountered psychiatric disorders in this population are listed in table 1 , in the approximate order of their expected prevalence in heroin and cocaine abusers (Kosten et al. 1989a; Rounsaville et al. 1982).

Table 1. Commonly encountered psychiatric disorders among cocaine and heroin abusers

Table 1. Commonly encountered psychiatric disorders among cocaine and heroin abusers
Disorder Category | Disorder
Axis I | Affective disorders Major depression Dysthymic disorder Bipolar disorder
Axis I | Anxiety disorders Panic disorder Agoraphobia Social phobia Posttraumatic stress disorder
Axis I | Attention deficit hyperactivity disorder
Axis I | Schizophrenia
Axis II | Antisocial personality disorder Narcissistic personality disorder Borderline personality disorder

The frontline clinician working with cocaine- and heroin-abusing patients may be in the best position to recognize these disorders in the patients. Therefore, the clinician should have a working familiarity with how the disorders present. Definitive diagnosis and treatment may be best handled by referral to an experienced mental health clinician (e.g., psychiatrist, psychologist, or psychiatric social worker). It is ideal for a mental health clinician to be an integral part of the treatment team and to diagnose and treat on site. This capability will not be possible at all clinical sites, in which case ready availability of outside consultants and referral sources is recommended.

Symptoms of cocaine, other-stimulant, and narcotic abuse can mimic a variety of psychiatric disorders and symptoms. To avoid misdiagnosis, the clinician must carefully elicit the patient's lifetime history to determine whether any psychiatric disorder has occurred during periods of abstinence or minimal drug use. For example, patients who present symptoms of hyperactivity, impulsivity, or inattentiveness may indeed be abusing cocaine. However, these symptoms are also characteristic of attention deficit hyperactivity disorder (ADHD), and it is essential that clinicians be aware of the possibility that ADHD may be an underlying problem. Psychiatric diagnosis should usually be withheld until the patient has been stabilized in substance abuse treatment (minimum, 5-7 days; preferable 2-4 weeks) and drug use is either reduced or eliminated. Although several weeks of abstinence will allow the clinician to diagnose more accurately, severe psychiatric symptoms (e.g., suicidality or a psychotic reaction) need to be attended to promptly (Ziedonis 1992). Many psychiatric syndromes, however, will be resolved once the drug abuse is treated.

An overview of psychiatric disorders to aid clinicians in screening patients and to indicate the range of possible treatment options is provided in appendix H. Exact DSM-IV criteria can be found in the DSM-IV manual and handbooks (American Psychiatric Association 1994). The Structured Clinical Interview (SCID) for DSM-IV may also be a useful tool for clinicians, since it suggests standard questions for eliciting the various disorders.

The following characteristics of this population should be considered in developing a therapeutic response (Borant 1992):

- Patients with psychiatric comorbidity do not readily self-identify in exclusively addiction-oriented groups. The patients feel most at ease with others who are also suffering from similarly diagnosed psychiatric problems.
- Groups are effective with psychotic individuals as long as the patient is able to tolerate a group session without causing disruption.
- A relapse in one disease increases the chance of relapse in the other. Stress may lead to a relapse in either.
- Patients with psychiatric comorbidity may have special problems that may not be adequately dealt with by either system; therefore, they may be given conflicting messages about the use of medications.

The following principles are essential in the clinical management of patients with psychiatric comorbidity:

- The treatment of the psychiatric illness should be well coordinated with the substance abuse rehabilitation.
- Physicians treating substance abusers should be knowledgeable about addictive diseases, and substance abuse counselors should understand psychiatric illness and its treatment. See the preceding section of this chapter on pharmaco- logical interventions.
- Psychotropic medications should be prescribed only when spontaneous remission has been ruled out and only after the patient has stabilized (3 weeks to a month). Dependence-producing agents should be avoided.
- Patients are often fearful of and resistant to receiving a psychiatric diagnosis. This resistance should be addressed by assuring patients that it will allow them to receive optimal treatment.
- Therapy should be more active than therapy for single diagnosis psychiatric patients, with the primary goal being abstinence rather than insight.
- An initial family meeting is often effective early in treatment and is an appropriate time to address the family's feelings regarding how the addiction has affected them, as well as any resistance to psychiatric treatment for the patient (Stanton and Todd 1982).
- Patients need to be told that their mental state may have been induced by their cocaine use. If depression, anxiety, or psychosis persist after 1 month, patients should be reevaluated.
- Physicians should be alert to the presence of panic disorders, which can be dangerous, especially when suicidal ideation is present.

Cocaine-dependent methadone patients diagnosed with depression have improved treatment outcomes if psychotherapy and pharmacotherapy are both integrated into their treatment plans (Ziedonis and Kosten 1991). When treating cocaine and heroin abusers for depression, it is important that depressed addicts acknowledge their need for drug rehabilitation and abandon their common belief that the addiction will disappear when the depression lifts (Dackis and Gold 1992). Substance abuse treatment requires effort and sacrifice on the part of the patient, while affective illness usually responds well to pharmacotherapy. Cognitive therapies can be effective with this population when used with pharmacotherapy. Interpersonal therapy (IPT) can also be effective in treating depressed heroin and cocaine addicts (Rounsaville et al. 1985).

In treating anxiety disorder among cocaine and heroin addicts, it is important to guard against indiscriminate use of medication. Anxiety is a cardinal feature of early recovery and may not indicate a disorder unless the anxiety symptoms persist after detoxification (Dackis and Gold 1992). Patients with anxiety disorder are likely to self-medicate with opioids, which can cause a vicious cycle of craving and euphoria (Dackis and Gold 1992; Kosten et al. 1986b). The therapist will need to be aware of this risk.

Related Research

- Kosten (1992) suggested that patients seeking treatment for cocaine abuse were psychiatrically vulnerable; up to 35 percent were concurrently depressed (Kleber and Gawin 1984; Rounsaville et al. 1991; Weiss et al. 1986). Specific interventions, therefore, may need to be undertaken for cocaine abusers who have this psychopathology.
- Nunes and colleagues (1991) identified methadone patients with chronic depression and treated them with the antidepressant imipramine. A total of 9 of 17 (53 percent) showed substantial improvement in both mood and decreased illicit drug use; 5 of these 9 responders were injecting or freebase cocaine users. Since depression occurs frequently among opioid addicts and cocaine abusers, this research suggests that diagnosing and treating depression in these patients is a useful strategy and may result in reduced cocaine use as well as improved mood.

According to DSM-IV, a diagnosis of antisocial personality (ASP) disorder should be made only if the associated characteristics occurred prior to age 15 and are not the result of the addict's lifestyle; in other words, they must precede the substance abuse. Conventional psychotherapy is not effective in treating substance abusers with ASP (Shamise 1981; Woody et al. 1985). Many patients with this diagnosis do not respond well to treatment (Rounsaville et al. 1983; Woody et al. 1991). However, behavioral interventions have been used to suppress antisocial behavior of patients whether or not full-blown ASP was indicated (Walker 1992; Woody et al. 1991). In addition, there is evidence of a strong association between high-risk behavior (such as needle sharing) and patients suffering from psychological stress (Metzger et al. 1991).

Related Research

- Woody and coworkers (1991) found that addicts with ASP often have other psychiatric disorders. In particular, patients with depression as well as ASP tended to benefit from therapy more than addicts with only ASP. The authors suggested that this result may occur either because these patients have at least one disorder that is responsive to psychotherapy or because depressed ASP patients have more capacity to relate to people and events and to experience their feelings. The study was done with patients in methadone treatment; although it may apply to persons with cocaine dependence, it has not been studied in this population.

### Prescribing Psychotropics for Patients With Other Psychiatric Problems

A variety of psychiatric problems may accompany narcotic addiction and require concurrent use of psychotropic medications with methadone. Clinicians should carefully review possible drug interactions when combining psychotropic medications with methadone (Woody et al. 1991). Drug interactions that may not normally be present in nonsubstance abusers may appear in substance abusers because they tend to experiment with drugs. For example, using benzodiazepines with methadone may produce a clinically significant high not normally obtained when either drug is used alone. When monoamine oxidase (MAO) inhibitors are prescribed for depression, the clinician needs to be aware that serious drug interactions may occur if the patient uses prescribed medications (e.g., meperidine [Demerol]), or illicit drugs (e.g., cocaine).

Kleber (1983) summarizes the use of psychotropics for various disorders as follows:

- For schizophrenia, neuroleptics can be used at lower doses than normal but with caution, to avoid the possibility of tardive dyskinesia.
- Lithium can be used for manic disorders. Patients may experience increased drowsiness as a side effect.
- Minor tranquilizers used for anxiety may pose a problem when used by drug-addicted patients because of the possibility for abuse.
- MAO inhibitors used for depression may have dangerous drug interactions when used by drug-addicted patients.
- When using tricyclic antidepressants to treat major depression, care should be taken to establish that the depression has persisted for a clinically significant length of time.

## Patient Noncompliance

To assist patients who concurrently abuse opioids and cocaine to comply with program rules, it is necessary to (1) understand the psychosocial factors influencing the patient and (2) implement action based on understanding the patient's problem. It is also essential to provide a fair set of treatment options that responds to the patient's needs. Patients can become extremely opposed to the total abstinence ideal if they feel pushed too far (Barthwell and Gastfriend 1993).

To assess a patient's motivation for treatment, the clinician should first review what is known about the patient. If this information does not explain the patient's compliance problem, the clinician may need to collect more data about the patient. Collecting more data usually leads to enhancement of services, including moving to a more intensive level of care, such as a day program or therapeutic community.

Understanding the patient's resistance to treatment may be facilitated by asking a series of questions:

- Does the patient feel overwhelmed by the demands of the treatment?
- Are there special circumstances contributing to continued drug use (e.g., a spouse who is also a user; community conditions, including a prodrug environment; many users in the work environment)?
- Does the patient feel involved in his or her treatment?

Summary of Strategies for Patient Compliance

- Review what you know about the patient. Collect more data if necessary.
- Enhance your understanding of the patient by identifying and thoroughly investigating his or her resistance to treatment. Develop methods for ameliorating noncompliance behaviors.
- Consult with the treatment team to both supplement patient evaluation and solicit recommendations for treatment.
- Review program policies and procedures. Establish a philosophy of treatment that allows for the needs of individuals and makes distinctions among the various drug- abusing behaviors and lifestyles.
- Recognize the various stages of a patient's motivation and plan interventions accordingly (Miller and Rollnick 1991; Prochaska and DiClemente 1982).
- Network with probation and social service officials to promote a comprehensive strategy to increase a patient's compliance with treatment.
- Make special provisions for access to treatment in unusual circumstances, such as for a patient who is disabled or has atypical employment considerations.
- Consider the patient's socioeconomic background in assessing his or her ability to effectively advocate for himself or herself, and provide extra support when necessary.
- Effectively use role models within the program.

Approach a patient's resistance to treatment sensitively. If the patient feels overwhelmed by the demands of the treatment regime, he or she may drop out of treatment and feel more discomforted and demoralized than before admission (Miller and Rollnick 1991; Millman 1988). Be aware of limit setting within treatment strategies that can directly affect patient motivation. Although limit setting is necessary, effective treatment involves collaboration between the patient and therapist, reflecting the need to promote autonomy and responsible decision making on the part of the patient (Zweben 1993).

It may be helpful, especially in more difficult cases, to meet with the treatment team and review their recommendations in addition to those of the counselor. If necessary, the clinical supervisor should intervene by evaluating the patient and providing supervision to the counselor. The treatment team and the clinical supervisor may provide a more powerful intervention than the counselor alone.

On a more procedural level, it is important to develop a program philosophy that distinguishes the needs of different types of drug abusers. An overgeneralized treatment approach does not adequately engage a patient in treatment (Millman 1988). Also, the program's policies should be reviewed by asking the following questions:

- Has the program developed a spectrum of services: day care, therapeutic community, evening care for working patients?
- Does the program policy provide for clinical recognition of the treatment/recovery phase?
- Are all staff regularly provided an arena to discuss ethnic, gender, and minority issues?
- What is the program's policy for maintaining a therapeutic climate?

Cocaine-abusing patients in methadone programs have been shown to have higher rates of noncompliance with program rules and regulations than those who do not abuse cocaine (Condelli et al. 1991). A variety of strategies can be used to help motivate patients to comply with their program and stay in treatment.

The list in the text box to the left gives some of the major points of consideration.

Related Research

- A study by Hunt and colleagues (1984) found that patients reporting cocaine use were more likely to use heroin and spend time on the street and less likely to conform to program rules, receive take-home privileges, and hold jobs or seek employment than patients who did not report cocaine use.

Several program elements should be considered that can affect patient compliance and subsequent retention in treatment:

- Adequacy of methadone dosage
- Geographic ease of access to clinics
- Convenient hours sensitive to patient need
- Affordability of care
- Staff availability and access (to minimize patient discouragement)
- Staff competence in responding to cultural, ethnic, gender, and social factors
- Quality of social services (e.g., family, employment, and financial assistance)
- Provision of a complete and holistic service continuum that includes primary medical, psychiatric, obstetric and gynecologic, and HIV services
- Staff attitudes and a program atmosphere that convey respect, dignity, and compassion toward the patient
- The inappropriateness of short-term MTPs for these patients

## Spiritual Issues

A drug user with a high degree of religious motivation sometimes finds that treatment programs that include spiritual guidance or counseling can produce positive outcomes (Muffler et al. 1992). Since affiliation with religious organizations has long been an important component of American culture, it makes good sense to draw on these resources to help treat substance abusers. Larson and colleagues (1988) have noted, however, that more effective collaboration between religious organizations and other community providers (e.g., mental health professionals) would increase the benefits to individuals seeking help for their substance abuse problems.

More than ever, Protestant and Catholic churches are responding to the needs of this part of their congregations, usually by sponsoring and providing meeting space for AA or NA groups (Muffler et al. 1992). One advantage offered by church-oriented programs is the support offered by others in a socially sanctioned group.

Churches have a long history of commitment to serving their parishioners in time of need. They are finding that contemporary social problems require a reexamination of the services they deliver. For example, people who work in programs developed for the HIV/AIDS population or the homeless recognize that alcohol and other drug abuse can be a major deterrent to achieving a functional lifestyle. This recognition has compelled churches and other religious associations to find ways to address substance abuse within their established programs (Muffler et al. 1992).

Participation in church-sponsored programs is not for everyone; however, for patients for whom religion or spirituality is an important part of their cultural milieu, the churches may play a pivotal role in helping the substance abuser resolve to seek help.

## Issues for Special Populations

Although cocaine dependency touches the lives of many different groups who are part of the same clinic environment, certain populations warrant special attention. Among these are women, especially pregnant women; adolescents and young adults; families with children; persons with HIV/ AIDS; and persons with TB. Clinics may be able to offer specialized services to some of these groups. For example, some clinics have obtained special funding for services to pregnant women or children of substance abusers. Optimally, more specialized services would be available in drug treatment programs, since such ready access to these popu- lations provides opportunities for public health intervention. This section provides an overview of issues to consider when treating special populations.

When working with these populations, it is important for clinics to do the following:

- Employ counselors and therapists who understand the unique factors that may impact on each of these subpopulations, such as socioeconomic status, cultural and value systems, race, ethnicity, gender, sexual orientation, and media misrepresentation
- Modify therapy and consider therapist selection on the basis of the age, ethnicity, and gender of the patients. Some patients may be distrustful of therapists who are of a different gender, socioeconomic status, or culture. Explore these issues with the patient early in treatment
- Provide cross-cultural competency training for staff to enhance counselors' ability to effectively serve various subpopulations

### Women

It is well accepted by clinicians that women need to be treated with sensitivity to their special needs and problems. Such sensitivity may be critical to successful treatment. Women who have been long-term substance abusers may have complex and multiple medical problems, including gynecological infections, amenorrhea, hypertension, hepatitis, TB, pneumonia, sexually transmitted diseases, and HIV infection (Brown et al. 1992). Women face both external and internal barriers to entering treatment:

- Many women enter the treatment system with a long history of childhood emotional, physical, and sexual abuse. Such abuse may not be mentioned or discussed by either the patient or the therapist. However, after initial stabilization for substance abuse problems, counseling may begin focusing on the patient's intimate relationships. Counselors should be aware that unresolved physical and sexual abuse issues may become primary relapse hazards.
- It may be difficult to reduce addicted women's risk of contracting HIV. Addicted women's sexual partners are often injecting drug users. Women may be unwilling to raise issues of safer sex or needle sharing because they fear rejection or physical violence if they urge safer sex practices with their partners. These women may benefit from group therapy and eventually from assertiveness training.
- Women with a history of narcotic and/or cocaine addiction may engage in prostitution to finance their drug use. Sometimes they come from a subculture where sex for drugs and money is common, and they may work for pimps who control them by supplying heroin or cocaine as well as money. By continuing their opioid use, prostitutes find they can numb themselves to their work, handle long working hours, sustain their energy levels, and remain somewhat confident despite their difficult living situations. Many treatment centers have found that women who trade sex for drugs or money usually have an underdeveloped sense of femininity and sexuality (Winick 1992). These women may be helped by treatment that incorporates these issues into the treatment plan.
- Child care responsibilities present a major barrier to consistent participation in treatment. The cost of child care and the inability of programs to provide on-site day care while the mother is in therapy may present obstacles to beginning or remaining in treatment. Lack of transportation can also be a barrier to seeking or maintaining treatment and should be evaluated for each patient.
- Family planning services, including reproductive education, should be available in any treatment program, but especially where cocaine abuse is a problem. Family planning practices become an issue because some women confuse amenorrhea caused by substance use with infertility. Before entering treatment, they may have been sexually active for many years, without using contraceptives and without becoming pregnant. Given that substance abuse treatment pharmacotherapies help to normalize endocrine function and shift eating patterns, women in early stages of treatment may become pregnant unexpectedly. Assertiveness training may be appropriate for sexually active women but should be considered with care in the absence of an adequate support system (e.g., a "safe place") and group therapy or self-help groups.
- Clinicians should advise pregnant women who continue using cocaine that some State regulations require reporting illicit substance use to child protective services or other appropriate agencies.
- Socioeconomic factors, such as discriminatory hiring practices, low wages, and stigmatization may cause low self-esteem, shame, and guilt and contribute to continued drug use by women.

It is important to recognize these issues when planning treatment interventions for women and to provide educational information about possible health risks specific to women.

#### Pregnant Women

The use of opioids and cocaine during pregnancy can cause medical and obstetrical complications and affect the development of the fetus. Clinicians should take care to designate pregnant drug-dependent women as "high risk" and closely monitor the medications given for drug dependence treatment over the course of the pregnancy.

In addition to biomedical consequences found in any opioid-dependent person, heroin is known to cause neonatal abstinence syndrome, low birth weight, prematurity, stillbirth, and sudden infant death syndrome (Finnegan and Kandall 1992).

Increased numbers of pregnancy complications are specifically associated with the use of cocaine. These include spontaneous abortion, poor weight gain, and precipitous delivery (Finnegan and Kandall 1992). The appetite suppressant effect of cocaine may compromise the nutritional needs of the mother and fetus and can interfere with a successful delivery. Cocaine has also been found to pass into breast milk (Smith 1986). Possible effects on the fetus associated with cocaine use include mild neurodysfunction, transient electro- encephalogram abnormalities, cerebral infarction and seizures, vascular disruption syndrome, and smaller head circumference. There is some evidence that cocaine use may cause congenital anomalies. However, other factors may also be responsible, including alcohol, nicotine, or other drug use; general poor nutrition; and the patient's lifestyle.

The use of methadone treatment for narcotic dependency during pregnancy has been well-studied and established. Research indicates that methadone can be successfully used during pregnancy without major adjustments in dosage and, in fact, may provide the following advantages (CSAT 1993a):

- Reduces or eliminates illegal opioid use
- Buffers opioid-dependent women from the drug-seeking environment and eliminates the "necessary" illegal behavior
- Prevents the sharp fluctuations of the maternal illicit drug levels that may occur throughout the day and are detrimental to the developing fetus
- May reduce, control, or even eliminate multidrug abuse because of exposure to a drug treatment environment in which all drug use is discouraged and abstinence is rewarded
- Improves maternal nutrition and increases the weight of the newborn
- Improves the women's access to and ability to participate in prenatal care and other rehabilitation efforts
- Enhances the women's ability to prepare for the birth of the infant and begin homemaking
- Reduces obstetrical complications

Withdrawal from methadone maintenance is rarely appropriate during pregnancy. When attempted, methadone should be withdrawn slowly under close medical supervision and with careful fetal monitoring. It is generally accepted that if the patient insists that the dose should be lowered, this step should be taken during the middle trimester of pregnancy, not the first or third. Split dosing or raising doses in the last trimester of pregnancy (Pond et al. 1985) is recommended by some clinicians since plasma levels of methadone are decreased in the last trimester because of expansion of blood volume. In any case, all factors should be considered while making an individualized assessment. Neonatal abstinence syndrome may occur in a fetus exposed to methadone, and the baby will require careful monitoring after birth.

The use of medication to reduce craving for cocaine during pregnancy is not as well studied. It is generally recommended that pregnant women withdrawing from cocaine should not be medicated except in very specific instances and under certain conditions. Guidelines for treatment options for cocaine withdrawal during pregnancy have been developed by a Consensus Panel (CSAT 1993a).

Sensitivity to and elimination of the barriers women often encounter will help them to enter and continue treatment. Removing these barriers may mean addressing the needs of family members through family services, which may include the following:

- Women's groups to discuss the many issues confronting drug-dependent pregnant women
- Groups that focus on parenting and child-care issues
- A safe place for children to play while waiting for their parents or other child-care options should a mother seek treatment in an inpatient or residential setting
- Including children in group meetings when appropriate
- Couples/marital counseling
- Possible relocation to a safe place

All staff in methadone programs should be trained to meet the needs of pregnant women. It is equally important that public assistance workers be cross-trained about MTPs. In addition, pregnant women should be informed by MTP staff that some States regard drug use during pregnancy as child abuse and require the program to file a report with child welfare authorities. Some women are driven from treatment because of these laws. Others may be mandated to treatment by a child welfare agency in order to keep their babies who might otherwise be put in foster care. To keep families together, treatment programs must maintain honesty and credibility with such child welfare agencies.

Frequently Occurring Complications That Can Compromise Pregnancy in Drug-Dependent Women

Anemia, bacteremia, cardiac disease, cellulitis, central nervous system hemorrhage, depression and low self-esteem, poor dental hygiene, diabetes, edema, hepatitis, hypertension,, phlebitis,, septicemia, pneumonia, tachycardia, tetanus, tuberculosis, urinary tract infections, STDs

### Persons With HIV Infection

The most common behaviors associated with HIV exposure of methadone patients concurrently dependent on cocaine are sharing injection equipment and engaging in unprotected sex with partners at risk of HIV infection. Increasing HIV rates among injecting drug users are a significant problem for patients concurrently dependent on heroin and cocaine because injection is usually the primary route of administration. Treatment providers have noticed that these patients need intensive medical intervention and that other medical problems associated with injecting drug use, such as TB or hepatitis, are exacerbated by the HIV infection. In addressing HIV issues within this population, both prevention and intervention strategies should be employed.

An advantage of MTPs is that patients inject heroin less frequently or quit altogether, thereby decreasing their risk of HIV exposure through needle sharing. Yet methadone-maintained patients who inject cocaine and share injection equipment continue to be at risk of HIV infection. For this reason, all staff need extra training to work with cocaine-abusing HIV patients. In addition, during acute use of cocaine, cocaine's aphrodisiac qualities can lead to increased sexual drive, prolongation of the sexual interaction, and participation in multiple-partner sex marathons (Winick 1992). The risk of HIV exposure can remain very high if concurrently dependent persons are treated independently for opioids or cocaine without consideration of the risks associated with use of the other substance. An additional problem with some cocaine abusers is coexisting compulsive sexuality, which often remains undiagnosed and unaddressed. The combination increases the frequency of sexual behaviors that contribute to the spread of HIV (Washton 1989).

When working with methadone patients concurrently dependent on cocaine, medical staff should do the following:

- Consider HIV testing highly desirable, with pretest and posttest counseling conducted for each patient during the medical evaluation. More appropriate medical care and other supportive services can be offered if the patient's HIV status is known early in treatment.
- Perform periodic physical examinations on HIV-positive patients to observe potential symptomatology. Referral to more specialized HIV services is appropriate if basic medical care and monitoring are not available in the treatment program.
- Obtain baseline and followup T-lymphocyte (CD4 and CD8) counts. (Most programs do not have this capability except by referral.)
- Provide early medical intervention, including nutritional changes, supplemented with prophylactic medications such as aerosolized pentamidine.

Components of prevention strategies should include the following:

- Counseling and testing of persons already infected or at risk of HIV infection by using qualified staff. (Some States require staff certification.)
- Helping uninfected individuals initiate and sustain behavioral changes to reduce the risk of infection
- Assisting infected persons to take precautions to avoid infecting others
- Educating staff about HIV infection, including risk reduction and confidentiality issues, the implications of HIV testing and counseling, infection control guidelines, and universal precaution procedures
- Informing HIV-negative patients that STDs may increase the risk of HIV infection (because of open lesions and a compromised immune system, for example)

Pretest counseling sessions should include discussion of the following issues (Neshin 1993):

- Modes of viral transmission
- Prevention measures, with special attention given to evidence that having other STDs may increase the likelihood of contracting HIV infection during sexual activity
- The HIV antibody test and the meaning of both negative and positive results as well as the need for retesting to confirm a negative result after the 6-month latency period ("window")
- Advantages and disadvantages of testing
- The patient's expectations of test results
- The patient's existing support system (if the patient agrees to be tested)
- Confidentiality of the test results and the patient's reaction and coping skills if the result is positive

Patients with a positive result may exhibit a variety of reactions such as anxiety, shock, anger, sadness, guilt, denial, depression, and isolation (Sorenson and Batki 1992). After patients receive the results, posttest counseling should be offered, in which patients are allowed to absorb the information and vent their feelings. In the posttest counseling session, the clinician should do the following:

- Provide support for the patient
- Review information about preventing the transmission of the virus
- Remind HIV-positive patients that a positive HIV test result is not the same as having AIDS
- Encourage HIV-positive patients to notify sex and needle-sharing partners and offer assistance in making these contacts
- If necessary, refer HIV-positive patients to a mental health professional for assistance
- For HIV-negative patients, review prevention issues, including those relating to STDs
- Discuss the window period with HIV-negative patients, and encourage a retest within 6 months
- Consider framing treatment plans using the situational-distress model stages: crisis, denial, anger, acceptance, and death

Some programs have extended their services by networking with other organizations, for example, religious organizations, as noted earlier. Depending on religious persuasion or upbringing, it may be appropriate to refer HIV-positive patients to church-based programs whose counselors are trained to work with HIV/AIDS patients. Such programs may also include an emphasis on grief and bereavement counseling. Many churches that have traditionally administered to the disadvantaged and poor have broadened their programs to include the homeless, drug abusers, and those with HIV/AIDS (Muffler et al. 1992). HIV-positive and AIDS patients generally have far greater needs for social services than do "healthy" patients, and often substance abuse treatment programs have few resources to provide anything but minimal social services (Sorenson and Batki 1992). A religious organization can be an important source of support.

### Persons With TB

Given the increasing incidence of TB in the substance-abusing population, patients should be screened and examined for active symptoms of TB every 6 months (see appendix D for sample TB/PPD testing forms). Anergy panels should also be administered to diagnose anergic patients. Should a patient have TB or a positive TB test, medical staff should treat the patient for TB or refer the patient to a primary care clinic for medication. In either case, drug treatment staff can have an active role in monitoring medication compliance to help prevent the emergence of multidrug-resistant TB. If rifampin is used to treat TB in a methadone patient, care should be taken to adjust the patient's methadone dosage, as rifampin accelerates the clearance of drugs metabolized by the liver. The methadone dose may need to be increased, split, or both (Neshin 1993). Women patients who take INH and oral contraceptives should be advised that the INH may decrease the effectiveness of the oral contraceptives; these women should be advised to use barrier methods as well to prevent pregnancy. Special attention should be paid to hygiene and ventilation in drug treatment programs to protect staff, patients, and the general public.

### Adolescents and Young Adults

Special services for youth are rare in methadone maintenance since regulations for acceptance of patients under 18 are quite restrictive; the average methadone patient is in his or her midthirties. Alcohol, nicotine, and marijuana remain the first drugs of abuse in the teenage years, with some teens using cocaine early on. Opioid addiction often develops secondarily. Since cocaine use persists and often dominates methadone treatment, it is crucial to meet the special needs of this younger population. The few programs that have developed services for this group (e.g., The Adolescent Development Program in New York City) emphasize group work and peer pressure as well as social, educational, cultural, and recreational programs designed to meet the needs of youth, both to attract them into treatment and to retain them.