# Chapter 3-Screening, Admission, and Assessment Techniques

Screening, admission, and assessment can be viewed as stages in a 3-4-week process, during which increasingly detailed information is gradually gathered. For patients who do not meet Federal eligibility criteria for methadone services, staff should assess the need for acute services and promptly make appropriate referrals. Crisis situations call for a rapid assessment and appropriate response.

## Screening

The screening (or intake) process serves as the foundation for ongoing clinical intervention, and within this context, provides the following:

- Stabilization-immediate assistance with a crisis situation
- Eligibility-State criteria may be more restrictive than Federal criteria
- Treatment alliance-discussion of patient and program responsibilities
- Initial evaluation-formulation of the presenting problems, including prioritization
- Initial treatment plan

Patients typically present themselves for treatment because they are in trouble; assisting them with their crises is the best way to establish an initial treatment alliance. The applicant may feel "bottomed out." This feeling may be behaviorally expressed by passivity, suggestibility, uncertainty about the meaning of what has happened, and a degree of demoralization. The substance abuser may also be in a state of denial or ambivalence about the need for treatment (Senay 1992). Given these variables, information obtained during the initial screening process may be incomplete or unreliable.

The individual's first contact with a substance abuse treatment program begins the treatment alliance and the transition from addict to patient. In the initial contact with a potential new patient, the staff member conducting the process may be met by an aloof, hostile, demanding, or drug-influenced individual. The patient may be apprehensive, distrustful, and resistant, especially if he or she has entered the program through a mandatory referral such as the child welfare or criminal justice system.

Interviewing Techniques

The manner in which the patient experiences the screening process will likely influence his or her attitudes, concerns, and motivations throughout treatment (Langrod 1993). To facilitate a positive experience, the screening interviewer may do the following:

- Allow the patient a few minutes to give the history without intrusion.
- If the patient does not take the initiative, ask "What brings you to see me?" or "Tell me why you're here."
- Listen to the patient with the goal of learning how the patient defines the problem.
- After the patient has had some free time to speak, move to a more active, controlling mode of interviewing.
- Ask questions subtly, in a variety of ways and at different times. This method will be more likely to elicit accurate responses.
- Communicate with the individual in a supportive and nonjudgmental manner that conveys acceptance and a desire to help. Explain that all information acquired is held in confidence and that the applicant's privacy is protected by Federal law. This statement will help to relieve the applicant's apprehension and enhance rapport.

These individuals also may be in physical distress, for example, suffering from a cocaine crash or heroin withdrawal (Gold 1992). They may have HIV and/or AIDS, TB, STDs, or other infectious diseases.

Strategies for the Screening Process

When a patient presents for treatment at an MTP, the interviewer may use the following strategies:

- Immediately provide crisis intervention services to stabilize the patient.
- Make a preliminary determination of the patient's qualifications for treatment (see the section below).
- If the patient is qualified for the program and experiences uncomfortable withdrawal symptoms, quickly move the patient into the admission process and, if necessary, ensure that medication is prescribed.
- Begin helping the individual to identify the problem, and offer hope through recovery.
- Conduct the interview with the expectation that more information will be collected over time. Screening should be viewed as the first part of a process that occurs in stages.
- Use the first meeting with the patient as an opportunity to establish rapport.

### Need for Privacy

The program's physical surroundings should be attractive and welcoming and allow for privacy during the screening interview (Langrod 1993). Privacy is especially important because questions raised during the screening process (and later on during the admission and assessment processes) may evoke feelings of shame or guilt, cause fears of possible legal consequences, or cause other emotions best managed by both the patient and the interviewer in a private setting (Senay 1992).

### Determining Patient Eligibility for Treatment

Drug users who are primarily regular users of cocaine and not physiologically dependent on opioids are generally neither therapeutically nor legally appropriate for admission to MTPs. (Exceptions are individuals physically addicted to opioids but not currently using due to enforced abstinence, for example, because of incarceration.) They should be referred to treatment centers that treat primary cocaine problems. Patient eligibility for a methadone treatment program must comply with Federal and State requirements (21 CFR, § 291.505). (Please refer to the State Methadone Treatment Guidelines [CSAT 1993b] for Federal and State requirements not discussed in the following pages.)

It is important to remember that Federal regula- tions on eligibility represent the minimum criteria for admission. Many States develop and implement criteria more stringent than those required by the Federal Government. Providers need to be aware of their respective States' regulations.

Initial Data Collection

In determining eligibility, the screening process for concurrent addiction to opioids and cocaine should elicit the following data:

- Applicant identification (e.g., driver's license, passport, birth certificate, Social Security card, Medicaid card)
- Personal and demographic informa- tion on employment, education, legal involvement, military background, family history, financial status, psychiatric treatment, and medical background, including current prescribed and over-the- counter medications
- Likelihood of incarceration in the near future, especially since many correctional facilities rapidly taper or abruptly stop methadone maintenance treatment
- A preliminary determination of the applicant's current degree of dependence on all drugs, including route(s) of administration, information on all other substances used, length of time used, and frequency and amount of use
- A determination of the applicant's mental status, including psychosis or the potential risk of violence or suicide (see page 16 for risk factors for violence and suicide)
- The degree to which the applicant engages in high-risk HIV-related behavior (applicant should be asked if he or she has been tested for HIV)
- History of past substance abuse and any concomitant treatment, including dates of treatment, use of secondary substances while in treatment, and reasons for discharge
- The precipitating factor for seeking the current treatment and whether treatment options and requirements for the chosen program are understood
- Drug screening results, using a urine sample (21 CFR, § 291.505 (d)(2)) and an alcohol breathalyzer test

Federal Regulations on Eligibility

- A person may be admitted as a patient for a maintenance program only if a program physician determines that the person is currently physiologically dependent upon a narcotic drug and became physiologically dependent at least 1 year before admission for maintenance treatment.
- A 1-year history of addiction means that an applicant for admission to a maintenance program was physiologically addicted to a narcotic at a time at least 1 year before admission to a program and was addicted, continuously or episodically, for most of the year immediately before admission to a program.
- The person responsible for the program shall ensure that: A patient voluntarily chooses to participate in a program; all relevant facts concerning the use of the narcotic drug used by the program are clearly and adequately explained to the patient; and all patients, with full knowledge and understanding of its contents, sign the "Consent to Methadone Treatment" Form FDA-2635.
- A person under 18 years of age is required to have had two documented attempts at short-term detoxification or drug-free treatment to be eligible for maintenance treatment. No person under 18 years of age may be admitted to a maintenance treatment program unless a parent, legal guardian, or responsible adult designated by the State authority completes and signs consent form, Form FDA-2635 "Consent to Methadone Treatment."

Exceptions to Minimum Admissions Criteria

- A person who has resided in a penal or chronic care institution for 1 month or longer may be admitted to maintenance treatment within 14 days before release or discharge, or within 6 months after release from such an institution without documented evidence to support findings of physiological dependence, provided the person would have been eligible for admission before he or she was incarcerated or institutionalized and, in the reasonable clinical judgement of a program physician, treatment is medically justified.
- Under certain circumstances, a patient who has been treated and later voluntarily detoxified from maintenance treatment may be readmitted to maintenance treatment, without evidence to support findings of current physiologic dependence, up to 2 years after discharge, if the program attended is able to document prior narcotic drug maintenance of 6 months or more, and the admitting program physician, in his or her reasonable clinical judgement, finds readmission to maintenance to be medically justified.
- If in the responsible clinical judgement of the medical director a particular patient would not benefit from treatment with a narcotic drug, the patient may be refused such treatment even if the patient meets the admission standards.

Exceptions to Minimum Admissions Criteria for Pregnant Patients

- Pregnant patients, regardless of age, who have had a documented narcotic dependency in the past and who may return to narcotic dependency, with all its attendant dangers during pregnancy, may be placed on a maintenance regimen. For such patients, evidence of current physiological dependence on narcotic drugs is not needed if a program physician certifies the pregnancy and, in his or her reasonable clinical judgement, finds treatment to be medically justified.
- Pregnant patients are required to be given the opportunity for prenatal care either by the program or by referral to appropriate health care providers. If a program cannot provide direct prenatal care for pregnant patients in treatment, the program shall establish a system for informing the patients of the publicly or privately funded prenatal care opportunities available. If there are no publicly funded prenatal referral opportunities and the program cannot provide such services or the patient cannot afford them or refuses them, then the treatment program shall, at a minimum, offer her basic prenatal instruction on maternal, physical, and dietary care as part of its counseling service.
- Within 3 months after termination of pregnancy, the program shall enter an evaluation of the patient's treatment state into her record and state whether she should remain in the maintenance program or be detoxified.
- The program sponsor shall ensure that each female patient is fully informed of the possible risks to her or her unborn child from continued use of illicit drugs and from the use of or withdrawal from a narcotic drug administered or dispensed by the program in maintenance or detoxification treatment.

### Preliminary Assessment and Treatment Plan

If treatment staff have collected screening data and determined that an applicant is eligible for treatment, they should make an initial assessment and recommend the applicant for admission. (If the applicant is not eligible, staff should provide a referral to a more appropriate program.) If the applicant accepts admission, an initial assessment and preliminary treatment plan should be developed. The plan should briefly state the patient's primary problem, the immediate goal, and the action plan to begin treatment services.

## Admission

The admission process includes a medical evaluation. Because MTPs are an important provider of initial medical services to heroin addicts, Kosten and coworkers (1987b) suggest that careful medical evaluations on admission are necessary and that the development of primary medical care facilities within or closely associated with drug treatment programs is justified. A substance abuse history should also be completed during the admission process.

A medical evaluation is especially important for narcotic addicts and multidrug users since these patients may have many medical problems. While a medical history may be completed by any staff person trained in the medical aspects of addiction, a physician must decide whether to admit a patient to a narcotic treatment program, and only a physician can order medications.

### Medical History

A complete medical history typically examines current information to determine whether the patient has any chronic or acute medical conditions such as diabetes, renal diseases, hepatitis, HIV, TB, STDs and other infectious diseases, sickle-cell trait or anemia, chronic cardiopulmonary disease, or pregnancy. The history should document any treatments that the patient has had or is currently receiving for any medical condition, including any medications the patient may currently be taking. For women, the history should include documentation of any previous pregnancies, types of delivery, pregnancy complications, and current involvement with prenatal care. The history should document alcohol and drug use during and prior to any pregnancies and any incidence of sudden infant death syndrome (SIDS). A family health history should be obtained.

Elements of the Medical Evaluation

The medical evaluation should include the following:

- A complete medical history
- A complete physical exam
- A brief psychiatric evaluation, with attention to suicide risk, violence risk, and psychosis
- Laboratory tests as appropriate or required
  - HIV testing^1^
  - Liver function tests
  - TB testing^2^
  - Syphilis tests^1,2^
  - Tests for other STDs, such as chlamydia
  - Pregnancy test
- A determination of current substance dependence
  - Objective signs of withdrawal on examination
  - Breathalyzer
  - Physical examination
  - Narcan challenge (if indicated)
  - Prior treatment history
- A history of HIV testing and risk assessment
- Collection of information on current medications the patient is taking
- A determination of treatment eligibility and treatment options

- HIV testing^1^
- Liver function tests
- TB testing^2^
- Syphilis tests^1,2^
- Tests for other STDs, such as chlamydia
- Pregnancy test

- Objective signs of withdrawal on examination
- Breathalyzer
- Physical examination
- Narcan challenge (if indicated)
- Prior treatment history

^1^False positives are not uncommon. Confirmatory tests may be required.

^2^Required by Federal regulations

### Physical Examination

A complete physical examination conducted by medical staff ordinarily includes examination of all major systems. As required by Federal regulation (21 CFR, § 291.505 (d)(3)(i)), narcotic treatment programs must document physical examination of organ systems for possibilities of infectious disease; pulmonary, liver, and cardiac abnormalities; dermatologic sequelae of addiction; vital signs; general appearance-head, ears, nose, throat, chest, abdomen, extremities, and skin; evidence of physical drug dependence; and the physician's clinical judgment of physical dependence. Patients should be examined for symptoms of active TB, including cough, fever, night sweats, weight loss, and fatigue.

### Psychiatric Evaluation

The physical examination can be useful in understanding psychiatric symptomatology (e.g., psychiatric symptomatology related to a diagnosis of AIDS). An initial psychiatric evaluation should be completed, beginning with a determination of the potential risk of suicide or violence or the presence of psychosis. A full evaluation should then proceed only after acute withdrawal and lingering withdrawal effects have passed (Dackis and Gold 1992). Another evaluation should occur 6 months later. When applicable, patients should be told that their mental state may be the result of cocaine or other drug use.

Staff should also assess risk factors for women who may be subject to past or current physical or emotional abuse.

### Laboratory Tests

Federal regulation requires narcotic treatment programs to conduct a drug screening test or analysis, a serological test for syphilis, and a tuberculin skin test (21 CFR, § 291.505 (d)(3)(i)). Given the fact that some drugs are extensively metabolized and quickly excreted from the body, it is important to use analytic procedures that give the highest level of specificity when screening for the presence of drugs. For patients concurrently dependent on opioids and cocaine, enzyme immunoassay or radioimmunoassay urine screening techniques have been found to be effective because they have high sensitivity levels (Verebey 1992). Detecting cocaine can be particularly difficult because the half-life of cocaine is only about 1 hour, and unchanged cocaine is detectable in urine for only 12-18 hours after use. Screening for cocaine is therefore most effective when conducted within hours of use or if the patient is suspected to be under the influence of cocaine at the time of the sample collection. Given cocaine's short half-life, medical staff should routinely test for the presence of benzoylecgonine, a metabolite of cocaine that may be detected in the urine for at least 24-48 hours after the last use. Since cocaine use can go undetected on admission, patients should be screened frequently during the assessment process.

### TB Testing

The Centers for Disease Control and Prevention recommends the use of the Mantoux TB test on admission and annually thereafter unless the patient is known to be purified protein derivative (PPD) positive (10-millimeter induration or more for HIV-negative persons and 5-millimeter induration for HIV-positive persons or those at risk of HIV infection). Some HIV-positive patients may have a false negative reading on a PPD test because immunocompromised persons are frequently anergic. For such cases, anergy testing can be used to screen out false negative PPD tests. All patients with a positive PPD test should receive a chest x-ray. Care should be taken to assist patients placed on isoniazid (INH) prophylaxis, in complying with daily doses. (See appendix D for a sample TB/PPD testing form and supplementary questions.)

Risk Factors for Violence

SOURCES: Levy 1988; Marzuk and Mann 1988

- Stimulant or alcohol intoxication
- Psychotic states, such as paranoia (drug induced or otherwise)
- Previous history of violent behaviors
- Availability of weapons
- History of childhood abuse

- Ensure availability of backup help for management of those who are aggressive or psychotic
- Remove objects that could be used as weapons, including items of clothing
- Ensure that the door is readily accessible to both client and interviewer; however, the client should not be allowed to get between the interviewer and the door
- Stay calm
- Face the client while maintaining a discreet distance
- Discreetly ensure that the client does not have a weapon

- Determine who can hospitalize patients
- Have available phone numbers of special crisis units or services (other than 911)
- Know the criteria for hospitalization
- Know the rules concerning the duty to warn

Risk Factors for Suicide

- Age: 20--30
- Sex: Male
- Concurrent alcohol abuse and use of multiple substances, especially opioids, cocaine, amphetamine, sedatives
- Chronic use, including history of drug overdoses
- Stimulant withdrawal
- Comorbid psychiatric symptoms, especially depression, borderline personality disorder, psychoses; exhaustion
- Recent (within 6 weeks) significant loss
- Childhood history of hyperactivity, incorrigibility, family financial difficulties, family suicidal behaviors, abuse, living in foster homes
- Family history of depression, suicide, alcoholism
- Severe chronic pain (possibly)

- Suicidal thoughts or behaviors
- Availability of a means: drugs, weapons
- Risk-taking behaviors
- Accidents
- Legal difficulties
- Escalating patterns of substance abuse
- Recent losses
- Previous suicide attempts
- Comorbid syndromes, such as depression, psychosis, anxiety states, personality disorders
- Family history

### Hepatitis Testing

Hepatitis is one of many possible medical complications that can result from injecting heroin or cocaine. Many injecting drug users can have acute hepatitis infection without serologic evidence of hepatitis A or B. Recent data demonstrate that rates of hepatitis C are high among injecting drug users. Hepatitis C is described as having a chronic indolent course (Donahue et al. 1991). A simple blood test for antibodies against hepatitis C is now available. However, a positive result does not indicate that the patient is currently infected with the virus. It shows only that antibodies have been developed as a result of previous or current exposure. Interferon is being investigated as a promising treatment for hepatitis C, but it can have significant side effects and is very expensive.

### HIV Testing

Because of the high rate of HIV risk behaviors associated with opioid addiction, it is especially important for the physician to talk with applicants about safer sex and needle use practices. Given the increasing impact of AIDS on narcotic-dependent patients, medical staff should carefully consider counseling and testing patients for HIV. It is recommended that the physician discuss medical aspects of HIV infections and ask the patient the following questions:

1. Are you aware of your HIV status?
2. If yes, are you willing to share this information with us?
3. If yes, when were you tested?
4. Would you like to be tested or to have another test?

In addition, the physician should ask the patient for a complete history of any HIV testing that has been performed.

All staff providing HIV testing and counseling services should be educated about HIV/AIDS and able to provide pretest and posttest counseling (see chapter 4) and perform a risk assessment of the patients who enter the treatment center.

### Determining Current Dependence

A patient's current dependence on opioids or stimulants or both can be determined by medical staff through a history, an examination, and urine screening. The history should determine the length of time the patient has been dependent on narcotics or stimulants. A sample form for taking this history is shown in figure 1. The physical examination should include examination for the presence of clinical signs of addiction such as needle marks, constricted or dilated pupils, and a state of sedation. Medical staff should check for reported and observable withdrawal symptoms such as yawning, rhinorrhea, lacrimation, chills, restlessness, irritability, perspiration, piloerection, nausea, and diarrhea.

Figure 1: Sample Substance Use History Form

CLINICAL RECORD | | | | Admission Assessment
SUBSTANCE USE HISTORY
Drug | Current use (x) | Current rank | Past use only (_) | Year of 1st use | Date of last use | Typical pattern of use, including amount of daily use | Mode
Alcohol
Cocaine
Heroin
Methadone
Other opioids
Methamphetamine
Other amphetamine
Benzodiazepines
Barbiturates or other sedatives
Cannabis
LSD
Other psychedelics
PCP
Other (specify)
Cigarettes | | - - -
Other nicotine | | - - -
Caffeine | | - - -
Additional comments on history and pattern of use of primary substances: (use reverse side of page if more space is required)
Patient Identification
Clinician:
Date:

If the physician is not certain of the applicant's medical eligibility for admission to an MTP (that is, whether the patient is physiologically dependent on opioids), it is sometimes appropriate to implement a Narcan challenge. This test induces symptoms of withdrawal and is often controversial. To give a Narcan challenge, the following criteria should be met:

- No medical contraindications (for example, pregnancy, hypertension, acute opioid withdrawal)
- No history of methadone treatment
- No previous opioid detoxification with documented withdrawal

Narcan may be administered using the following method (Ling and Wesson 1990):

- Place 0.8 mg of naloxone (Narcan) in a syringe, and administer 0.2 mg intravenously or intramuscularly.
- Observe the patient for 30 seconds for signs of withdrawal.
- If you do not observe signs of withdrawal, administer the remaining 0.6 mg of naloxone and observe the patient for 20 minutes.
- During the 20-minute observation period, serially record vital signs and symptoms and signs of withdrawal.
- It may be helpful to develop a worksheet for recording these observations and quantifying the results.
- If a patient shows even minor symptoms of withdrawal, he or she has some degree of opioid tolerance.

Determining current dependence on cocaine can be more difficult because clearly defined withdrawal symptoms may not be present. In fact, the presence of a cocaine abstinence syndrome has been debated. Gawin and Kleber (1986) described a three-phase process in outpatients lasting 1-10 weeks. The phases include "crash," withdrawal, and extinction. During phase 1, the patient experiences exhaustion, intense depression, agitation, anxiety, hypersomnolence, hyperphagia, and craving for cocaine. In phase 2, the patient has no craving, but the craving may reemerge, bringing on symptoms of anhedonia, anergia, and anxiety. During phase 3, which can last indefinitely, the patient's mood returns to normal but the patient experiences recurrent craving, typically in response to cues.

Inpatient studies have not found such clearly defined phases of withdrawal. Instead, symptoms were found to be very acute in the first 24 hours and associated with intense depression. Mood state, cravings, and sleep problems gradually returned to normal in approximately 4 weeks (Weddington 1991). The difference between these findings may relate to the effects of cocaine availability on craving, such availability and cues being much greater for outpatients.

### Treatment Eligibility and Treatment Options

The admitting physician is responsible for recommending the treatment disposition and determining admission. The physician should make a clinical judgment about the appropriate level of care on the basis of the patient's individual needs. For narcotic treatment services, the physician must document current dependence on opioids and a 1-year history of physiological dependence prior to admission (21 CFR, § 291.505 (d)(1)(i)(A)).

Langrod (1993) recommends that medical staff fully explain available treatment options to the patient, including alternatives for less intensive and restrictive treatment, the chances for success or failure, the benefits and the risks of treatment, and the treatment process. Such an explanation should be based on the results of the medical evaluation, and medical staff should ensure that the best possible treatment option is being recommended. The physician is also responsible for explaining the pharmacological properties of any medication to be used for treatment or maintenance.

The Consensus Panel recognizes that some communities may not have extensive resources. However, if there are no facilities elsewhere in the community, the MTP itself should consider developing programs to meet the needs of patients who need alternative treatment. Program administrators should consult with appropriate State regulatory agencies, financing agencies, and community groups before opening a new service.

## Assessment

The assessment process may be conceptualized as taking place in three stages. First, the initial screening provides an opportunity to establish eligibility and, perhaps more importantly, to assist the applicant with concomitant psychosocial crises. This kind of help facilitates a working alliance. Second, indepth evaluation is based on subsequent interviews once the patient has entered treatment. More detailed information is collected over a 3-4-week period. This information permits clinicians to formulate a comprehensive treatment plan. Third, an ongoing evaluation process measures patient progress, updates the treatment plan, and signals the need for relapse prevention.

### Initial Screening and Crisis Intervention

Although initial screening interviews are often devoted to collecting eligibility data for methadone treatment, it is important not to overlook this initial contact as an opportunity to negotiate and establish an effective treatment alliance. Actively assisting the patient with the psychosocial crisis at hand makes the treatment system appear more helpful and less bureaucratic. Many patients who do not qualify for methadone maintenance nonetheless have life crises that require prompt assistance.

### Indepth Evaluation

A conscientious and individualized assessment guides treatment planning decisions toward effectively matching the patient to the most appropriate treatment interventions (Wallace 1992). The assessment process should go over details not covered in the initial screening interview. Many treatment centers are increasingly turning to the use of standardized diagnostic assessment instruments such as the Addiction Severity Index (ASI). Such instruments can be used periodically throughout treatment to measure patient progress and to assist in matching specific treatment interventions to specific kinds of problems.

Indepth interviews elicit greater detail about salient patient characteristics revealed during the initial interview and are fundamental in developing a comprehensive treatment plan. This workup commonly includes a detailed substance abuse history, a detailed psychosocial history, and a thorough psychiatric history. The patient also should be asked if he or she has been tested for HIV. Additional elements to be included may depend on the patient's background (e.g., education, employment, legal involvement, general health) and the particular treatment modality and target population.

In assessing the level of a patient's concurrent dependence on opioids and cocaine, it is important to conduct frequent urine screens for cocaine. Cocaine and cocaine metabolites are cleared from the bloodstream more rapidly than most opioids. Resources permitting, urine screens should occur two times per week. A functional analysis of cocaine use should be done to identify the circumstances of use (where, when, with whom, and relapse triggers). It is important to involve family members and other significant relations of the patient in the evaluation to help diminish defensive behaviors such as denial, isolation, and compartmentalization (Beeder and Millman 1992). The clinician should also determine whether the patient's family and friends also use drugs.

All seven domains of the problem areas identified by the ASI (described in the section on diagnostic assessment instruments later in this chapter) should be addressed:

- Medical status-Questions should relate to hospitalizations, chronic medical problems, prescribed medications, frequency and severity of recent medical problems, pension status (for physical disability), and the patient's view of the desirability of treatment.
- Employment and support status-Questions should explore the extent and type of education; automobile use; employment history, patterns, and salary; financial support and responsibilities; and employment problems and the patient's attitude toward those problems.
- Alcohol and drug use (two domains)- Questions should be asked about major substances used; frequency, duration, and last use of substances; detoxification or treatment experience; abstinence periods; and the patient's attitude toward the severity of the problem.
- Legal status-Questions should relate to type of admission (e.g., through the criminal justice system); criminal arrests, charges, and convictions; types of crime(s) involved; probation or parole status; incarcerations; illegal activities in the past 30 days; and the patient's view of the severity of his or her legal problems.
- Family and social relationships-Questions should be asked about marital status; living arrangements; use of leisure time (with friends and family); patient satisfaction with marital and living status; problems with family members, friends, significant others, neighbors and coworkers; and the patient's view of the severity of these problems.
- Psychiatric status-Questions should be asked about the presence of specific mental states; hospitalizations; pension status (for psychiatric disability); recent psychological or emotional problems; and the patient's view of the severity of any psychiatric problems and the need for treatment.

Since opioid abusers are at risk for abusing cocaine and cocaine abusers are at high risk for abusing opioids, the temporal relationship of the other drug use (whether heroin or cocaine is the primary drug of choice) should be identified (Barthwell and Gastfriend 1993). Primary cocaine addicts will tend to use cocaine first and then heroin to relieve the adverse agitation or "crash" effects. Primary heroin addicts tend not to use cocaine prior to a heroin fix because the cocaine agitation may be confused with opioid withdrawal.

In complex cases with psychiatric disorders, it is important to try to assess whether substance abuse preceded or followed psychiatric symptoms, although this distinction is admittedly difficult to make in many cases. Substance abuse may mimic psychiatric disorders and in some cases provoke them. Depression, for example, is a very common outcome of alcoholism, sedative abuse, and stimulant abuse. Paranoia may be provoked by the use of amphetamine or cocaine.

Conversely, patients with distressing psychiatric symptoms often seek to self-medicate. This experience appears to be especially true for individuals with attention deficit disorder or manic symptoms. Depressed individuals often seek out a variety of drugs, which they hope will ameliorate their dysphoria. The following section gives an overview of pertinent elements to include in the substance abuse history, psychiatric examination, and psychosocial history to ensure that the indepth interviews and assessments are comprehensive.

#### Substance Abuse History

The substance abuse history should include information about the following areas:

- Precipitating events leading to treatment
- Prior treatment (dates, modalities, outcomes)
- Onset of drug use, frequency of drug use, and duration and pattern of use (occasional versus regular). Include the period of heaviest use and the pattern of use within the past 3 weeks.
- Periods of abstinence (number, duration, and circumstances)
- Circumstances or events leading to relapse
- Desired psychoactive effects; subjective and objective effects on the patient's physical, psychological, and emotional states; symptomatology of use of the drug for the patient (see appendix E for multidrug abuse patterns and their desired effects)
- Assessment of the changing pattern of the patient's substance abuse, withdrawal symptomatology, and medical sequelae
- List of all psychoactive drug(s) used and determination of age of onset, pattern of use, and current status
- Extent of social deterioration or isolation to assist in comprehending the interpersonal losses and the legal, educational, medical, and employment consequences the patient is facing (Beeder and Millman 1992)

If the patient's use of various drugs from major drug classes has not been addressed during the screening process, this topic should be reviewed while taking the history. The commonly recognized major drug categories include alcohol and other depressants, cannabis, opioids, stimulants, hallucinogens, phencyclidine (PCP), inhalants, nicotine, caffeine, and certain over-the-counter drugs with sedative effects. This core set may need to be supplemented by local fad drugs. The period of heaviest lifetime use may provide clues to the patient's motivation for use (Senay 1992).

In the case of opioids and cocaine, it is important to learn the patient's drug use pattern during the past month because, without recent drug use, the possibility of physical drug withdrawal is unlikely. While not lethal, withdrawal from opioids and cocaine may be marked by depression or anxiety.

#### Psychosocial History

The psychosocial history should describe the relevant dynamics of the patient's functioning prior to the onset of illness (e.g., depression or anxiety). Make a point of identifying and supporting the patient's specific strengths (a good job, strong family ties, sensitivity, etc.) to provide the basis for a focused, individualized, and effective treatment plan. Information gained from the psychosocial history is important because addiction-related problems may be uncovered in psychosocial areas. The following elements may be explored to obtain a psychosocial history:

- Patient's family and other relationships
- Living arrangements (past and present)
- Sexual orientation
- Sexual history
- History of abuse (physical, emotional, and sexual)
- Patient's ability to manage money
- Recreational and leisure time activities
- Patient's assets and liabilities

#### Psychiatric Examination

The purpose of the psychiatric examination is to look for threshold criteria of disorders requiring emergency intervention or referral to a specialist. This evaluation should occur in three stages analogous to the previously described stages of substance abuse assessment:

- Immediate assessment of psychiatric status (suicidal or homicidal ideation, psychotic behavior, mental disorganization, depression)-This assessment requires some familiarity with the components of a mental status examination (general appearance, behavior, and speech; stream of thought, thought content, and mental capacity; mood and affect; and judgment and insight).
- Indepth diagnostic evaluation 4 or more weeks later, after the patient has stabilized-Behavior of patients under the influence of drugs often mimics symptoms of psychiatric disorders such as depression, anxiety, paranoia, and mania (as does that of patients in withdrawal from drugs).
- Ongoing psychiatric assessment-The most common psychiatric disorders in this treatment population are depression, anxiety, and antisocial behavior; the latter is especially difficult to disentangle from the antisocial activities inherent in the use of illicit drugs.

During the psychiatric examination, the following points are important to consider: (1) The psychiatric disorder may be a consequence of the addiction, (2) substances may be used for self-medication of underlying psychiatric symptoms, and (3) addiction and psychiatric illness may develop independently and later impact on each other (Meyer 1986; Senay 1992). The prognosis, course of treatment, and clinical approach will differ depending on which of these categories the patient falls into (Dackis and Gold 1992). The patient's presenting complaints should guide the order of the interviewer's questions about drug abuse symptoms versus DSM-IV disorders. What is essential, however, is that both spheres are equally and adequately explored (Senay 1992).

Indicators of psychopathology can also be sought in the specific pattern of reported drug use, choice of drug(s), and positive and negative effects of the drug(s) on the patient. For instance, a borderline patient may describe drug taking as a disorganized, chaotic pattern while an obsessive-compulsive patient may take the drug(s) of choice in a carefully prescribed pattern (Beeder and Millman 1992). Psychiatric symptoms may be the result of agonist effects of drugs and, therefore, may not be a true psychiatric comorbidity. However, psychiatric symptoms occurring following at least a 2-3-week period of abstinence are reliable indicators of psychiatric comorbidity (Beeder and Millman 1992; Dackis and Gold 1992).

While antisocial personality disorder is often present among substance abusers, the diagnosis should be made with caution. Care should be taken that antisocial personality disorder, which requires a history of problems before the age of 15, is not confused with adult antisocial behavior, a disorder that frequently develops as a result of substance abuse (American Psychiatric Association 1987).

Substance abusers often have great difficulty identifying and naming feelings. This inability to identify feelings (alexithymia) can make the assessment of anxiety, depression, and sadness more difficult (Dackis and Gold 1992). Krystal and Raskin (1970) have described these patients as "concrete" and "flat." They may appear depressed or unimaginative. They may be subject to internal experiences that are primitive, poorly differentiated, and difficult to articulate. It is important to learn whether these dysphoric experiences lead to relapse. If so, relapse prevention work may include helping these patients to identify, differentiate, and verbalize poorly understood feelings.

Baseline sexual behavior, with an emphasis on changes secondary to cocaine use, should be explored. To elicit a patient's sexual history, the AIDS Initial Assessment Questionnaire (AIA) can be consulted to help formulate questions that should be asked. Typical questions suggested by the AIA include the following:

- How many people have you had sex with in the past 6 months?
- Is your sex partner male? Female?
- Has he or she injected drugs in the past 6 months?
- When you had sex with your partner in the past 6 months, how often did you use a condom (latex protection)?
- If you did not use a condom (latex protection), is it because you feel you cannot give AIDS to your partner? Get AIDS from your partner? Is it because your partner may feel you are accusing him or her of having AIDS?
- If you did not use a condom (latex protection) in the past 6 months, is it because your partner does not like it? Is it because you are afraid of getting hurt or beat up by your partner? Is it because you or your partner wants to have a child?

The AIA questionnaire also includes questions for patients with multiple sex partners and questions about specific acts that may occur in male-female, male-male, and female-female relationships.

### Diagnostic Assessment Instruments

In addition to the psychiatric examination, diagnostic assessment instruments can be useful in gathering data (Beeder and Millman 1992). Although questionnaires and diagnostic instruments are not essential for an accurate diagnosis and effective treatment planning, some clinicians use such tools to supplement interview information. Instruments used alone are detrimental because some instruments assess for only one drug class and may miss local fads, and the patient may not experience the interviewer as interested and responsive to his or her needs (Senay 1992). The following is a brief description of some of the more widely recognized and used instruments. (Refer to appendix F for information on ordering these instruments.)

### Comprehensive Assessment Tools

#### Addiction Severity Index (ASI)

The ASI is a research instrument widely used to evaluate the overall severity of a patient's addiction disorder and the extent to which patients exhibit significant change over time. It is designed to evaluate seven key areas of problem severity. These domains are rated on 9-point scales, with the higher numbers signifying greater severity. The ASI is highly regarded and extremely well established as the most important addiction assessment available. It must be administered to the patient by a trained staff person and takes approximately 45 minutes.

#### Structured Clinical Interview (SCID)

This clinical interview is used to assess psychiatric and substance abuse-related disorders. It guides an experienced mental health clinician through all of the major mood, anxiety, psychotic, and substance use disorders. An advantage of SCID is that the interview is modular. It can be shortened by focusing only on the diagnoses of interest. The interview provides very reliable DSM-IV-R diagnoses, which, along with Research Diagnostic Criteria (RDC), can be considered the "gold standard" for psychiatric diagnosis. The SCID takes an hour or more to administer and requires a highly skilled interviewer with prior mental health specialty training. It is primarily for use in clinical research settings that have sufficient resources to support indepth testing.

#### Diagnostic Interview Schedule (DIS)

The DIS is a structured interview that has been used in numerous clinical and research settings to support DSM-III-R diagnoses and is also available for DSM-IV. It must be administered by a trained interviewer and takes a minimum of 45-60 minutes to administer. The DIS is helpful in documenting psychiatric diagnostic information. It is not specifically geared to drug- or alcohol-dependent patients, and it is not a measure of change to be used in preoutcome or postoutcome studies.

### Brief Assessment Tools

#### Beck Depression Inventory (BDI)

The BDI is a well-established, brief questionnaire easily used to assess symptoms of depression. The BDI is self-administered and easily scored, and the results are widely recognized. In the field of addiction treatment, the BDI can be used to measure one dimension of patient functioning-the level of depressive symptoms. However, the BDI is not a comprehensive or multidimensional instrument since it does not measure attributes other than depression. Like other self-rating depression instruments (the Zung Depression Scale and the Hamilton Depression Scale), the Beck overrates the true incidence of DSM-III depression, but it is a good screening tool to use prior to administering more complex depression assessments. It is also useful for monitoring the progress of the patient in treatment.

#### Michigan Alcoholism Screening Test (MAST)

MAST is a brief, self-administered questionnaire that assesses the extent of a person's problem with alcohol. Although MAST has been widely used as a screening instrument, some question its accuracy as a measure of change over time. Therefore, it may be useful to gain a quick assessment of alcohol-related problems, but not as a treatment outcome instrument. Another limitation is that the instrument assesses problems related only to alcohol use and not to all substances of abuse.

#### Drug Addiction Severity Test (DAST)

DAST is an instrument parallel to MAST; it is used to assess the level of drug-related problems and is used less widely than MAST. DAST's use is limited to screening programs, and it is not used to measure change over time.

#### CAGE (Cut Down, Annoyed, Guilty, Eye-Opener)

CAGE is a quick indicator of alcohol-related problems and can be self-administered. It may be useful as part of the routine medical screening process. It asks the following four questions (Ewing 1984):

- Have you ever felt the need to cut down on your drinking?
- Have you ever been annoyed by criticism of your drinking?
- Have you ever felt guilty about your drinking?
- Have you ever felt the need for an eye-opener in the morning?

These questions are not intended for use in measuring changes in behavior and do not provide any information regarding drug use.

### Ongoing Assessment

While assessment serves as a beginning phase of treatment, it also must be an ongoing process used to measure patient progress, update the treatment plan, and aid in relapse prevention. In this sense, assessment is a dynamic process that creates a feedback loop from treatment intervention and disposition of patient progress to continued treatment planning. The frequency of ongoing assessments will vary from case to case. Patients at risk for suicide, for example, should be assessed more often than those concentrating on long-term goals.

Ongoing assessment can be accomplished by using the instruments described above, consulting with patients to review progress as measured by treatment plan goals, and doing followup studies of patients that measure abstinence at different intervals of treatment (e.g., 6 months or 1 year or both). Of particular importance in the ongoing assessment of MTPs is the evidence that many methadone-maintained patients initiate, continue, or increase cocaine use after the onset of treatment to experience the euphoric state no longer attainable with heroin (Condelli et al. 1991; Dunteman et al. 1992). Ongoing assessment also serves as a relapse prevention strategy by identifying early warning signs of relapse (see the Relapse Prevention section of chapter 4).

## Diagnosis and Confirmatory Procedures

Assessment allows the clinician to form an accurate diagnosis and build an appropriate and realistic treatment plan. Two diagnostic classification systems are currently in use: The Diagnostic and Statistical Manual of Mental Disorders (DSM-IV) and the International Classification of Disease, 10th revision (ICD-10), soon to be used by the World Health Organization. Although the two systems are organized differently, they are conceptually similar (Woody and Cacciola 1992). However, the DSM-IV classification system is more widely used in substance abuse treatment programs.

Disorders related to psychoactive substance use, most commonly dependence and abuse, are covered in the Substance-Related Disorders section of the DSM-IV. In DSM-IV, Axis I disorders such as depression, when accompanied by psychoactive substance use within 30 days, may be categorized as secondary or due to psychoactive substance use. A total of 11 categories of abuse and dependence are specified: alcohol; amphetamines or similarly acting sympathomimetics; caffeine; cannabis; cocaine; hallucinogens; inhalants; nicotine; opioids; PCP; and sedatives, hypnotics, or anxiolytics. Other DSM-IV categories include polysubstance dependence (meeting criteria for at least three categories of dependence as a group), psychoactive substance dependence not otherwise specified, and psychoactive substance abuse not otherwise specified (see appendix G, DSM-IV Diagnostic Criteria for Substance Abuse).

## Preparing the Treatment Plan

After completing a thorough assessment and preliminary diagnosis of the patient, a treatment plan specific to the patient's identified needs should be prepared. A formalized treatment plan is required by Federal methadone regulations (21 CFR, § 291.505 (d)(3)(iv)), the Joint Commission on the Accreditation of Healthcare Organizations (JCAHO), and the Commission on Accreditation of Rehabilitation Facilities (CARF).

Formulation of a comprehensive, individualized, attainable treatment plan is based on patient strengths and the application of an appropriate mix of available programs or external resources. Often this plan concretely addresses the steps an individual must take to attain each goal. A quality treatment plan addressing short- and long-range goals is developed within a 90-day period through a series of progressive action plans. It is a much expanded version of the initial treatment plan identified earlier in this chapter. This plan is critical for ensuring that treatment is delivered in an organized fashion, and it serves as a continuous reference point for the clinician. The patient should participate in preparing the treatment plan and should sign and receive a copy so that patient and program work toward the same goals.

The case study in the following section introduces an example of an appropriate treatment plan and what it might entail.

M.J. is a 30-year-old Hispanic mother of two children who has been legally divorced for 3 years. She dropped out of high school at age 15 when she found out that she was pregnant. As a single mother on public assistance, M.J. first began using heroin intranasally at age 17 and began injecting 1 year later. M.J. was born in Puerto Rico, and her family came to the United States when she was age 10. She is the youngest of five children whose father was an unemployed painter and alcoholic who physically abused her mother. He died in Puerto Rico 5 years ago from cirrhosis of the liver. M.J.'s relationship with her mother has always been strained. Her mother had numerous lovers whom M.J. resented. As the youngest, M.J. never felt that she received enough attention or love from her mother. She has spent most of her life searching for approval and love from whoever will show her affection. To support her drug habit, which involved alcohol, cocaine, and continuous heroin use, M.J. turned to prostitution, which led to drug sales, theft, and other criminal activities. During this period, M.J. gave birth to her second child and married the father. M.J. was arrested on numerous occasions and currently has a case pending in criminal court for selling cocaine. After divorcing her husband, she moved in with her mother. Because of her chronic drug abuse and criminal history, the Child Welfare Agency was called anonymously and her children were placed in foster care. After her arrest and removal of her children, her mother threw M.J. out of the house; she lived with anyone who would allow her to spend the night. M.J. entered a methadone maintenance treatment program as one of her first attempts to regain custody of her children. She saw cessation of her cocaine habit as secondary to cessation of her heroin abuse. She initially stated that she wanted to change her life, obtain permanent housing, and cease prostitution. Though currently stabilized on methadone, she continued to use cocaine on a regular basis during her first 6 months in treatment. While in the program, she was tested for HIV and was found to be seropositive. This led to a bout of severe depression and some suicidal ideation, including an escalation in her cocaine abuse. Even though various attempts have been made to engage M.J. in treatment of her cocaine addiction, she is very resistant and often misses appointments. M.J.'s treatment plan may be developed with short- and long-term objectives.

### Short-Term Objectives

1. Evaluate depression and suicidal ideation

Objective: To determine the patient's needs for psychotropic medication, inpatient care, or weekly counseling

Action: Obtain an assessment, diagnosis, and treatment plan from the psychiatrist

Target date: Within 1 month

Responsible persons: Social worker, case- worker, psychiatrist

2. Obtain housing

Objective: To obtain a stable residence for the patient

Action: Contact Section 8 (an assisted- housing program), speak to Department of Social Services housing representative, check classified ads, contact realty agencies

Target date: Immediately

Responsible persons: Patient, caseworker, social worker, case aide

Criteria: Copy of lease, patient self-report, or both

3. Obtain followup HIV care

Objective: To obtain immediate medical attention for the patient, including possible medication with AZT, to delay the progress of the virus, and to reduce the patient's risk of transmitting the virus

Action: Refer to health care practitioners for medical history and comprehensive HIV physical examination.

Target date: 2 weeks

Responsible persons: Patient, caseworker, health care coordinator, medical staff

Criteria: Patient self-report and verification of medical results

4. Address cocaine abuse

Objective: To educate the patient on the psychological and physiological effects of cocaine abuse

Action: Arrange for weekly meeting with caseworker, refer to a cocaine group, or to self-help groups such as Narcotics Anonymous (NA) or Cocaine Anonymous (CA).

Target date: Within 1 month

Responsible persons: Patient, caseworker, group worker, medical staff

Criteria: Patient attendance at meetings with the caseworker and group(s)

### Long-Term Objectives

1. Abstain from cocaine use

Objective: To be free from cocaine abuse, regain custody of children, help resolve criminal court case, prevent physical deterioration due to HIV status

Action: Treatment through inpatient detoxification if outpatient approach has not worked; aftercare, such as cocaine continuing recovery groups; relapse prevention groups, NA, or CA meetings; or weekly meetings with the caseworker

Target date: 6 months

Responsible persons: Patient, caseworker, social worker, medical staff, group workers

Criteria: Toxicology reports, patient self-report, and patient's observed behavior at the treatment program

2. Regain custody of the children

Objective: To reconcile the family unit

Action: Refer to family and child welfare services; cooperate with the child welfare agency; and encourage the patient to become involved in treatment, maintain abstinence, obtain housing, etc.

Target date: 1 year

Responsible persons: Patient, caseworker, social worker, COSA (children of substance abusers) worker

Criteria: Patient self-report and Family and Children Welfare Services report

3. Continue HIV medical care

Objective: To provide ongoing HIV education, treatment, and assessment

Action: Continue with primary care unit and attendance at support group meetings for HIV-positive individuals

Target date: Ongoing

Responsible persons: Patient, medical staff, primary care worker, social worker, caseworker, group worker

Criteria: Patient's self-report, primary care unit reports, and group leader reports

4. Obtain GED

Objective: To enhance patient's employability and self-esteem

Action: Refer to an educational therapist for testing, and have patient attend GED classes

Target date: 2 years

Responsible persons: Patient and educational therapist

Criteria: Patient's self-report and diploma

5. Obtain employment

Objective: To have the patient support herself and her children, and to enhance her self-esteem

Action: Refer to a vocational counselor for testing and determine an appropriate career goal, attend life skills group, consult classified advertisements, and refer to the National Association for Drug Abuse Problems (NADAP) or Vocational Educational Services for Individuals with Disabilities (VESID)

Target date: 2 years

Responsible persons: Patient and vocational counselor

Criteria: Employment verification and patient's self-report

In developing the treatment plan, the clinician should focus the discussion on the problem areas identified by the ASI or a similar instrument, giving special consideration initially to areas critical to survival (eating, sleeping, housing). The treatment plan should evolve as the patient's circumstances change.

Elements of a Treatment Plan

- Identify appropriate interventions.
- Determine the order in which the patient's identified problems should be addressed.
- State the patient's problems along with goals, action steps, and target and actual dates for accomplishing them.
- Identify both long- and short-term goals attainable at 3-, 6-, and 12-month intervals and measurable by an expected performance or behavior.
- Discuss the treatment plan with the patient, and ensure that he or she agrees to it.
- Regularly modify and update the treatment plan to reflect patient changes and progress.

## Patient-Treatment Matching

Patient-treatment matching requires further research. A variety of conclusions have been drawn by researchers about how to match patients to treatment modalities, but the type of treatment that works best for a particular patient at a particular time remains unclear. These are some areas that are under investigation:

- Does matching work only if the treatment programs in the treatment network are distinct from one another in their interventions and are effective? (McLellan and Alterman 1991).
- Should the least intensive treatment interventions be attempted before more intensive interventions are pursued? (Wallace 1992). Do patients who have failed at one level of care need a more intense level of care? (Barthwell and Gastfriend 1993).
- Is the medical maintenance approach appropriate for rehabilitated methadone patients who are stable, employed, not abusing drugs, and not in need of support services? (Novick et al. 1988; Senay et al. 1993).
- Do outpatient intervention services to cocaine-abusing patients offer the same psychological and psychosocial interventions (e.g., counseling services, building the patient's social network, addressing family and job problems, and promoting participation in self-help groups) whether or not the patient is also in a methadone treatment program? (Kolar et al. 1990).
- Can methadone-maintained, cocaine-abusing patients benefit from structure, surveillance, and time-limited groups focusing on learning to avoid stimuli of cocaine craving? (Kolar et al. 1990).
- Should a distinction be made between matching at the initiation of treatment and matching during treatment since different levels of care may be needed over time? (McLellan and Alterman 1991).
- Should drug-free, behavioral, 12-step-oriented, and/or psychosocial approaches for cocaine- or alcohol-dependent patients in MTPs be used in addition to methadone treatment pharmacotherapy? (Dole 1988).
- Are psychological and behavioral interventions along with pharmacological treatment beneficial to concurrently addicted heroin and cocaine users? (Magura et al. 1991).
- Is inpatient or residential treatment initially indicated to detoxify the patient from cocaine followed by abstinence-based treatment for the cocaine addiction and methadone treatment for the heroin addiction? (Kreek 1991).
- Are cognitive therapies that are generally effective with depressed individuals equally effective with depressed substance abusers? (Woody et al. 1985).

Patients with psychiatric comorbidity should be carefully matched to treatment modalities because their success varies in different types of programs (McLellan et al. 1984). In a study that measured treatment improvement of patients in both therapeutic communities and methadone maintenance programs, it was found that those in the residential therapeutic community with high psychiatric severity actually worsened the longer they were retained. However, high-severity patients in the methadone programs slightly improved. Although high-severity patients may improve marginally in a therapeutic community, their chances may be better in a methadone maintenance program (McLellan et al. 1984).

The American Society of Addiction Medicine (ASAM) has developed criteria for assessing the level of care appropriate for substance abuse patients (Hoffman et al. 1991). The criteria are defined for four levels of care using the following categories:

- Acute intoxication or withdrawal potential or both
- Biomedical conditions and complications
- Emotional or behavioral conditions and complications
- Degree of acceptance of or resistance to treatment
- Relapse potential
- Recovery environment

(See appendix B for a more extensive discussion of the ASAM placement criteria and levels of care.)

## The Multidisciplinary Team

The complexities of treating patients concurrently dependent on opioids and cocaine require a multidisciplinary treatment team ideally involving general physicians, psychiatrists, psychologists, nurses, and counseling and social work staff (Barthwell and Gastfriend 1993). The actual composition of the treatment team will vary with the resources of the treatment program and the population treated by the program. Recovering staff often have important insights and can make significant contributions to the multidisciplinary team.

### Roles

The general physician or psychiatrist has the primary medical responsibility on the treatment team. He or she should actively provide direction in the medical care of the patient. Not only should the physician be involved in decisions about medication and dosing levels for methadone patients, but he or she should also have an active role in treatment assessment, diagnosis, and planning in case conferences with the team. The physician should also provide supervision and training to other team members and play an active role in treatment planning. Preferably, the physician will have been trained in addiction medicine. Ideally, program quality assurance plans should incorporate a peer review process.

Physicians are usually involved in doing indepth evaluations of the patient, monitoring all medications, and providing needed substance abuse interventions when indicated. Physicians can also provide help with specialty care and consultation on substance abuse treatment. While trained counseling staff can complete historical information on concurrent opioid and cocaine addicts, only a physician can make the final decision on admitting them to methadone maintenance treatment. Medical staff in a methadone maintenance treatment program are required to determine current dependence, document medical and family history, determine treatment eligibility, and explain the treatment process and the treatment options (Langrod 1993).

An additional role for the psychiatrist is to evaluate the patient and provide a psychological profile as well as administer standard psychological instruments, help the team articulate patient strengths and weaknesses, provide primary therapy when indicated, and consult with and train the treatment team. A psychologist may also perform these tasks.

Nursing staff see patients most often and routinely dispense medication; therefore, they can assess acute changes in appearance or demeanor that may indicate drug impairment or withdrawal and monitor all pharmaceutical medication taken by the patient as well as potential drug-drug interactions. Nurses may also be involved in conducting health education, HIV and TB counseling and education, HIV and TB testing, and TB prophylaxis and treatment.

The counselor or social worker or both work directly with the patient to develop and follow the treatment plan. In programs that do not have social work staff, counselors are often involved in case management services, sometimes supervised by social workers. The case manager on the treatment team helps the patient acquire a healthy living environment, education, employment, or new job skills; negotiate with social, criminal justice, and other systems in which the patient must interact; and address other areas of focus relevant to meeting primary living needs and psychosocial adjustment. Sometimes the social worker also functions as the counselor.

Strategies for Multidisciplinary Team Meetings

- Hold multidisciplinary meetings, ideally twice a week for 1 1/2 hours each.
- Develop an agenda to facilitate the meeting. The agenda might include hospitalizations, HIV cases, updates on patients in crisis, and case reports.
- Base clinical decisions on patients' performance in treatment, focusing on behavior rather than intentions.
- Use multidisciplinary meetings as a forum for clinical reviews of all patients rather than as a forum for "venting" or focusing only on the sicker patients.
- Use multidisciplinary meetings as a time to discuss clinic management issues (e.g., patient-counselor ratio, training, clustering, loitering, dealers who prey on patients); these issues can affect overall treatment. Good management and communication among team members improve morale and service delivery.
- Use regularly scheduled multidisciplinary meetings as an opportunity to provide staff training and quality assurance.

### Multidisciplinary Team Meetings

Multidisciplinary treatment planning and ongoing assessment of the patient by professional staff is most beneficial for an effective treatment strategy and ensures that members of all disciplines work together on the same plan, each from a unique perspective. During these meetings, staff contribute their perspectives on the patient's progress and reach consensus on a treatment course.

Team members must base clinical decisions on the patient's readiness for treatment, which can be determined by identifying the patient's stage of change. For a patient not yet ready to change, for example, the clinician should seek ways to develop motivation.

Miller and Rollnick (1991) describe the stages-of-change model developed by Prochaska and DiClemente (1982). This model can be viewed as a wheel divided into five stages of readiness, with a sixth stage (Precontemplation) positioned outside the wheel. Once the patient enters the wheel, he or she can move through the stages of change. The clinician should recommend treatment appropriate for the patient's particular stage. The six stages are described below:

- Precontemplation-This stage lies outside the wheel. At this point, the person has not yet considered the possibility of change and seldom presents himself or herself voluntarily for treatment.
- Contemplation-This stage is characterized by ambivalence. The patient fluctuates between motivations to change and justifications for not changing.
- Determination-During this stage, the person experiences motivation to change.
- Action-At this point, the person acts to bring about a change. The actions may involve counseling or therapy.
- Maintenance-During this stage, the person seeks to sustain the change accomplished by the previous action and prevent relapse.
- Relapse-If relapse occurs, the person faces the challenge of starting again around the wheel rather than remaining in the relapse stage.

These stages of change and corresponding counseling responsibilities are outlined in the text box.

Stages of Change and Therapist Tasks

Precontemplation

### Training

In addition to specific knowledge about methadone medication (e.g., its pharmacology), all staff should have specialized training in working with patients who may be addicted to cocaine. Staff should receive cross-training and continuing medical education from multidisciplinary team members so that each understands the different roles on the team. This training should include information about HIV and TB, including infection control; counseling concurrently dependent patients; psychiatric comorbidity; domestic violence; and cocaine-specific pharmacology and associated medical complications. A helpful resource in staff training is the State Methadone Treatment Guidelines (CSAT 1993b).