# Appendix F - Diagnostic Assessment Instruments

## Ordering Information

### Addiction Severity Index (ASI)

National Clearinghouse for Alcohol and Drug Abuse Information (NCADI) P.O. Box 2345 Rockville, MD 20847-2345 (800) 729-6686 301) 468-2600

### Beck Depression Inventory (BDI)

The Psychological Corporation Order Service Center P.O. Box 839954 San Antonio, TX 78283-3954 (800) 228-0752

### Diagnostic Interview Schedule (DIS)

EPRB DESR NIMH HIH 5600 Fishers Lane, Room 10C-09 Rockville, MD 20857 (301) 443-3774

### Drug Addiction Severity Test (DAST)

Addiction Research Foundation 33 Russell Street Toronto, Ontario CANADA M5S 2S1

### Michigan Alcoholism Screening Test (MAST)

Melvin L. Selzer 6967 Paseo Laredo La Jolla, CA 92037 (619) 299-4043

### Structured Clinical Interview (SCID)

American Psychiatric Press, Inc. 1400 K Street, NW 11th Floor Washington, DC 20005 (1-800-368-5777)