# Appendix E - Multidrug Abuse Patterns

Multidrug Abuse Patterns

Combination | Desired Effect
Heroin plus alcohol | Enhance a "high" or create euphoria
Heroin followed by alcohol | Self-medicate narcotic withdrawal symptoms
Heroin plus cocaine | "Speedball": enhance or alter cocaine "high" or euphoria
Heroin followed by cocaine | Medicate narcotic withdrawal or mitigate cocaine "nerves" (overstimulation)
Cocaine plus alcohol | Enhance "high"; modulate overstimulation
Cocaine followed by alcohol | Medicate cocaine anxiety, nervousness; modulate the "crash" (parachute)
Cocaine followed by heroin | Medicate overstimulation; modulate the crash (parachute)
Methadone plus alcohol | Create a high; accelerates metabolism
Methadone plus cocaine | Modulate the anxiety and nervousness that is frequent with cocaine use; parachute effect of crash
Methadone plus "benzos" (e.g., Valium) | Create a high; "boost" the methadone