# Appendix D - TB/PPD Testing - Sample Forms

TB/PPD Testing

Patient Name_________________________ SS#__________ Unit: ... Sat ... AC ... SUPT
Section A (History)
- Confirmed Negative TB test in past 30 days: ... Yes ... No Date (Mo/Day/Yr) _________ Location ______________; If YES, DO NOT TEST; SKIP sections B and C; go to section D; - Previous Positive test for tuberculosis: ... Yes ... No Date (Mo/Day/Yr) _________ Location ______________; If YES (positive TB history), DO NOT TEST; go to section C - If NO, complete section B
Section B (If Previously Negative)
- Has patient ever had mumps? ... Yes ... No ... Unknown; - Is patient allergic to eggs?... Yes ... No; Instructions: If patient is allergic to eggs, DO NOT USE MUMPS. Specify amount of erythema and induration in mm. First test for TB is positive if there is palpable induration of at least 5 mm. Test for mumps is positive if there is erythema of at least 5 mm. Test for Candida is positive if the erythema and induration are at least 5 mm. Repeat test for TB, if indicated, within 14 days. Second test for TB is positive if there is palpable induration at least 6 mm larger than was present from the first TB test.; - Results:... Positive ... Negative ... Anergic ... Equivocal ... No Show; If POSITIVE, complete section C
Test | Placement | 24 hr | 48 hr | 72 hr
TB-Initial
Mumps
Candida
Cocci
Date/Time
Initials
TB-Repeat
Date/Time
Initials
Section C (If Previously or Currently Positive)
- Type:...; - Active ...; - Latent ...; - Unknown; - Referral: ...; - IDC ...; - Pulmonary Clinic...; - Hospital ...; - Private Physician ...; - None/Dropped Out ...; - Other__________________________; - Treatment Status: ...; - Initiated/Continuing ...; - Discontinued ...; - Completed ...; - Not Initiated/Contraindicated ...; - Unknown; - If Treatment Discontinued or Not Initiated, reason: ...; - Previous Adequate Treatment ...; - Age ...; - Noncompliance ...; - Poor Liver Function ...; - Other Medical Problem __________
- Treatment: | dose/frequency | start date | recommended end date | actual end date
... Aminosalicylic acid
... Ethambutol HCL
... Isoniazid & Pyridoxine(INH & B6)
... Rifampin
... Streptomycin
... Other
Section D
- HIV Status: ... Positive ... Negative ... Unknown; If POSITIVE, date of EARLIEST positive test (Mo/Yr) ______________ If NEGATIVE, date of MOST RECENT negative test (Mo/Yr) _____________

Substance Abuse Inpatient Unit

TB Testing Supplemental Questions
Chest X-ray results: | NAD / Consistent with TB / Equivocal
Followup (after discharge):
| None indicated
| Repeat Chest X-ray (suggested date) | ____________
| Repeat skin testing (suggested date) | ____________
| Infectious disease appointment (date) | ____________
| Pulmonary appointment (date) | ____________
| CDC report filed
| Unable to follow up: no known address / premature discharge
Important statistics:
| Residence: home / homeless / shelter / unknown
| Imprisonment: past / current
| IV drug abuse: past 6 months / remote history / never
| Three highest ranked drugs of use:
1. ____________ | 2. ____________ | 3. ____________
DSM III R Axis I | _______________
| _______________
| _______________
Axis II | _______________
_______________ Signature | _______________ Date

Substance Abuse Treatment Outpatient Clinic

PPD Testing Supplemental Questions
1. When was your last chest X-ray? | | ___________ Date
2. When were you last skin-tested for tuberculosis? | | ___________ Date
3. Were you tested with a single poke from a needle (PPD) or with four pokes from a small plastic applicator (tine test)? | | ___________ Date
4. Did you get tested with controls (anergy panel)? | | ___________ Y/N
5. Drug use in past 6-12 months (check if yes):
IV Heroin _____ | Other opioids _____ | Sedative/Hypnotic _____
IV Cocaine _____ | Smoked Crack _____ | Snorted Cocaine ______
IV Amphetamine ______ | Other Amphetamine _____ | PCP _____
Alcohol _____ | Cigarettes _____ | Marijuana _____
Hallucinogens _____
6. Residence in the past 6-12 months (check if yes)
Home _____ | Homeless _____ | Shelter _____ | Unknown _____
ORDERS:; 1. Place the PPD skin test with two of the anergy panels on the same forearm with the PPD nearest the elbow and the Coccidioidin or Candida nearest the hand. DO NOT use mumps if allergic to eggs.; 2. Read and record the results at 24, 48 and 72 hours.; 3. DO NOT DO SKIN TESTING if the patient has ever tested positive for tuberculosis.; 4. DO NOT DO SKIN TESTING if the patient has ever been treated for tuberculosis.; 5. Repeat PPD test within 14 days if patient was anergic or had a skin reaction which would be interpreted as negative (less than 5 mm).
_______________ Date | | ____________________ Physician's Signature
____________________ (Signatures of all RNs/LVn involved in testing) | | _______________ Date