# Appendix C - Acronyms

- AA
- Alcoholics Anonymous

- ADHD
- Attention Deficit Hyperactivity Disorder

- ADM disorder
- alcohol, drug, and mental health disorder

- AIA
- AIDS Initial Assessment Questionnaire

- AIDS
- acquired immune deficiency syndrome

- AOD
- alcohol and other drug

- ASAM
- American Society of Addiction Medicine

- ASI
- Addiction Severity Index

- ASP disorder
- antisocial personality disorder

- AZT
- azidothymidine

- BDI
- Beck Depression Inventory

- CA
- Cocaine Anonymous

- CAGE
- Cut Down, Annoyed, Guilty, Eye-Opener

- CARF
- Commission on Accreditation of Rehabilitation Facilities

- CDC
- Centers for Disease Control and Prevention

- CFR
- Code of Federal Regulations

- CNS
- central nervous system

- COSA
- Children of Substance Abusers

- CSAT
- Center for Substance Abuse Treatment

- DARP
- Drug Abuse Reporting Program

- DAST
- Drug Addiction Severity Test

- DATOS
- Drug Abuse Treatment Outcome Study

- DAWN
- Drug Abuse Warning Network

- DEA
- Drug Enforcement Administration

- DHEW
- Department of Health, Education and Welfare

- DIS
- Diagnostic Interview Schedule

- DSM-III-R
- Diagnostic and Statistical Manual of Mental Disorders, Third Edition, Revised

- DSM-IV
- Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition

- ECA
- Epidemiologic Catchment Area

- FDA
- Food and Drug Administration

- GAO
- General Accounting Office

- GED
- general equivalency diploma

- HIV
- human immunodeficiency virus

- ICD-10
- International Classification of Disease, 10th revision

- IDUs
- injecting drug users

- IND
- investigational new drug

- INH
- isoniazid

- IPT
- Interpersonal Psychotherapy model

- IV
- intravenous

- JCAHO
- Joint Commission on the Accreditation of Healthcare Organizations

- LAAM
- levo-alpha-acetylmethadol

- MA
- Methadone Anonymous

- MAO inhibitors
- monoamine oxidase inhibitors

- MAST
- Michigan Alcoholism Screening Test

- MDI
- Bayley Mental Development Index

- MDR TB
- multidrug-resistant tuberculosis

- MTQAS study
- Methadone Treatment Quality Assurance System

- NA
- Narcotics Anonymous

- NADAP
- National Association for Drug Abuse Problems

- NIDA
- National Institute on Drug Abuse

- NIMH
- National Institute of Mental Health

- NTP
- narcotic treatment program

- OEO
- Office of Economic Opportunity

- ONDCP
- Office of National Drug Control Policy

- OSHA
- Office of Safety and Health Administration

- PCP
- phencyclidine

- PCP
- Pneumocystis carinii pneumonia

- PDI
- Motor Development Index

- PPD
- purified protein derivative

- QSOA
- Qualified Service Organization Agreement

- RDC
- Research Diagnostic Criteria

- RR
- Rational Recovery

- RTI
- Research Triangle Institute

- SAMHSA
- Substance Abuse and Mental Health Services Administration

- SAS
- Social Adjustment Scale

- SCID
- Structured Clinical Interview (DSM-IV)

- SIDS
- Sudden Infant Death Syndrome

- SMA
- State Methadone Authority

- SOS
- Secular Organization for Sobriety

- SSA
- Single State Agency

- STDs
- sexually transmitted diseases

- TB
- tuberculosis

- TOPS
- Treatment Outcome Prospective Study

- VA
- Department of Veterans Affairs

- VDRL
- Venereal Disease Reference Laboratory

- VESID
- Vocational Educational Services for Individuals with Disabilities