# Appendix L - Field Reviewers

- Emizie Abbott
- Executive Director
- Cleveland Treatment Center
- Cleveland, OH

- Cynthia E. Aiken
- Executive Director
- Narcotic Drug Treatment Center, Inc.
- Center for Drug Problems
- Anchorage, AK

- John P. Allen, Ph.D.
- Chief
- Treatment Research Branch
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, MD

- Michael E. Amara
- Assistant Director, Program Monitoring
- Department of Public Health and Addiction Services
- Hartford, CT

- John J. Ambre, M.D.
- Director
- Department of Toxicology and Drug Abuse
- American Medical Association
- Chicago, IL

- Philip Appel, Ph.D.
- Project Manager
- New York State Office of Alcoholism and Substance Abuse Services
- New York, NY

- G. Dean Austin
- Chief, Licensure Section
- Division of Substance Abuse and Health
- Iowa Department of Public Health
- Des Moines, IA

- John C. Ball, Ph.D.
- Senior Scientist and Professor
- University of Pennsylvania Research Center/VA Medical Center
- Philadelphia, PA

- Mac R. Bell
- Policy Analyst
- Division of Substance Abuse
- Department for Mental Health and Mental Retardation Services
- Frankfort, KY

- Richard J. Bilangi
- Executive Director
- Connecticut Counseling Centers, Inc.
- Norwalk, CT

- Dennis Bobo
- State Authority
- Bureau of Substance Abuse Services
- Madison, WI

- C. Hope Bolger
- Methadone Administrator
- Office of Substance Abuse Services
- Department of Mental Health, Mental Retardation, and Substance Abuse Services
- Richmond, VA

- Joseph P. Burick, D.O.
- North Hill Family Practice Center, Inc.
- Akron, OH

- Richard Christensen
- Director of Medical Services
- Valle del Sol, Inc.
- Phoenix, AZ

- Donald McKinley Clark
- Principal Investigator
- Clark & Associates
- Sacramento, CA

- Shirley D. Coletti
- President
- Operation PAR, Inc.
- St. Petersburg, FL

- Robert Corley
- Program Field Representative
- Oklahoma Department of Mental Health and Substance Abuse Services
- Oklahoma City, OK

- Thomas H. Coyne
- Trainer and Consultant
- Garden City Park, NY

- Helen L. Danser
- Pharmacy Services Program Manager
- Division of Mental Health, Adult Services Branch
- Department for Mental Health and Mental Retardation Services
- Frankfort, KY

- Sharon R. Dow
- Chief
- Planning and Policy Development
- Maryland Alcohol and Drug Abuse Administration
- Baltimore, MD

- Michael J. Doyle, M.D.
- Chairman
- Commission of Special Issues and Clinical Interests
- American Academy of Family Physicians
- Mantoloking, NJ

- Winfred Dunham, Jr.
- State Methadone Authority and Chief, Program Development
- Alabama Substance Abuse Services Division
- Department of Mental Health and Mental Retardation
- Montgomery, AL

- Mike Ezzell
- Director, Program Compliance
- Texas Commission on Alcohol and Drug Abuse
- Austin, TX

- Robert Garner
- Director
- Alcohol and Drug Abuse Services
- Santa Clara Valley Health and Hospital System
- San Jose, CA

- David Gastfriend, M.D.
- Chief
- Addiction Services
- Massachusetts General Hospital
- Boston, MA

- Jeff Gronstal
- Licensure Inspector
- Division of Substance Abuse and Health Promotion
- Iowa Department of Public Health
- Des Moines, IA

- Charles V. Grudzinskas, Ph.D.
- Acting Deputy Director
- Medications Development Division
- National Institute on Drug Abuse
- Rockville, MD

- Merrill Herman, M.D.
- Chief of Service
- Substance Abuse Treatment Program (SATP)
- Montefiore Medical Center
- Bronx, NY

- Jeffrey A. Hoffman, Ph.D.
- Executive Director
- Center for Drug Treatment and Research
- KOBA Associates, Inc.
- Washington, DC

- Robert Holden
- Program Director
- Partners in Drug Abuse Rehabilitation and Counseling (PIDARC)
- Washington, DC

- Arthur MacNeill Horton, Jr.
- Research Psychologist/Project Officer
- Treatment Services Research Branch
- National Institute on Drug Abuse
- Rockville, MD

- Elizabeth F. Howell, M.D.
- Clinical Director
- Atlanta West Intake and Treatment Center
- Atlanta, GA

- Elizabeth W. Imeson, M.D.
- Medical Director
- Southland Counseling Center
- Lansing, MI

- Paul W. Ingram
- Executive Director
- PBA, Inc.-The Second Step
- Pittsburgh, PA

- Joy Jarfors
- Manager
- Methadone Licensing Branch
- California Department of Alcohol and Drug Programs
- Sacramento, CA

- Oscar Jones
- Program Director
- Lubbock Regional Mental Health Mental Retardation Center
- Lubbock, TX

- Herman Joseph
- Chair
- Chemical Dependency Research Working Group
- New York State Office of Alcoholism and Substance Abuse Services
- New York, NY

- Roger Kenton
- Chief
- Division of Program Development
- Ohio Department of Alcohol and Drug Addiction Services
- Columbus, OH

- Andrew J. V. Klein, M.D.
- Medical Director (retired)
- Honesty House
- Orange, NJ

- Ron Kletter, Ph.D.
- Executive Director
- Bay Area Addiction Research and Treatment (BAART)
- San Francisco, CA

- Gary J. Koontz
- Adult Treatment Services Coordinator
- Office of Behavioral Health Services
- Division on Alcoholism and Drug Abuse
- West Virginia Department of Health and Human Resources
- Charleston, WV

- John Langrod, Ph.D.
- Director of Research and Quality Improvement
- Division of Substance Abuse
- Albert Einstein College of Medicine
- Bronx, NY

- Marilyn LeVee
- Supervisor
- Southland Counseling Center
- Lansing, MI

- Joyce H. Lowinson, M.D.
- Professor of Psychiatry, Vice-Chair, and Executive Director
- Division of Substance Abuse
- Albert Einstein College of Medicine
- Bronx, NY

- David J. Mactas
- President
- Marathon, Inc.
- (Currently, Director, Center for Substance Abuse Treatment, Rockville, MD)

- Janice S. Maehlum
- Coordinator of Drug Programs
- Dede Wallace Center
- Madison, TN

- Kay Malone
- Projects Director
- Brandywine Counseling, Inc.
- Wilmington, DE

- George F. Marko
- Board Member
- American Council on Alcoholism
- LaPorte, IN

- Myrene McAninch, Ph.D.
- President
- Healthcare Quality Improvement, Inc.
- Seattle, WA

- Michael J. McCann
- Administrative Director
- Matrix Center
- Woodland Hills, CA

- John J. McCarthy, M.D.
- Medical and Executive Director
- Bi-Valley Medical Clinic, Inc.
- Sacramento, CA

- Christine Beck Meadows
- Executive Director
- Corpus Christi Drug Abuse Council, Inc.
- Corpus Christi, TX

- David Mee-Lee, M.D.
- Medical Director
- Community Systems/BMS
- Castle Medical Center
- Honolulu, HI

- John T. Perez
- Assistant Director
- New York State Office of Alcoholism and Substance Abuse Services
- New York, NY

- Nina Peskoe Peyser
- Executive Director
- Chemical Dependency Institute
- Beth Israel Medical Center
- New York, NY

- Leon PoVey
- Director
- Utah State Division of Substance Abuse
- Salt Lake City, UT

- Nick Vega Puente
- Residential Treatment Coordinator
- Chemical Dependency Program Division
- Minnesota Department of Human Services
- St. Paul, MN

- Randolph E. Ratliff
- Interim Executive Vice President
- Operation PAR, Inc.
- St. Petersburg, FL

- Nicholas Reuter
- Consumer Safety Officer
- Office of Health Affairs
- Food and Drug Administration
- Rockville, MD

- Michael Rizzi
- Deputy Director
- CODAC
- Cranston, RI

- Alex R. Rodriguez, M.D.
- Medical Director
- Preferred Works/Value Health
- Wilton, CT

- Marianne L. Scheck
- Nurse/Counselor
- Marion County Drug Treatment Program
- Salem, OR

- Elizabeth C. Shifflette, Ed.D.
- Treatment Consultant
- South Carolina Department of Alcohol and Other Drug Abuse Services
- Columbia, SC

- Stephan Jon Sorrell, M.D.
- Medical Director
- Substance Abuse Program
- St. Luke's/Roosevelt Hospital Center
- New York, NY

- Elizabeth A. Stanley
- Chief Deputy Director
- Department of Alcohol and Drug Programs
- Sacramento, CA

- Kenneth D. Stark
- Director
- Division of Alcohol and Substance Abuse
- Department of Social and Health Services
- Olympia, WA

- Carolyn L. Suchecki
- Quality Assurance Coordinator
- Department of Public Health and Addiction Services
- Hartford, CT

- Richard T. Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- Mental Health and Behavioral Sciences Service
- Department of Veterans Affairs
- Washington, DC

- Sari Trachtenberg
- Director of Professional Services
- Achievement Through Counseling and Treatment (ACT)
- Philadelphia, PA

- Ronald J. Vlasaty
- Administrator
- Division of Licensing and Monitoring
- Illinois Department of Alcoholism and Substance Abuse
- Chicago, IL

- William W. Weddington, M.D.
- Head, Addiction Psychiatry Program
- West Side Veterans Affairs Medical Center
- Chicago, IL

- Bink F. Williams
- Clinical Resources Coordinator
- Florida Department of Health and Rehabilitative Services
- Tallahassee, FL

- Cheryl D. Williams
- Director
- Division of Drug and Alcohol Program Licensing
- Pennsylvania Department of Health
- Harrisburg, PA

- Ken Willinger, Ph.D.
- Clinical Psychologist
- Hawaii Alcohol and Drug Abuse Division
- Honolulu, HI

- Gary E. Woodward-Smith
- Director of Treatment Services
- Bureau of Alcohol and Drug Abuse Services
- Tennessee Department of Health
- Nashville, TN

- Larry Worley
- Executive Director
- Center for Behavioral Health, Nevada
- Las Vegas, NV

- John A. Yeatman
- Senior Quality Assurance Specialist
- Division of Alcoholism, Drug Abuse and Mental Health
- Delaware Health and Social Services
- New Castle, DE