# Appendix K - Federal Resource Panel

- Suzanne Baranik
- Public Health Advisor
- Center for Substance Abuse Treatment
- Rockville, MD

- James Callahan, D.P.A.
- Executive Vice President/CEO
- American Society of Addiction Medicine
- Washington, DC

- John Gregrich
- Acting Deputy Director for Treatment
- Office of National Drug Control Policy
- Executive Office of the President
- Washington, DC

- Charles Grudzinskas, Ph.D.
- Director
- Division of Medications Development
- National Institute on Drug Abuse
- Rockville, MD

- Arthur MacNeill Horton, Jr., Ed.D.
- Research Psychologist
- Treatment Research Branch
- Division of Clinical Research
- National Institute on Drug Abuse
- Rockville, MD

- Herbert D. Kleber, M.D., Chairperson
- Director
- Division on Substance Abuse
- College of Physicians and Surgeons
- Columbia University
- New York State Psychiatric Institute
- New York, NY

- Frances Levin, M.D., Facilitator
- Assistant Professor of Psychiatry
- College of Physicians and Surgeons
- Columbia University
- New York State Psychiatric Institute
- New York, NY

- Robert Lubran, M.S., M.P.H.
- Chief
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment
- Rockville, MD

- Donald Storms
- Project Coordinator
- New York City Department of Health
- HIV Anonymous Testing and Counseling Site
- New York, NY

- Richard Suchinsky, M.D.
- Associate Director for Addictive Disorders and Psychiatric Rehabilitation
- Department of Veterans Affairs
- Washington, DC

- Betty Tai, Ph.D.
- Division of Medications Development
- National Institute on Drug Abuse
- Rockville, MD

- Sylvia D. Trent, R.N.
- Public Health Analyst
- Health Resources Services Administration
- Bureau of Primary Health Care
- Rockville, MD