# Appendix J - Self-Help Groups

These telephone numbers are provided for the convenience of readers who want information on the following self-help groups:

- Alcoholics Anonymous (AA)
- (212) 870-3400 (New York, NY)
- Cocaine Anonymous (CA)
- (310) 839-1141 (Los Angeles, CA)
- Methadone Anonymous (MA)
- (410) 837-4292 (Baltimore, MD)
- Narcotics Anonymous (NA)
- (818) 780-3951 (Pasadena, CA)
- Rational Recovery (RR)
- (916) 621-4374 (Sacramento, CA)
- Women for Sobriety
- (215) 536-8026 (Philadelphia, PA)