# List of Acronyms/Abbreviations

Acronyms/Abbreviations | Definition
AAFP | American Academy of Family Physicians
ACP | American College of Physicians
ACT | Assertive Community Treatment
AGS | American Geriatric Society
BIPA | Medicare Benefits Improvement and Protection Act
CBA | Controlled Before-After
CCHT | Coordination/Home Telehealth
CI | Confidence interval
CINAHL^®^ | Cumulative Index to Nursing and Allied Health^®^
CMS | Centers for Medicare and Medicaid Services
CMSA | Case Management Society of America
DMAA | Disease Management Association of America
EPC | Evidence-based Practice Center
GHb | Glycated hemoglobin
GRACE | Geriatric Resources for Assessment and Care of Elder
HAPI | Health and Psychological Index
IOM | Institute of Medicine
ICU | Intensive care unit
ITS | Interrupted Time Series
JCAHO | Joint Commission on Accreditation of Healthcare Organizations
LOS | Length of Stay
LTC | Long-term care
MHSO | Medicare Health Support Organizations
MMA | Medicare Prescription Drug, Improvement, and Modernization Act
NCQA | National Committee for Quality Assurance
NQF | National Quality Forum
OR | Odds ratio
PACE | Program of All-Inclusive Care for the Elderly
RCT | Randomized Controlled Trial
ROI | Return on Investment
RR | Risk ratio
SGIM | Society of General Internal Medicine
S/HMO | Social Health Maintenance Organization
URAC | Utilization Review Accreditation Commission
VA | Department of Veterans Affairs