# References and Included Reviews

1 Gwathmey B. Bringing cancer care and prevention to all. [Accessed: January 26, 2007]; Available from: http://ralphlaurencenter.org/about_director.asp?langid=1
2 Institute of Medicine (U.S.). Committee on Quality of Health Care in America. Crossing the quality chasm: a new health system for the 21st century. Washington, D.C.: National Academy Press; 2001.
3 Ma J, Stafford RS. Quality of US outpatient care: temporal changes and racial/ethnic disparities. Arch Intern Med. Jun 27. 2005;165(12):1354-61. [pmid: 15983283].
4 National Committee for Quality Assurance. The state of health care quality: 2005. 2005 [Accessed: January 28, 2006]; Available from: http://www.ncqa.gov
5 McGlynn EA, Asch SM, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. Jun 26. 2003;348(26):2635-45. [pmid: 12826639].
6 Institute of Medicine (U.S.). Committee on Identifying Priority Areas for Quality Improvement. Priority areas for national action: transforming health care quality. Washington, D.C.: National Academies Press; 2003.
7 Stille CJ, Jerant A, Bell D, Meltzer D, Elmore JG. Coordinating care across diseases, settings, and clinicians: a key role for the generalist in practice. Ann Intern Med. Apr 19. 2005;142(8):700-8. [pmid: 15838089].
8 Coleman EA, Boult C. Improving the quality of transitional care for persons with complex care needs. J Am Geriatr Soc. Apr. 2003;51(4):556-7. [pmid: 12657079].
9 Coleman EA. Falling through the cracks: challenges and opportunities for improving transitional care for persons with continuous complex care needs. J Am Geriatr Soc. Apr. 2003;51(4):549-55. [pmid: 12657078].
10 Grumbach K, Bodenheimer T. A primary care home for Americans: putting the house in order. JAMA. Aug 21. 2002;288(7):889-93. [pmid: 12186609].
11 Reiss J, Gibson R. Health care transition: destinations unknown. Pediatrics. Dec. 2002;110(6 Pt 2):1307-14. [pmid: 12456950].
12 Coleman EA, Berenson RA. Lost in transition: challenges and opportunities for improving the quality of transitional care. Ann Intern Med. Oct 5. 2004;141(7):533-6. [pmid: 15466770].
13 Ziring PR, Brazdziunas D, Cooley WC, et al. American Academy of Pediatrics. Committee on Children With Disabilities. Care coordination: integrating health and related systems of care for children with special health care needs. Pediatrics. Oct. 1999;104(4 Pt 1):978-81. [pmid: 10506246].
14 Partnership for Solutions. Chronic Conditions: Making the Case for Ongoing Care; 2004.
15 Phillips BR, Kemper P, Applebaum RA. The evaluation of the National Long Term Care Demonstration. 4. Case management under channeling. Health Serv Res. Apr. 1988;23(1):67-81. [pmid: 3130331]. [pmcid: 1065489].
16 Kane RA. The noblest experiment of them all: learning from the national channeling evaluation. Health Serv Res. Apr. 1988;23(1):189-98. [pmid: 3130328]. [pmcid: 1065497].
17 Kemper P. The evaluation of the National Long Term Care Demonstration. 10. Overview of the findings. Health Serv Res. Apr. 1988;23(1):161-74. [pmid: 3130326]. [pmcid: 1065495].
18 Manton KG, Newcomer R, Lowrimore GR, Vertrees JC, Harrington C. Social/health maintenance organization and fee-for-service health outcomes over time. Health Care Financ Rev. Winter. 1993;15(2):173-202. [pmid: 10135342].
19 Evaluation Results for the Social/Health Maintenance Organizations II (2002). [Accessed: February 4, 2007]; Available from: http://www.cms.hhs.gov/DemoProjectsEvalRpts/downloads/SHMO_Report.pdf
20 Eng C, Pedulla J, Eleazer GP, McCann R, Fox N. Program of All-inclusive Care for the Elderly (PACE): an innovative model of integrated geriatric care and financing. J Am Geriatr Soc. Feb. 1997;45(2):223-32. [pmid: 9033525].
21 Mui AC. The Program of All-Inclusive Care for the Elderly (PACE): an innovative long-term care model in the United States. J Aging Soc Policy. 2001;13(23):53-67. [pmid: 12216362].
22 The Centers for Medicare & Medicaid Services. Medicare Coordinated Care Demonstration. Fact Sheet., 2004 [Accessed; Available from: http://www.cms.hhs.gov/DemoProjectsEvalRpts/downloads/CC_Fact_Sheet.pdf
23 Glabman M. 12 DM trends you should know about. Managed Care Magazine, 2005 [Accessed: August 30, 2006]; Available from: http://www.managedcaremag.com/archives/0508/0508.twelvedmtrends.html
24 Gelber S, Dougherty RH. Disease management for chronic behavioral health and substance use disorders. 2005 [Accessed: May 20, 2006]; Available from: http://www.chcs.org/usr_doc/bh_dm.pdf
25 Are disease management programs effective in improving quality of care for people with chronic conditions?, August 2003 [Accessed: January 30, 2006]; Available from: http://www.euro.who.int/document/e82974.pdf
26 Anderson T. Employers should investigate disease management math crimes. 2005 [Accessed: January 30, 2006]; Available from: http://www.benefitnews.com/detail.cfm?id=6901
27 Standard outcome metrics and evaluation methodology for disease management programs. Novemeber 2002 [Accessed: January 30, 2006]; Available from: http://www.americanhealthways.com/Pdf/SMoutcomes_FINAL.pdf
28 Long DA, Perry TL, Pelletier KR, Lehman GO. Care management program evaluation: constituents, conflicts, and moves toward standardization. Dis Manag. Jun. 2006;9(3):176-81. [pmid: 16764535].
29 Disease management effectiveness programs: A final report from the Pacific Business Group. November 2002 [Accessed: January 30, 2006]; Available from: http://www.pbgh.org/programs/dmep/disease_mgmt_report_11-02.pdf
30 Short AC, Mays GP, Mittler J. Disease management: A leap of faith to lower-cost, higher-quality health care. Issue brief No. 69. October 2003 [Accessed: January 30, 2006]; Available from: http://www.hschange.com/CONTENT/607/
31 Anderson G. Medicare and Chronic Conditions. N Engl J Med. 2005;353(3):305-9. [pmid: 16034019].
32 Chen A, Brown R, Archibald N, Aliotta S, Fox PD. Best practices in coordinated care. March 22, 2000 [Accessed: January 30, 2006]; Available from: http://www.cms.hhs.gov/DemoProjectsEvalRpts/downloads/CC_Full_Report.pdf
33 Blaum C, Douglass BA, Marion LN, et al. Mainstreaming Care Coordination for People with Complex Health Care Needs. 2001 [Accessed: January 30, 2006]; Available from: http://www.primarycaresociety.org/2001a.htm
34 Super N. Medicare's Chronic Care Improvement Pilot Program: What is its Potential? National Health Policy Forum Issue Brief. 2004;797 (http://www.nhpf.org/pdfs_ib/IB797_ChronicCare.pdf).
35 The Medicare Modernization Act and Chronic Care Improvement. 2004 [Accessed: January 30, 2006]; Available from: http://www.medpac.gov/publications%5Ccongressional_reports%5CJune04_ch2.pdf
36 Centers for Medicare and Medicaid Services. Demonstration Projects and Evaluation Reports. [Accessed: January 24, 2007]; Available from: http://www.cms.hhs.gov/DemoProjectsEvalRpts/MD/list.asp#TopOfPage
37 The Centers for Medicare and Medicaid Services. Medicare health support to improve care of beneficiaries with chronic illnesses. [Accessed: January 30, 2006]; Available from: http://www.cms.hhs.gov/CCIP/downloads/factsheet.pdf
38 The Centers for Medicare and Medicaid Services. Care management for high-cost beneficiaries general information fact sheet. [Accessed: January 30, 2006]; Available from: http://www.cms.hhs.gov/DemoProjectsEvalRpts/downloads/CMHCB_GeneralInfo_FactSheet.pdf
39 The Centers for Medicare and Medicaid Services. Details for care management of high cost beneficiaries demonstration. [Accessed: January 30, 2006]; Available from: http://www.cms.hhs.gov/DemoProjectsEvalRpts/MD/itemdetail.asp?filterType=none&filterByDID=-00&sortByDID=3&sortOrder=ascending&itemID=CMS024081
40 The Centers for Medicare and Medicaid Services. Help for chronically ill beneficiaries: The Medicare disease management demonstration., 2003 [Accessed: January 23, 2006]; Available from: http://www.cms.hhs.gov/DemoProjectsEvalRpts/downloads/BIPAADM_Fact_Sheet.pdf
41 The Centers for Medicare and Medicaid Services. Providing coordinated care to improve quality of care for chronically ill Medicare beneficiaries., 2001 [Accessed: January 23, 2006]; Available from: http://www.cms.hhs.gov/apps/media/press/release.asp?Counter=394
42 Brown R, Schore J, Archibald N, et al. Coordinating care for Medicare beneficiaries: early experiences of 15 demonstration programs, their patients, and providers. 2004 [Accessed: January 24, 2007]; Available from: http://www.mathematica-mpr.com/publications/PDFs/bestpraccongressional.pdf
43 The Centers for Medicare and Medicaid Services. Medicare physician group practice demonstration: New demonstration program tests financial incentives for improved quality and coordination in large group practices., 2005 [Accessed: January 23, 2006]; Available from: http://www.cms.hhs.gov/DemoProjectsEvalRpts/downloads/PGP_Fact_Sheet.pdf
44 Trisolini M, Pope G, Kautter J, Aggarwal J. Medicare Physician Group Practices: Innovations in Quality and Efficiency. The Commonwealth Fund, December 2006. December 2006 [Accessed: January 22, 2007]; Available from: http://www.cmwf.org/publications/publications_show.htm?doc_id=428880
45 Silow-Carroll S, Alteras T. Stretching State Health Care Dollars: Targeted Care Management to Enhance Cost-Effectiveness. 2004 [Accessed: January 23, 2006]; Available from: http://www.cmwf.org/publications/publications_show.htm?doc_id=243635
46 Smith V, Ramesh R, Gifford K, Ellis E, Rudowitz R, O'Malley M. The Continuing Medicaid Budget Challenge: State Medicaid Spending Growth and Cost Containment in Fiscal Year 2004 and 2005: Results from a 50-State Survey; 2004.
47 Williams C. Medicaid Disease Management: Issues and Promises: Kaiser Commission on Medicaid and the Uninsured; 2004 September 24. Report No.: 7170.
48 Disease Management for Asthma. 2004 [Accessed: January 23, 2006]; Available from: http://www.npcnow.org/resources/PDFs/AsthmaMonograph2004.pdf
49 States' Issues and Concerns with Implementation of Medicare Part D Prescription Drug Coverage. July 2004 [Accessed: January 23, 2006]; Available from: http://www.statecoverage.net/pdf/medicarepartd.pdf
50 Rosenbach M, Young C. Care Coordination and Medicaid Managed Care: Emerging Issues for States and Managed Care Organizations. Princeton, New Jersey: Mathematica Policy Research, Inc.; 2000.
51 The Medicaid Integration Partnership. [Accessed: 01/30/06; Available from: http://fortress.wa.gov/dshs/maa/mip/
52 Florida: A Healthy State. A Florida First Health Care Initiative. November, 2004 [Accessed: January 30, 2006]; Available from: http://www.floridahealthy.org/program-outcomes/clinical-outcomes.html
53 Department of Veteran Affairs Office of Care Coordination. General telehealth in the VA. 1/30/2006 [Accessed: January 30, 2005]; Available from: http://www.va.gov/occ/THinVA.asp
54 Department of Veterans Affairs. Care coordination in the Department of Veterans Affairs: Providing the right care in the right place at the right time. Activities and Achievements 2003-2005., 2005 [Accessed; Available from: http://www.va.gov/occ/Docs/OCCProgRep.pdf
55 Statement of Patricia Ryan MS RN,VISN 8 Community Care Coordination Service VHA Office of Care Coordination Department of Veterans Affairs. Testimony for the House Committee on Veterans' Affairs., 2005 [Accessed: January 23, 2006]; Available from: http://veterans.house.gov/hearings/schedule109/may05/5-18-05/pryan.html
56 Chumbler N, Neugaard B, Kobb R, Ryan P, Qin H, Joo Y. Evaluation of a care coordination/home-telehealth program for veterans with diabetes: health services utilization and health-related quality of life. Eval Health Prof. 2005;28(4):464-78. [pmid: 16272426].
57 Wakefield B, Buresh K, Flanagan J, Kienzle M. Interactive video specialty consultations in long-term care. J Am Geriatr Soc. 2004;52(5):789-93. [pmid: 15086663].
58 Whited J, Hall R, Foy M, et al. Patient and clinician satisfaction with a store-and-forward teledermatology consult system. Telemed J E Health. 2004;10(4):422-31. [pmid: 15689645].
59 Barnett TE, Chumbler NR, Vogel WB, Beyth RJ, Qin H, Kobb R. The effectiveness of a care coordination home telehealth program for veterans with diabetes mellitus: a 2-year follow-up. Am J Manag Care. Aug. 2006;12(8):467-74. [pmid: 16886889].
60 Noel H, Vogel D, Erdos J, Cornwall D, Levin F. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047].
61 Chumbler N, Mann W, Wu S, Schmid A, Kobb R. The association of home-telehealth use and care coordination with improvement of functional and cognitive functioning in frail elderly men. Telemed J E Health. 2004;10(2):129-37. [pmid: 15319042].
62 Patient Navigator Outreach and Chronic Disease Prevention Act of 2005. [Accessed: January 26, 2007]; Available from: http://frwebgate.access.gpo.gov/cgi-bin/getdoc.cgi?dbname=109_cong_bills&docid=f:h1812enr.txt.pdf
63 Executive Order: Incentives for the Use of Health Information Technology and Establishing the Position of the National Health Information Technology Coordinator [Accessed: January 26, 2007]; Available from: http://www.whitehouse.gov/news/releases/2004/04/20040427-4.html
64 Whellan DJ, Cohen EJ, Matchar DB, Califf RM. Disease management in healthcare organizations: results of in-depth interviews with disease management decision makers. American Journal of Managed Care. 2002;8(7):633-41. [pmid: 12125803].
65 DM Programs Can Fill ‘Gap’ Left by Suboptimal Rx Treatment. [Accessed: February 3, 2007]; Available from: http://www.aishealth.com/ManagedCare/DM/DM_Programs_Can_Fill_Gap.html
66 More Health Plans Use Bariatric Centers of Excellence to Manage Obesity. [Accessed: Febuary 3, 2007]; Available from: http://www.aishealth.com/ManagedCare/DM/DM_Bariatric.html
67 Mechanic R. Will Care Management Improve the Value of U.S. Health Care? Background Paper for the 11th Annual Princeton Conference May 20 – 21, 2004 [Accessed: January 3, 2007]; Available from: http://council.brandeis.edu/pubs/Princeton%20XI/Rob%20Mechanic%20paper.pdf
68 American Academy of Pediatrics, Council on Children with Disabilities. Care coordination in the medical home: integrating health and related systems of care for children with special health care needs. Pediatrics. 2005;116(5):1238-44. [pmid: 16264016].
69 American Academy of Family Physicians. Testimony on “Medicare chronic disease ‘care management fee’ concept” before the practicing physicians' advisory council., 2004 [Accessed: January 23, 2006]; Available from: http://www.aafp.org/x26272.xml
70 American College of Physicians. Written comments on section 721 of the Medicare Modernization Act of 2003, the Medicare Chronic Care Improvement (CCI) demonstration program. Subcommittee on Health of the House Ways and Means Committee, 2004 [Accessed: January 23, 2006]; Available from: http://waysandmeans.house.gov/hearings.asp?formmode=view&id=2194
71 Society of General Internal Medicine. Health Care System Chaos Should Spur Innovation: Summary of a report of the Society of General Internal Medicine Task Force on the Domain of General Internal Medicine. Ann Intern Med. 2004;140(8):639-43. [pmid: 15096335].
72 AAFP testifies to PPAC about chronic disease management. February 2004 [Accessed: January 30, 2006]; Available from: http://www.aafp.org/x26273.xml
73 Berenson R. Medicare chronic care improvement. Congressional testimony., 2004 [Accessed: January 23, 2006]; Available from: http://www.urban.org/publications/900714.html
74 American College of Physicians. The Advanced Medical Home: A Patient-Centered, Physician-Guided Model of Health Care. Policy Monograph of the American College of Physicians. 2006 [Accessed: January 3, 2007]; Available from: http://www.acponline.org/hpp/statehc06_5.pdf
75 Debisette AT, Esperat MC, Johnson AE, et al. Healthy, wealthy, and wise: expanding the medical home. 2005 [Accessed: August 20, 2006]; Available from: http://www.primarycaresociety.org/2005e.pdf
76 Disease Management Association of America website. [Accessed; Available from: www.dmaa.org
77 Case Management Society of America website.
78 Care coordination across the continuum policy recommendations. A White House conference on aging policy solutions forum., 2005 [Accessed: May 23, 2006]; Available from: http://www.medicaring.org/whcoa/care_coord_short_recommendations_final.pdf
79 People with chronic conditions, coordinated care, and the Medicare Act of 2004. 2005 [Accessed: May 23, 2006]; Available from: http://www.medicareadvocacy.org/chronic_ChronCoordCareAndMedActof2003.htm
80 Carson N. Meeting the challenge of care coordination. [Accessed: January 30, 2005]; Available from: http://www.thefamilycaregiver.org/ed/v1_a3.cfm
81 Fifth Disease Management Colloquim, 2005. [Accessed; Available from: http://www.dmconferences.com/past5/index.html
82 Coleman EA. Aspen Transitional Care Conference Proceedings. 2002 [Accessed: January 30, 2005]; Available from: http://www.caretransitions.org/documents/AspenTransitionProceedings.pdf
83 Case Management Society of America 2006 conference. [Accessed; Available from: http://www.cmsa.org/CONFERENCES/CMSAAnnualConferenceExpo/tabid/83/Default.aspx
84 Department of Veterans Affairs Office of Care Coordination. Care Coordination in VA. [Accessed: January 23, 2006]; Available from: http://www.va.gov/occ/CCinVA.asp
85 DMAA 2005 Conference. [Accessed; Available from: http://www.dmaa.org/conferences.html
86 3rd Annual Optimizing the Implementation of Predictive Modeling. [Accessed: February 10, 2006]; Available from: http://www.managedhealthcareexecutive.com/mhe/event/eventDetail.jsp?id=281877
87 The Disease Management Colloquium. [Accessed: February 10, 2006]; Available from: http://www.dmconferences.com/
88 Disease Management Association of America. Conferences. 2006 [Accessed: January 23, 2006]; Available from: http://www.dmaa.org/conferences.html
89 Allred CA, Arford PH, Michel Y. Coordination as a critical element of managed care. J Nurs Adm. Dec. 1995;25(12):21-8. [pmid: 8523140].
90 Allred CA, Arford PH, Michel Y, Veitch JS, Dring R, Carter V. Case management: the relationship between structure & environment. Nurs Econ. 1995 Jan–Feb;13(1):32–41, 51.
91 Bickell NA, Young GJ. Coordination of care for early-stage breast cancer patients. J Gen Intern Med. Nov. 2001;16(11):737-42. [pmid: 11722686]. [pmcid: 1495290].
92 Bodenheimer T, Lo B, Casalino L. Primary care physicians should be coordinators, not gatekeepers. JAMA. Jun 2. 1999;281(21):2045-9. [pmid: 10359396].
93 Bolland JM, Wilson JV. Three faces of integrative coordination: a model of interorganizational relations in community-based health and human services. Health Serv Res. Aug. 1994;29(3):341-66. [pmid: 8063569]. [pmcid: 1070009].
94 Cassady CE, Starfield B, Hurtado MP, Berk RA, Nanda JP, Friedenberg LA. Measuring consumer experiences with primary care. Pediatrics. Apr. 2000;105(4 Pt 2):998-1003. [pmid: 10742362].
95 Cooley WC, McAllister JW, Sherrieb K, Clark RE. The Medical Home Index: development and validation of a new practice-level measure of implementation of the Medical Home model. Ambul Pediatr. Jul–Aug. 2003;3(4):173-80. [pmid: 12882594].
96 Fletcher RH, O'Malley MS, Fletcher SW, Earp JA, Alexander JP. Measuring the continuity and coordination of medical care in a system involving multiple providers. Med Care. May. 1984;22(5):403-11. [pmid: 6717120].
97 Flocke SA, Stange KC, Zyzanski SJ. The association of attributes of primary care with the delivery of clinical preventive services. Med Care. Aug. 1998;36(8 Suppl):AS21-30. [pmid: 9708580].
98 Flocke SA. Measuring attributes of primary care: development of a new instrument. J Fam Pract. Jul. 1997;45(1):64-74. [pmid: 9228916].
99 Forrest CB, Glade GB, Baker AE, Bocian A, von Schrader S, Starfield B. Coordination of specialty referrals and physician satisfaction with referral care. Archives of Pediatrics & Adolescent Medicine. 2000;154(5):499-506. [pmid: 10807303].
100 Institute of Medicine (U.S.). Division of Health Care Services. Committee on the Future of Primary Care., Donaldson MS. Primary care: America's health in a new era. Washington, D.C.: National Academy Press; 1996.
101 Starfield B. Primary care: balancing health needs, services, and technology. New York, NY: Oxford University Press; 1998.
102 Gilbert M, Counsell CM. Coordinated care for the SCI patient. SCI Nurs. Aug. 1995;12(3):87-9. [pmid: 7569852].
103 Gittell JH. Organizing work to support relational co-ordination. Int J of Human Resource Management. 2000;11(3):517-39.
104 Gittell JH. Coordinating mechanisms in care provider groups: relational coordination as a mediator and input uncertainty as a moderator of performance effects. Management Science. 2002;48(11):1408-26.
105 Gittell JH, Weiss SJ. Coordination networks within and across organizations: a multi-level framework. J Management Studies. 2004;41(1):127-53.
106 Glasgow RE, Wagner EH, Schaefer J, Mahoney LD, Reid RJ, Greene SM. Development and validation of the Patient Assessment of Chronic Illness Care (PACIC). Med Care. May. 2005;43(5):436-44. [pmid: 15838407].
107 Guastello SJ, Bock BR, Caldwell P, Bond RW Jr. Origins of group coordination: nonlinear dynamics and the role of verbalization. Nonlinear Dynamics Psychol Life Sci. Apr. 2005;9(2):175-207. [pmid: 15757578].
108 Healey AN, Undre S, Vincent CA. Developing observational measures of performance in surgical teams. Qual Saf Health Care. Oct. 2004;13(Suppl 1):i33-40. [pmid: 15465953].
109 Hoenig H, Sloane R, Horner RD, Zolkewitz M, Reker D. Differences in rehabilitation services and outcomes among stroke patients cared for in veterans hospitals. Health Serv Res. Feb. 2001;35(6):1293-318. [pmid: 11221820]. [pmcid: 1089191].
110 Institute of Medicine (U.S.). Committee on the Crossing the Quality Chasm: Next Steps Toward a New Health Care System. The 1st annual crossing the quality chasm summit: a focus on communities. Washington, D.C.: National Academies Press; 2004.
111 Shortell S, Gillies R, Anderson D. Remaking health care in America. 2nd ed. San Fransisco, CA: Jossey-Bass; 2000.
112 Kibbe DC. Physicians, care coordination, and the use of web-based information systems to manage chronic illness across the continuum. Case Manager. Sep–Oct. 2001;12(5):56-61. [pmid: 11552096].
113 Kinsman SL, Levey E, Ruffing V, Stone J, Warren L. Beyond multidisciplinary care: a new conceptual model for spina bifida services. Eur J Pediatr Surg. Dec. 2000;10(Suppl 1):35-8. [pmid: 11214831].
114 Kodner DL. The quest for integrated systems of care for frail older persons. Aging Clin Exp Res. Aug. 2002;14(4):307-13. [pmid: 12462377].
115 Lima BR, Brooks ML. Coordination of services for outpatients under concurrent medical and psychiatric care. Gen Hosp Psychiatry. Oct. 1985;7(4):330-3. [pmid: 4065551].
116 Longest J, B.B., Klingensmith JM. Coordination and communication. In: Shortell SM, Kaluzny AD, editors. Health care management: organization design and behavior. New York: Delmar Publishers Inc.; 1994. p. 182–211.
117 Malone TW, Crowston K. The interdisciplinary study of coordination. ACM Computing Surveys. 1994;26(1):87-119.
118 Allen D, Ryan K, Prepared by the Care Coordination Work Group of the Massachusetts Consortium for Children with Special Health Care Needs. Care Coordination in Massachusetts Findings & Recommendations of a Three-Year Study. January 14, 2006 [Accessed: January 21, 2007]; Available from: http://www.neserve.org/maconsortium/pdf/CareCoordination/Care_Coordination_in_MA_Exec_Summary_6-06.pdf
119 McGuiness C, Sibthorpe B. Development and initial validation of a measure of coordination of health care. Int J Qual Health Care. Aug. 2003;15(4):309-18. [pmid: 12930046].
120 National Quality Forum. NQF-Endorsed Definition and Framework for Measuring Care Coordination. [Accessed: January 21, 2007]; Available from: http://216.122.138.39/pdf/reports/ambulatory_endorsed_definition.pdf
121 Ohlinger J, Brown MS, Laudert S, Swanson S, Fofah O. Development of potentially better practices for the neonatal intensive care unit as a culture of collaboration: communication, accountability, respect, and empowerment. Pediatrics. Apr. 2003;111(4 Pt 2):e471-81. [pmid: 12671167].
122 Parchman ML, Noel PH, Lee S. Primary care attributes, health care system hassles, and chronic illness. Med Care. Nov. 2005;43(11):1123-9. [pmid: 16224306].
123 Parkerton PH, Smith DG, Straley HL. Primary care practice coordination versus physician continuity. Fam Med. Jan. 2004;36(1):15-21. [pmid: 14710324].
124 Pollack MM, Koch MA. Association of outcomes with organizational characteristics of neonatal intensive care units. Crit Care Med. Jun. 2003;31(6):1620-9. [pmid: 12794396].
125 Reid R, Haggerty J, McKendry R. Defusing the confusion: concepts and measures of continuity of healthcare., 2002 [Accessed: January 30, 2006]; Available from: http://www.chsrf.org/final_research/commissioned_research/programs/pdf/cr_contcare_e.pdf.
126 Shortell SM, Zimmerman JE, Rousseau DM, et al. The performance of intensive care units: does good management make a difference?. Med Care. May. 1994;32(5):508-25. [pmid: 8182978].
127 Sprague L. Disease management to population-based health: steps in the right direction? Washington, DC: National Health Policy Forum; 2003. Report No.: Issue Brief May 16 (No. 791).
128 Starfield B, Steinwachs D, Morris I, Bause G, Siebert S, Westin C. Concordance between medical records and observations regarding information on coordination of care. Med Care. Jul. 1979;17(7):758-66. [pmid: 313490].
129 Temkin-Greener H, Gross D, Kunitz SJ, Mukamel D. Measuring interdisciplinary team performance in a long-term care setting. Med Care. May. 2004;42(5):472-81. [pmid: 15083108].
130 Van de Ven AH, Delbecq AL, Koenig JR. Determinants of coordination modes within organizations. American Sociological Review. 1976;41(2):322-38.
131 Wehr E. Basic elements of care coordination for people with special health care needs in Medicaid managed care. February, 2000 [Accessed: November 16, 2006]; Available from: http://www.chcs.org/publications3960/publications_show.htm?doc_id=212943
132 Wenger NS, Young R. Quality indicators for continuity and coordination of care in vulnerable elders. Santa Monica, CA: RAND Health; 2004. Report No.: RAND report no. WR-176.
133 Donabedian A. The Definition of Quality and Approaches to its Assessment. Ann Arbor, MI: Health Administration Press, p. 23–24; 1980.
134 Joint Commission on Accreditation of Healthcare Organizations. 1997 Hospital Accreditation Standards. Oakbrook Terrace, IL: JCAHO.
135 Young GJ, Charns MP, Desai K, et al. Patterns of coordination and clinical outcomes: a study of surgical services. Health Serv Res. Dec. 1998;33(5 Pt 1):1211-36. [pmid: 9865218]. [pmcid: 1070314].
136 Alexander JA, Lichtenstein R, Jinnett K, Wells R, Zazzali J, Liu D. Cross-functional team processes and patient functional improvement. Health Serv Res. Oct. 2005;40(5 Pt 1):1335-55. [pmid: 16174137]. [pmcid: 1361204].
137 Safran DG, Miller W, Beckman H. Organizational dimensions of relationship-centered care. Theory, evidence, and practice. J Gen Intern Med. Jan. 2006;21(Suppl 1):S9-15. [pmid: 16405711].
138 Thompson JD. Organizations in action; social science bases of administrative theory. New York,: McGraw-Hill; 1967.
139 Sprague S, Cook DJ, Anderson D, O'Brien BJ. A systematic review of economic analyses of low-molecular-weight heparin for the treatment of venous thromboembolism. Thromb Res. 2003;112(4):193-201. [pmid: 14987911].
140 Swarztrauber K, Vickrey BG. Do neurologists and primary care physicians agree on the extent of specialty involvement of patients referred to neurologists?. J Gen Intern Med. Jun. 2004;19(6):654-61. [pmid: 15209604]. [pmcid: 1492387].
141 Charns MP, Schaefer MJ. Health care organizations, a model for management. Englewood Cliffs, N.J.: Prentice-Hall; 1983.
142 Glasgow RE, Whitesides H, Nelson CC, King DK. Use of the Patient Assessment of Chronic Illness Care (PACIC) with diabetic patients: relationship to patient characteristics, receipt of care, and self-management. Diabetes Care. Nov. 2005;28(11):2655-61. [pmid: 16249535].
143 Starfield BH, Simborg DW, Horn SD, Yourtee SA. Continuity and coordination in primary care: their achievement and utility. Med Care. Jul. 1976;14(7):625-36. [pmid: 940406].
144 Graham K, Timney CB, Bois C, Wedgerfield K. Continuity of care in addictions treatment: the role of advocacy and coordination in case management. Am J Drug Alcohol Abuse. Nov. 1995;21(4):433-51. [pmid: 8561096].
145 Stille CJ, Korobov N, Primack WA. Generalist-subspecialist communication about children with chronic conditions: an analysis of physician focus groups. Ambul Pediatr. May–Jun. 2003;3(3):147-53. [pmid: 12708892].
146 Mangione-Smith R, Schonlau M, Chan KS, et al. Measuring the effectiveness of a collaborative for quality improvement in pediatric asthma care: does implementing the chronic care model improve processes and outcomes of care?. Ambul Pediatr. Mar–Apr. 2005;5(2):75-82. [pmid: 15780018].
147 U.S. Department of Veterans Affairs. [Accessed: January 28, 2006]; Available from: http://www1.va.gov/opa.fact/telehealth.html
148 Weingarten SR, Henning JM, Badamgarav E, et al. Interventions used in disease management programmes for patients with chronic illness — which ones work? Meta-analysis of published reports. BMJ. 2002;325(7370):925-8. [pmid: 12399340]. [pmcid: 130055].
149 Wagner EH, Glasgow RE, Davis C, et al. Quality improvement in chronic illness care: a collaborative approach. Jt Comm J Qual Improv. Feb. 2001;27(2):63-80. [pmid: 11221012].
150 Schmitt MH. Collaboration improves the quality of care: methodological challenges and evidence from US health care research. J Interprof Care. Feb. 2001;15(1):47-66. [pmid: 11705070].
151 American Medical Association. Management of chronic disease (Report 11 of the Council on Scientific Affairs (A-04)). June 2004 [Accessed: January 28, 2006]; Available from: http://www.ama-assn.org/ama/pub/category/print/14428.html
152 Norris SL, Nichols PJ, Caspersen CJ, et al. The effectiveness of disease and case management for people with diabetes. A systematic review. Am J Prev Med. May. 2002;22(4 Suppl):15-38. [pmid: 11985933].
153 Henneman EA, Lee JL, Cohen JI. Collaboration: a concept analysis. J Adv Nurs. Jan. 1995;21(1):103-9. [pmid: 7897060].
154 Zillich AJ, Doucette WR, Carter BL, Kreiter CD. Development and initial validation of an instrument to measure physician-pharmacist collaboration from the physician perspective. Value Health. Jan–Feb. 2005;8(1):59-66. [pmid: 15841895].
155 Baggs JG, Schmitt MH. Collaboration between nurses and physicians. Image J Nurs Sch. Fall. 1988;20(3):145-9. [pmid: 3049311].
156 Weiss SJ, Davis HP. Validity and reliability of the Collaborative Practice Scales. Nurs Res. Sep–Oct. 1985;34(5):299-305. [pmid: 3850490].
157 Bronstein LR. A model for interdisciplinary collaboration. Soc Work. Jul. 2003;48(3):297-306. [pmid: 12899277].
158 Baggs JG, Schmitt MH. Nurses' and resident physicians' perceptions of the process of collaboration in an MICU. Res Nurs Health. Feb. 1997;20(1):71-80. [pmid: 9024479].
159 Baggs JG, Schmitt MH, Mushlin AI, Eldredge DH, Oakes D, Hutson AD. Nurse-physician collaboration and satisfaction with the decision-making process in three critical care units. Am J Crit Care. Sep. 1997;6(5):393-9. [pmid: 9283677].
160 Copnell B, Johnston L, Harrison D, et al. Doctors' and nurses' perceptions of interdisciplinary collaboration in the NICU, and the impact of a neonatal nurse practitioner model of practice. J Clin Nurs. Jan. 2004;13(1):105-13. [pmid: 14687300].
161 Hojat M, Fields SK, Veloski JJ, Griffiths M, Cohen MJ, Plumb JD. Psychometric properties of an attitude scale measuring physician-nurse collaboration. Eval Health Prof. Jun. 1999;22(2):208-20. [pmid: 10557856].
162 El Ansari W, Phillips CJ, Hammick M. Collaboration and partnerships: developing the evidence base. Health Soc Care Community. Jul. 2001;9(4):215-27. [pmid: 11560737].
163 Dougherty MB, Larson E. A review of instruments measuring nurse-physician collaboration. J Nurs Adm. May. 2005;35(5):244-53. [pmid: 15891488].
164 Baker DP, Gustafson S, Beaubien J, Salas E, Barach P. Medical teamwork and patient safety: the evidence-based relation. Literature Review. AHRQ Publication No. 05-0053, April 2005. Agency for Healthcare Research and Quality, Rockville, MD; 2005.
165 Burke CS, Salas E, Wilson-Donnelly K, Priest H. How to turn a team of experts into an expert medical team: guidance from the aviation and military communities. Qual Saf Health Care. Oct. 2004;13(Suppl 1):i96-104. [pmid: 15465963].
166 Campbell LJ, Cole KD. Geriatric assessment teams. Clin Geriatr Med. Feb. 1987;3(1):99-110. [pmid: 3545426].
167 Ilgen DR, Hollenbeck JR, Johnson M, Jundt D. Teams in organizations: from input-process-output models to IMOI models. Annu Rev Psychol. 2005;56:517-43. [pmid: 15709945].
168 Mickan SM. Evaluating the effectiveness of health care teams. Aust Health Rev. May 2. 2005;29(2):211-7. [pmid: 15865572].
169 Freed GL, Hudson EJ. Transitioning children with chronic diseases to adult care: current knowledge, practices, and directions. J Pediatr. Jun. 2006;148(6):824-7. [pmid: 16769396].
170 Saultz JW, Lochner J. Interpersonal continuity of care and care outcomes: a critical review. Ann Fam Med. Mar–Apr. 2005;3(2):159-66. [pmid: 15798043]. [pmcid: 1466859].
171 Saultz JW. Defining and measuring interpersonal continuity of care. Ann Fam Med. Sep–Oct. 2003;1(3):134-43. [pmid: 15043374]. [pmcid: 1466595].
172 Donaldson MS. Continuity of care: a reconceptualization. Med Care Res Rev. Sep. 2001;58(3):255-90. [pmid: 11523291].
173 Sparbel KJ, Anderson MA. Integrated literature review of continuity of care: Part 1, Conceptual issues. J Nurs Scholarsh. 2000;32(1):17-24. [pmid: 10819734].
174 Freeman GK, Olesen F, Hjortdahl P. Continuity of care: an essential element of modern general practice?. Fam Pract. Dec. 2003;20(6):623-7. [pmid: 14701883].
175 Adair CE, McDougall GM, Beckie A, et al. History and measurement of continuity of care in mental health services and evidence of its role in outcomes. Psychiatric Services. 2003;54(10):1351-6. [pmid: 14557520].
176 Rogers J, Curtis P. The concept and measurement of continuity in primary care. Am J Public Health. Feb. 1980;70(2):122-7. [pmid: 7352605]. [pmcid: 1619202].
177 Durbin J, Goering P, Streiner DL, Pink G. Continuity of care: validation of a new self-report measure for individuals using mental health services. J Behav Health Serv Res. Jul–Sep. 2004;31(3):279-96. [pmid: 15263867].
178 Fortney J, Sullivan G, Williams K, Jackson C, Morton SC, Koegel P. Measuring continuity of care for clients of public mental health systems. Health Services Research. 2003;38(4):1157-75. [pmid: 12968822]. [pmcid: 1360938].
179 Dolovich LR, Nair KM, Ciliska DK, et al. The Diabetes Continuity of Care Scale: the development and initial evaluation of a questionnaire that measures continuity of care from the patient perspective. Health and Social Care in the Community. 2004;12(6):475-87. [pmid: 15717895].
180 Ware NC, Tugenberg T, Dickey B. Ethnography and measurement in mental health: qualitative validation of a measure of continuity of care (CONNECT). Qualitative Health Research. 2003;13(10):1393-406. [pmid: 14658353].
181 Haggerty J, Reid R, McGrail K, McKendry R. Here There and All Over the Place: Defining and Measuring Continuity of Health Care. British Columbia, Canada: British Columbia: Center for Health Services and Policy Research, Health Policy Research Unit, University of British Columbia; 2001.
182 Gulliford M, Naithani S, Morgan M. What is ‘continuity of care’?. J Health Serv Res Policy. Oct. 2006;11(4):248-50. [pmid: 17018200].
183 Haggerty JL, Reid RJ, Freeman GK, Starfield BH, Adair CE, McKendry R. Continuity of care: a multidisciplinary review. BMJ. Nov 22. 2003;327(7425):1219-21. [pmid: 14630762]. [pmcid: 274066].
184 Disease Management Association of America. DMAA Definition of Disease Management. [Accessed: January 26, 2007]; Available from: http://www.dmaa.org/dm_definition.asp
185 Case Management Society of America. Definition of case management. [Accessed: January 28, 2006]; Available from: http://www.cmsa.org/ABOUTUS/DefinitionofCaseManagement/tabid/104/Default.aspx
186 Wagner EH, Austin BT, Davis C, Hindmarsh M, Schaefer J, Bonomi A. Improving chronic illness care: translating evidence into action. Health Aff (Millwood). Nov–Dec. 2001;20(6):64-78. [pmid: 11816692].
187 Wagner EH, Davis C, Schaefer J, Von Korff M, Austin B. A survey of leading chronic disease management programs: are they consistent with the literature?. Managed Care Quarterly. 1999;7(3):56-66. [pmid: 10620960].
188 Cretin S, Shortell SM, Keeler EB. An evaluation of collaborative interventions to improve chronic illness care. Framework and study design. Eval Rev. Feb. 2004;28(1):28-51. [pmid: 14750290].
189 Bonomi AE, Wagner EH, Glasgow RE, VonKorff M. Assessment of chronic illness care (ACIC): a practical tool to measure quality improvement. Health Serv Res. Jun. 2002;37(3):791-820. [pmid: 12132606]. [pmcid: 1434662].
190 Barr VJ, Robinson S, Marin-Link B, et al. The expanded Chronic Care Model: an integration of concepts and strategies from population health promotion and the Chronic Care Model. Hosp Q. 2003;7(1):73-82. [pmid: 14674182].
191 World Health Organization, Health Care for Chronic Conditions Team. Innovative Care for Chronic Conditions: Building Blocks for Action. 2002 [Accessed: January 24, 2006]; Available from: http://www.who.int/chp/knowledge/publications/icccglobalreport.pdf
192 Dohan D, Schrag D. Using navigators to improve care of underserved patients: current practices and approaches. Cancer. Aug 15. 2005;104(4):848-55. [pmid: 16010658].
193 Battaglia TA, Roloff K, Posner MA, Freund KM. Improving follow-up to abnormal breast cancer screening in an urban population: a patient navigation intervention. Cancer. Jan 15. 2007;109(2 Suppl):359-67. [pmid: 17123275].
194 Fillion L, de Serres M, Lapointe-Goupil R, et al. Implementing the role of patient-navigator nurse at a university hospital centre. Can Oncol Nurs J. 2006 Spring;16(1):11–7, 5–0.
195 Steinberg ML, Fremont A, Khan DC, et al. Lay patient navigator program implementation for equal access to cancer care and clinical trials: essential steps and initial challenges. Cancer. Dec 1. 2006;107(11):2669-77. [pmid: 17078056].
196 Lemak CH, Johnson C, Goodrick EE. Collaboration to improve services for the uninsured: exploring the concept of health navigators as interorganizational integrators. Health Care Manage Rev. Jul–Sep. 2004;29(3):196-206. [pmid: 15357230].
197 National Cancer Institute. NCI's Patient Navigator Research Program: Fact Sheet: What exactly is a patient navigator? [Accessed: January 25, 2007]; Available from: http://www.cancer.gov/cancertopics/factsheet/PatientNavigator
198 Southern California Evidence Based Practice Center - RAND. Health Information Technology Costs & Benefits Database Project. [Accessed: January 24, 2007]; Available from: http://healthit.ahrq.gov/tools/rand
199 Shekelle P, Morton S, Keeler E. Costs and Benefits of Health Information Technology. Evidence Report/Technology Assessment No. 132. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-02-0003.) Rockville, MD: Agency for Healthcare Research and Quality; 2006 April. Report No.: AHRQ Publication No. 06-E006.
200 Hersh W, Hickam D, Severance S, Dana T, Krages K, Helfand M. Telemedicine for the Medicare Population: Update. Evidence Report/Technology Assessment No. 131 (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-02-0024) Rockville, MD: Agency for Healthcare Research and Quality; 2006 February. Report No.: AHRQ Publication No. 06-E007.
201 Park EJ. Telehealth technology in case/disease management. Lippincotts Case Manag. May–Jun. 2006;11(3):175-82. [pmid: 16738470].
202 McDonald K. p. Personal correspondence with Randall Brown based on work presented at AcademyHealth June 2006 Annual meeting.
203 Chheda N. Electronic Medical Records and Continuity of Care Records - The Utility Theory. Application of Information Technology and Economics. November 2005 [Accessed: February 10, 2007]; Available from: http://www.emrworld.net/emr-research/articles/emr-ccr.pdf
204 Medical Records Institute. Continuity of Care Record (CCR). [Accessed: February 10, 2007]; Available from: http://www.medrecinst.com/pages/about.asp?id=54
205 Counsell SR, Callahan CM, Buttar AB, Clark DO, Frank KI. Geriatric Resources for Assessment and Care of Elders (GRACE): a new model of primary care for low-income seniors. J Am Geriatr Soc. Jul. 2006;54(7):1136-41. [pmid: 16866688].
206 Shojania KG, Bero LA. Taking advantage of the explosion of systematic reviews: an efficient MEDLINE search strategy. Eff Clin Pract. Jul–Aug. 2001;4(4):157-62. [pmid: 11525102].
207 Drug Effectiveness Review Project. Quality assessment methods for drug class reviews for the drug effectiveness review project. [Accessed: May, 2005]; Available from: http://www.ohsu.edu/drugeffectiveness/methods/QualityAssessmentDERP.pdf
208 Bower P, Sibbald B. On-site mental health workers in primary care: effects on professional practice. Cochrane Database Syst Rev. 2000(3):CD000532.
209 Craven MA, Bland R. Better practices in collaborative mental health care: an analysis of the evidence base. Can J Psychiatry. May. 2006;51(6 Suppl 1):7S-72S. [pmid: 16786824].
210 Gunn J, Diggens J, Hegarty K, Blashki G. A systematic review of complex system interventions designed to increase recovery from depression in primary care. BMC Health Serv Res. 2006;6:88. [pmid: 16842629]. [pmcid: 1559684].
211 Latimer EA. Economic impacts of assertive community treatment: a review of the literature. Can J Psychiatry. Jun. 1999;44(5):443-54. [pmid: 10389605].
212 Marshall M, Lockwood A. Assertive community treatment for people with severe mental disorders. Cochrane Database Syst Rev. 2000(2):CD001089.
213 Simmonds S, Coid J, Joseph P, Marriott S, Tyrer P. Community mental health team management in severe mental illness: a systematic review. Br J Psychiatry. Jun. 2001;178:497-502. discussion 3–5. [pmid: 11388964].
214 Wadhwa S, Lavizzo-Mourey R. Tools, methods, and strategies. Do innovative models of health care delivery improve quality of care for selected vulnerable populations? A systematic review. Jt Comm J Qual Improv. Aug. 1999;25(8):408-33. [pmid: 10434191].
215 Ziguras SJ, Stuart GW. A meta-analysis of the effectiveness of mental health case management over 20 years. Psychiatric Services. 2000;51(11):1410-21. [pmid: 11058189].
216 Holland R, Battersby J, Harvey I, Lenaghan E, Smith J, Hay L. Systematic review of multidisciplinary interventions in heart failure. Heart. Jul. 2005;91(7):899-906. [pmid: 15958358]. [pmcid: 1769009].
217 McAlister FA, Stewart S, Ferrua S, McMurray JJ. Multidisciplinary strategies for the management of heart failure patients at high risk for admission: a systematic review of randomized trials. J Am Coll Cardiol. Aug 18. 2004;44(4):810-9. [pmid: 15312864].
218 McAlister FA, Lawson FM, Teo KK, Armstrong PW. Randomised trials of secondary prevention programmes in coronary heart disease: systematic review. BMJ. Oct 27. 2001;323(7319):957-62. [pmid: 11679383]. [pmcid: 58658].
219 Langhorne P, Taylor G, Murray G, et al. Early supported discharge services for stroke patients: a meta-analysis of individual patients' data. Lancet. Feb 5. 2005;365(9458):501-6. [pmid: 15705460].
220 Higginson IJ, Finlay IG, Goodwin DM, et al. Is there evidence that palliative care teams alter end-of-life experiences of patients and their caregivers?. J Pain Symptom Manage. Feb. 2003;25(2):150-68. [pmid: 12590031].
221 Lemieux-Charles L, McGuire WL. What do we know about health care team effectiveness? A review of the literature. Med Care Res Rev. Jun. 2006;63(3):263-300. [pmid: 16651394].
222 Richards S, Coast J. Interventions to improve access to health and social care after discharge from hospital: a systematic review. J Health Serv Res Policy. Jul. 2003;8(3):171-9. [pmid: 12869344].
223 Neumeyer-Gromen A, Lampert T, Stark K, Kallischnigg G. Disease management programs for depression: a systematic review and meta-analysis of randomized controlled trials. Medical Care. 2004;42(12):1211-21. [pmid: 15550801].
224 Gohler A, Januzzi JL, Worrell SS, et al. A systematic meta-analysis of the efficacy and heterogeneity of disease management programs in congestive heart failure. J Card Fail. Sep. 2006;12(7):554-67. [pmid: 16952790].
225 Roccaforte R, Demers C, Baldassarre F, Teo KK, Yusuf S. Effectiveness of comprehensive disease management programmes in improving clinical outcomes in heart failure patients. A meta-analysis. Eur J Heart Fail. Dec. 2005;7(7):1133-44. [pmid: 16198629].
226 Whellan DJ, Hasselblad V, Peterson E, O'Connor CM, Schulman KA. Metaanalysis and review of heart failure disease management randomized controlled clinical trials. Am Heart J. Apr. 2005;149(4):722-9. [pmid: 15990759].
227 Yu DS, Thompson DR, Lee DT. Disease management programmes for older people with heart failure: crucial characteristics which improve post-discharge outcomes. Eur Heart J. Mar. 2006;27(5):596-612. [pmid: 16299021].
228 Knight K, Badamgarav E, Henning JM, et al. A systematic review of diabetes disease management programs. Am J Manag Care. Apr. 2005;11(4):242-50. [pmid: 15839184].
229 Krause DS. Economic effectiveness of disease management programs: a meta-analysis. Dis Manag. Apr. 2005;8(2):114-34. [pmid: 15815160].
230 Badamgarav E, Croft JD Jr, Hohlbauch A, et al. Effects of disease management programs on functional status of patients with rheumatoid arthritis. Arthritis Rheum. Jun 15. 2003;49(3):377-87. [pmid: 12794794].
231 Gorey KM, Leslie DR, Morris T, Carruthers WV, John L, Chacko J. Effectiveness of case management with severely and persistently mentally ill people. Community Mental Health Journal. 1998;34(3):241-50. [pmid: 9607161].
232 Marshall M, Gray A, Lockwood A, Green R. Case management for people with severe mental disorders. The Cochrane Database of Systematic Reviews. 1998(2):Art. No: CD000050.
233 Windham BG, Bennett RG, Gottlieb S. Care management interventions for older patients with congestive heart failure. American Journal of Managed Care. 2003;9(6):447-61. [pmid: 12816174].
234 Payne S, Kerr C, Hawker S, Hardey M, Powell J. The communication of information about older people between health and social care practitioners. Age Ageing. Mar. 2002;31(2):107-17. [pmid: 12033184].
235 Jeffery DP, Ley A, McLaren S, Siegfried N. Psychosocial treatment programmes for people with both severe mental illness and substance misuse. The Cochrane Database of Systematic Reviews. 2000(2):Art. No: CD001088.
236 Briggs CJ, Garner P. Strategies for integrating primary health services in middle- and low-income countries at the point of delivery. Cochrane Database Syst Rev. 2006(2):CD003318.
237 Johri M, Beland F, Bergman H. International experiments in integrated care for the elderly: a synthesis of the evidence. Int J Geriatr Psychiatry. Mar. 2003;18(3):222-35. [pmid: 12642892].
238 Reeves S. A systematic review of the effects of interprofessional education on staff involved in the care of adults with mental health problems. J Psychiatr Ment Health Nurs. Dec. 2001;8(6):533-42. [pmid: 11842481].
239 Irajpour A, Norman I, Griffiths P. Interprofessional education to improve pain management. Br J Community Nurs. Jan. 2006;11(1):29-32. [pmid: 16493295].
240 Zwarenstein M, Reeves S, Barr H, Hammick M, Koppel I, Atkins J. Interprofessional education: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2001(1):CD002213.
241 Philbin EF. Comprehensive multidisciplinary programs for the management of patients with congestive heart failure. J Gen Intern Med. Feb. 1999;14(2):130-5. [pmid: 10051785].
242 Greenhalgh PM. Shared care for diabetes. A systematic review. Occas Pap R Coll Gen Pract. 1994 Oct(67):i–viii, 1–35.
243 Ram FS, Jones A, Fay JK. Primary care based clinics for asthma. Cochrane Database Syst Rev. 2005(3):CD003533.
244 Grimshaw JM, Winkens RA, Shirran L, et al. Interventions to improve outpatient referrals from primary care to secondary care. Cochrane Database Syst Rev. 2005(3):CD005471.
245 Gruen RL, Weeramanthri TS, Knight SE, Bailie RS. Specialist outreach clinics in primary care and rural hospital settings. Cochrane Database Syst Rev. 2003(4):Art. No: CD003798.pub2.
246 McCusker J, Verdon J. Do geriatric interventions reduce emergency department visits? A systematic review. J Gerontol A Biol Sci Med Sci. Jan. 2006;61(1):53-62. [pmid: 16456194].
247 Mitchell G, Del Mar C, Francis D. Does primary medical practitioner involvement with a specialist team improve patient outcomes? A systematic review. Br J Gen Pract. Nov. 2002;52(484):934-9. [pmid: 12434964]. [pmcid: 1314447].
248 Zwarenstein M, Bryant W. Interventions to promote collaboration between nurses and doctors. Cochrane Database Syst Rev. 2000(2):Art. No: CD000072.
249 Harding R, Karus D, Easterbrook P, Raveis VH, Higginson IJ, Marconi K. Does palliative care improve outcomes for patients with HIV/AIDS? A systematic review of the evidence. Sex Transm Infect. Feb. 2005;81(1):5-14. [pmid: 15681714]. [pmcid: 1763726].
250 Duffy JR, Hoskins LM, Chen MC. Nonpharmacological strategies for improving heart failure outcomes in the community: a systematic review. J Nurs Care Qual. Oct–Dec. 2004;19(4):349-60. [pmid: 15535541].
251 Dennis CL. Preventing postpartum depression part II: A critical review of nonbiological interventions. Can J Psychiatry. Aug. 2004;49(8):526-38. [pmid: 15453102].
252 Crawford MJ, de Jonge E, Freeman GK, Weaver T. Providing continuity of care for people with severe mental illness- a narrative review. Soc Psychiatry Psychiatr Epidemiol. Apr. 2004;39(4):265-72. [pmid: 15085327].
253 Mitchell GK. How well do general practitioners deliver palliative care? A systematic review. Palliat Med. Nov. 2002;16(6):457-64. [pmid: 12465692].
254 Renders CM, Valk GD, Griffin S, Wagner EH, Eijk JT, Assendelft WJ. Interventions to improve the management of diabetes mellitus in primary care, outpatient and community settings. Cochrane Database Syst Rev. 2001(1):CD001481.
255 Draper B. The effectiveness of old age psychiatry services. Int J Geriatr Psychiatry. Aug. 2000;15(8):687-703. [pmid: 10960881].
256 Druss BG, von Esenwein SA. Improving general medical care for persons with mental and addictive disorders: systematic review. Gen Hosp Psychiatry. Mar–Apr. 2006;28(2):145-53. [pmid: 16516065].
257 Handford CD, Tynan AM, Rackal JM, Glazier RH. Setting and organization of care for persons living with HIV/AIDS. Cochrane Database Syst Rev. 2006;3:CD004348.
258 Heideman J, van Rijswijk E, van Lin N, et al. Interventions to improve management of anxiety disorders in general practice: a systematic review. Br J Gen Pract. Nov. 2005;55(520):867-74. [pmid: 16282004]. [pmcid: 1570770].
259 Hwang SW, Tolomiczenko G, Kouyoumdjian FG, Garner RE. Interventions to improve the health of the homeless: a systematic review. Am J Prev Med. Nov. 2005;29(4):311-9. [pmid: 16242595].
260 Gonseth J, Guallar-Castillon P, Banegas JR, Rodriguez-Artalejo F. The effectiveness of disease management programmes in reducing hospital re-admission in older patients with heart failure: a systematic review and meta-analysis of published reports. Eur Heart J. Sep. 2004;25(18):1570-95. [pmid: 15351157].
261 Ofman JJ, Badamgarav E, Henning JM, et al. Does disease management improve clinical and economic outcomes in patients with chronic diseases? A systematic review. Am J Med. Aug 1. 2004;117(3):182-92. [pmid: 15300966].
262 Ara S. A literature review of cardiovascular disease management programs in managed care populations. J Manag Care Pharm. Jul–Aug. 2004;10(4):326-44. [pmid: 15298531].
263 Badamgarav E, Weingarten SR, Henning JM, et al. Effectiveness of disease management programs in depression: a systematic review. American Journal of Psychiatry. 2003;160(12):2080-90. [pmid: 14638573].
264 Pearson SA, Ross-Degnan D, Payson A, Soumerai SB. Changing medication use in managed care: a critical review of the available evidence. Am J Manag Care. Nov. 2003;9(11):715-31. [pmid: 14626470].
265 Sin DD, McAlister FA, Man SF, Anthonisen NR. Contemporary management of chronic obstructive pulmonary disease: scientific review. JAMA. Nov 5. 2003;290(17):2301-12. [pmid: 14600189].
266 Bijl D, van Marwijk HW, de Haan M, van Tilburg W, Beekman AJ. Effectiveness of disease management programmes for recognition, diagnosis and treatment of depression in primary care. Eur J Gen Pract. Mar. 2004;10(1):6-12. [pmid: 15060475].
267 Andrews JO, Felton G, Wewers ME, Heath J. Use of community health workers in research with ethnic minority women. J Nurs Scholarsh. 2004;36(4):358-65. [pmid: 15636417].
268 Halcomb E, Davidson P, Daly J, Yallop J, Tofler G. Australian nurses in general practice based heart failure management: implications for innovative collaborative practice. Eur J Cardiovasc Nurs. Jul. 2004;3(2):135-47. [pmid: 15234318].
269 Gilbody S, Whitty P, Grimshaw J, Thomas R. Educational and organizational interventions to improve the management of depression in primary care: a systematic review. JAMA. Jun 18. 2003;289(23):3145-51. [pmid: 12813120].
270 Phillips CO, Wright SM, Kern DE, Singa RM, Shepperd S, Rubin HR. Comprehensive discharge planning with postdischarge support for older patients with congestive heart failure: a meta-analysis. JAMA. 2004;291(11):1358-67. [pmid: 15026403].
271 Ingersoll S, Valente SM, Roper J. Nurse care coordination for diabetes: a literature review and synthesis. J Nurs Care Qual. Jul–Sep. 2005;20(3):208-14. [pmid: 15965384].
272 Vergouwen AC, Bakker A, Katon WJ, Verheij TJ, Koerselman F. Improving adherence to antidepressants: a systematic review of interventions. J Clin Psychiatry. Dec. 2003;64(12):1415-20. [pmid: 14728101].
273 Adli M, Bauer M, Rush AJ. Algorithms and collaborative-care systems for depression: are they effective and why? A systematic review. Biol Psychiatry. Jun 1. 2006;59(11):1029-38. [pmid: 16769294].
274 Griffin S. Diabetes care in general practice: meta-analysis of randomised control trials. BMJ. Aug 8. 1998;317(7155):390-6. [pmid: 9694757]. [pmcid: 28634].
275 Aminzadeh F, Dalziel WB. Older adults in the emergency department: a systematic review of patterns of use, adverse outcomes, and effectiveness of interventions. Ann Emerg Med. Mar. 2002;39(3):238-47. [pmid: 11867975].
276 Campbell NC, Ritchie LD, Cassidy J, Little J. Systematic review of cancer treatment programmes in remote and rural areas. Br J Cancer. Jun. 1999;80(8):1275-80. [pmid: 10376984].
277 Eastwood AJ, Sheldon TA. Organisation of asthma care: what difference does it make? A systematic review of the literature. Qual Health Care. Sep. 1996;5(3):134-43. [pmid: 10161527]. [pmcid: 1055397].
278 Harvey EL, Glenny A, Kirk SF, Summerbell CD. Improving health professionals' management and the organisation of care for overweight and obese people. Cochrane Database Syst Rev. 2001(2):CD000984.
279 Hastings SN, Heflin MT. A systematic review of interventions to improve outcomes for elders discharged from the emergency department. Acad Emerg Med. Oct. 2005;12(10):978-86. [pmid: 16204142].
280 Newcomer R, Harrington C, Kane R. Challenges and accomplishments of the second-generation social health maintenance organization. Gerontologist. Dec. 2002;42(6):843-52. [pmid: 12451166].
281 Wolff JL, Boult C. Moving beyond round pegs and square holes: restructuring Medicare to improve chronic care. Ann Intern Med. Sep 20. 2005;143(6):439-45. [pmid: 16172442].
282 Gold M, Lake T, Black WE, Smith M. Challenges In Improving Care For High-Risk Seniors In Medicare. Health Aff (Millwood). 2005 Apr 26.
283 Sofaer S, Kreling B, Carmel M. Coordination of care for persons with disabilities enrolled in Medicaid managed care: a conceptual framework to guide the development of measures. 2000 [Accessed: January 30, 2005]; Available from: http://aspe.hhs.gov/daltcp/reports/carecoor.htm
284 Beaudin CL, Lammers JC, Pedroja AT. Patient perceptions of coordinated care: the importance of organized communication in hospitals. Journal for Healthcare Quality. 1999;21(5):18-23. [pmid: 10620880].
285 Bodenheimer T, Lorig K, Holman H, Grumbach K. Patient self-management of chronic disease in primary care. JAMA. Nov 20. 2002;288(19):2469-75. [pmid: 12435261].
286 Fronstin P, Collins SR, The Commonwealth Fund. Early experience with high-deductible and consumer-driven health plans: findings from the EBRI/Commonwealth Fund Consumerism in Health Care Survey: Employee Benefit Research Institute (EBRI); 2005 Dec. Report No.: EBRI Issue Brief (288).
287 Andersen RM. Revisiting the behavioral model and access to medical care: does it matter?. J Health Soc Behav. Mar. 1995;36(1):1-10. [pmid: 7738325].
288 Dudley RA, Frolich A, Robinowitz DL, Talavera JA, Broadhead P, Luft HS. Strategies to support quality-based purchasing: a review of the evidence. Technical Review 10. (Prepared by the Stanford-University of California San Francisco Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04-0057. Rockville, MD: Agency for Healthcare Research and Quality; 2004.
289 McDonald K, Graham I, Grimshaw J. Chapter 3: Toward a Theoretic Basis for Quality Improvement Interventions. In: Shojania K, McDonald K, Wachter R, Owens D, editors. Closing The Quality Gap: A Critical Analysis of Quality Improvement Strategies, Volume 1—Series Overview and Methodology Technical Review 9 (Contract No 290-02-0017 to the Stanford University-UCSF Evidence-based Practices Center) AHRQ Publication No 04-0051-1. Rockville, MD: Agency for Healthcare Research and Quality; August 2004.
290 Hoenig H, Duncan PW, Horner RD, et al. Structure, process, and outcomes in stroke rehabilitation. Med Care. Nov. 2002;40(11):1036-47. [pmid: 12409849].
291 Gershon RR, Stone PW, Bakken S, Larson E. Measurement of organizational culture and climate in healthcare. J Nurs Adm. Jan. 2004;34(1):33-40. [pmid: 14737033].
292 Mitchell PH, Shortell SM. Adverse outcomes and variations in organization of care delivery. Med Care. Nov. 1997;35(11 Suppl):NS19-32. [pmid: 9366876].
293 Scott T, Mannion R, Davies H, Marshall M. The quantitative measurement of organizational culture in health care: a review of the available instruments. Health Serv Res. Jun. 2003;38(3):923-45. [pmid: 12822919]. [pmcid: 1360923].
294 Bower P, Campbell S, Bojke C, Sibbald B. Team structure, team climate and the quality of care in primary care: an observational study. Qual Saf Health Care. Aug. 2003;12(4):273-9. [pmid: 12897360]. [pmcid: 1743743].
295 Cashman S, Reidy P, Cody K, Lemay C. Developing and measuring progress toward collaborative, integrated, interdisciplinary health care teams. J Interprof Care. May. 2004;18(2):183-96. [pmid: 15203676].
296 Shortell SM, Marsteller JA, Lin M, et al. The role of perceived team effectiveness in improving chronic illness care. Med Care. Nov. 2004;42(11):1040-8. [pmid: 15586830].
297 Sicotte C, Beland F. The effect of medical work groups on hospital resource use. Health Serv Manage Res. Aug. 2001;14(3):165-80. [pmid: 11507811].
298 Zwarenstein M, Reeves S. Working together but apart: barriers and routes to nurse—physician collaboration. Jt Comm J Qual Improv. 2002 May;28(5):242–7, 09.
299 Stille CJ, Primack WA, Savageau JA. Generalist-subspecialist communication for children with chronic conditions: a regional physician survey. Pediatrics. Dec. 2003;112(6 Pt 1):1314-20. [pmid: 14654603].
300 Zillich AJ, McDonough RP, Carter BL, Doucette WR. Influential characteristics of physician/pharmacist collaborative relationships. Ann Pharmacother. May. 2004;38(5):764-70. [pmid: 15031418].
301 Bodenheimer T, Wang MC, Rundall TG, et al. What are the facilitators and barriers in physician organizations' use of care management processes?. Jt Comm J Qual Saf. Sep. 2004;30(9):505-14. [pmid: 15469128].
302 Donabedian A. The criteria and standards of quality. Ann Arbor, Mich.: Health Administration Press; 1982.
303 Donabedian A. Evaluating the quality of medical care. 1966. Milbank Q. 2005;83(4):691-729. [pmid: 16279964].
304 Nadler D, Tushman M. Strategic Organization Design. Glenview, Illinois and London, England: Scott, Foresman and Company; 1988.
305 March JG, Simon HA. Organizations. New York, NY: Wiley; 1958.
306 Argote L. Input uncertainty and organizational coordination in hospital emergency units. Adm Sci Q. Sep. 1982;27(3):420-34. [pmid: 10256878].
307 Shojania KG, Duncan BW, McDonald KM, Wachter RM, Markowitz AJ. Making health care safer: a critical analysis of patient safety practices. Evid Rep Technol Assess (Summ). 2001(43):i–x, 1–668.
308 Xiao Y, Hunter WA, Mackenzie CF, Jefferies NJ, Horst RL, Group atL. Task complexity in emergency medical care and its implications for team coordination. Human Factors. 1996;38(4):636–45.
309 Young GJ, Charns MP, Daley J, Forbes MG, Henderson W, Khuri SF. Best practices for managing surgical services: the role of coordination. Health Care Manage Rev. Fall. 1997;22(4):72-81. [pmid: 9358262].
310 Pogach L, Charns MP, Wrobel JS, et al. Impact of policies and performance measurement on development of organizational coordinating strategies for chronic care delivery. Am J Manag Care. Feb. 2004;10(2 Pt 2):171-80. [pmid: 15005510].
311 Sicotte C, Pineault R, Lambert J. Medical team interdependence as a determinant of use of clinical resources. Health Serv Res. Dec. 1993;28(5):599-621. [pmid: 8270423]. [pmcid: 1069966].
312 Wrobel JS, Charns MP, Diehr P, et al. The relationship between provider coordination and diabetes-related foot outcomes. Diabetes Care. Nov. 2003;26(11):3042-7. [pmid: 14578237].
313 Gittell JH, Fairfield KM, Bierbaum B, et al. Impact of relational coordination on quality of care, postoperative pain and functioning, and length of stay: a nine-hospital study of surgical patients. Med Care. Aug. 2000;38(8):807-19. [pmid: 10929993].
314 Baggs JG, Ryan SA, Phelps CE, Richeson JF, Johnson JE. The association between interdisciplinary collaboration and patient outcomes in a medical intensive care unit. Heart Lung. Jan. 1992;21(1):18-24. [pmid: 1735653].
315 Baggs JG. Development of an instrument to measure collaboration and satisfaction about care decisions. J Adv Nurs. Jul. 1994;20(1):176-82. [pmid: 7930118].
316 Cheng EM, Siderowf A, Swarztrauber K, Eisa M, Lee M, Vickrey BG. Development of quality of care indicators for Parkinson's disease. Mov Disord. Feb. 2004;19(2):136-50. [pmid: 14978668].
317 Boyd CM, Darer J, Boult C, Fried LP, Boult L, Wu AW. Clinical practice guidelines and quality of care for older patients with multiple comorbid diseases: implications for pay for performance. JAMA. Aug 10. 2005;294(6):716-24. [pmid: 16091574].
318 Coleman EA, Mahoney E, Parry C. Assessing the quality of preparation for posthospital care from the patient's perspective: the care transitions measure. Med Care. Mar. 2005;43(3):246-55. [pmid: 15725981].
319 Baggs JG, Ryan SA. ICU nurse-physician collaboration & nursing satisfaction. Nurs Econ. Nov–Dec. 1990;8(6):386-92. [pmid: 2267027].
320 Grimmer K, Moss J. The development, validity and application of a new instrument to assess the quality of discharge planning activities from the community perspective. Int J Qual Health Care. Apr. 2001;13(2):109-16. [pmid: 11430660].
321 Morita T, Hirai K, Sakaguchi Y, Maeyama E, Tsuneto S, Shima Y. Measuring the quality of structure and process in end-of-life care from the bereaved family perspective. J Pain Symptom Manage. Jun. 2004;27(6):492-501. [pmid: 15165647].
322 Radwin L, Alster K, Rubin KM. Development and testing of the Oncology Patients' Perceptions of the Quality of Nursing Care Scale. Oncol Nurs Forum. Mar–Apr. 2003;30(2):283-90. [pmid: 12692662].
323 Safran DG, Kosinski M, Tarlov AR, et al. The Primary Care Assessment Survey: tests of data quality and measurement performance. Med Care. May. 1998;36(5):728-39. [pmid: 9596063].
324 Shortell SM, Rousseau DM, Gillies RR, Devers KJ, Simons TL. Organizational assessment in intensive care units (ICUs): construct development, reliability, and validity of the ICU nurse-physician questionnaire. Med Care. Aug. 1991;29(8):709-26. [pmid: 1875739].
325 Shojania KG, McDonald K, Wachter R, Owens D. Closing the quality gap: a critical analysis of quality improvement strategies, Volume 1—Series overview and methodology. Rockville, MD: Agency for Healthcare Research and Quality; 2004. Report No.: 1587631563 (v. 1 & 2); 1587632055 (v. 3).
326 The Commonwealth Fund. The Commonwealth Fund Survey of Public Views of the U.S. Health Care System, 2006. [Accessed: February 10, 2007]; Available from: http://www.cmwf.org/surveys/surveys_show.htm?doc_id=394593
327 The Commonwealth Fund. 2003 National Survey of Physicians and Quality of Care. [Accessed: February 10, 2007]; Available from: http://www.cmwf.org/surveys/surveys_show.htm?doc_id=278869
328 Campion EW. A symptom of discontent. N Engl J Med. Jan 18. 2001;344(3):223-5. [pmid: 11172147].
329 Designing theoretically-informed implementation interventions. Implement Sci. 2006;1:4.
330 Bhattacharyya O, Reeves S, Garfinkel S, Zwarenstein M. Designing theoretically-informed implementation interventions: fine in theory, but evidence of effectiveness in practice is needed. Implement Sci. 2006;1:5. [pmid: 16722583]. [pmcid: 1436014].
331 Matlow AG, Wright JG, Zimmerman B, Thomson K, Valente M. How can the principles of complexity science be applied to improve the coordination of care for complex pediatric patients?. Qual Saf Health Care. Apr. 2006;15(2):85-8. [pmid: 16585105]. [pmcid: 2464825].