# Acknowledgments

We thank Marilyn Tinsley at the Stanford University Lane Library for her help with the literature searches; Juan Carlos Montoy for assistance with thoughtful background research during the scope setting stage; our AHRQ colleagues David Atkins, M.D., Kenneth Fink, M.D. (previously at AHRQ), Susan Norris, M.D. (previously at AHRQ) and Marian James, Ph.D. for their guidance in determining the appropriate scope for this undertaking and their comments on earlier drafts of this report; and Merrick Zwarenstein, M.B., B.Ch., M.Sc. and James L. Zazzali, Ph.D. for guidance and thoughtful discussions on the definitions and conceptual frameworks chapters. We also acknowledge with much gratitude our expert advisors and peer reviewers, who are listed in Appendix D *. Ms. Sundaram and Dr. Owens were supported by the Department of Veterans Affairs. Dr. Kraft was supported by the Palo Alto Medical Research Institute.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/caregaptp.htm