# Conclusions

This Report describes definitions, ongoing programs, systematic reviews of interventions, and conceptual frameworks related to care coordination. The field of care coordination may be thought of narrowly or broadly. Based on discussions with decisionmakers with diverse views of the field, we decided that an important first step in building an evidence base related to care coordination required an overview approach instead of a targeted literature review of primary studies representing only a slice of the full picture. For example, some decisionmakers are particularly interested in the role of self-management in coordinating and improving health care, while others are interested in specific approaches such as disease management. All agree, however, that care coordination needs to be defined in order to assemble pertinent evidence, that a critical analysis of evidence from systematic reviews related to care coordination would reflect the IOM's categorization of care coordination as a cross-cutting priority applicable to many health conditions and situations, and that more conceptual thinking could help guide the design and evaluation of care coordination programs and interventions. Our goal was to address these common interests, summarize findings of relevance now to both service level and system level decisionmakers, and recommend future research resulting from our work.

## Improving Care Coordination

Our findings highlight the need for reaching consensus on definitions, conceptual models, and outcome measures related to care coordination and the necessity of continued research to evaluate the value of different coordination efforts. While the research community responds to these needs, patients and providers recognize that improved coordination is an immediate and urgent problem. The 2006 Commonwealth Fund survey reported that 92% of patients felt that it was “somewhat” or “very important” to have one doctor, or one place, responsible for primary care and coordinating care and 96% percent of patients said it was “somewhat” or “very important” that care from different doctors be well coordinated. ^326^ Physicians surveyed by the Commonwealth Fund in 2003, indicated that patient medical records, tests, or other relevant clinical information were not available at the time of scheduled patient visits 72% of the time and only 34% of physicians reported receiving timely information about referrals. ^327^ How does this report inform the patients, providers, and system level decisionmakers in today's healthcare system?

We found that care coordination interventions improved important patient outcomes in different diseases across a broad spectrum of clinical settings. Systematic reviews provided evidence of benefit with multidisciplinary teams (including those involved in assertive community treatment, collaborative care, shared primary-specialty care and other arrangements), case management, and disease management. Multidisciplinary team interventions have been shown to reduce mortality and dependency in stroke patients; reduce mortality and hospital admissions in heart failure patients; improve service continuity for severely mentally ill patient; and reduce symptoms for terminally ill patients. Some evidence suggests that a deliberate effort to coordinate among team members (e.g., regular meetings) is a determinant of improved outcomes. ^219^ Case management as a care coordination strategy appears to improve patient outcomes for patients who have mental health problems, heart failure or diabetes. Close patient monitoring was identified as an important component in two reviews. ^233,^ ^269^ Disease management programs with coordination elements also appear to be effective in improving patient outcomes, especially for patients with depression or diabetes. While these and other care coordination interventions have been reported in systematic reviews covering other coordination challenges (e.g., transitions of care, other diseases, and specific patient populations such as the elderly or homeless people), there is insufficient evidence to draw any conclusions in these other instances.

Reviewing the literature from the perspective of the patient, the provider (or service delivery level) and the system level decisionmaker provides some guidance for the immediate future. From the perspective of system level decisionmakers, probably the most important lesson from the literature reviewed is that the current evidence does not support one single model of coordination. The lack of consensus regarding definitions and measures, and the paucity of data on the cost effectiveness of different interventions, limits the ability to compare the value of different care coordination efforts. Policymakers and decisionmakers at the system level must exercise caution before investing significant resources to support interventions without evidence demonstrating their value, despite the fact that these interventions may seem to “just make sense.” In the absence of strong evidence supporting specific coordination interventions, system level decisionmakers should consider supporting pilot programs while awaiting the results of larger, national studies such as the Medicare Coordinated Care and the Physician Group Practice Demonstration projects.

From the perspective of the patient, the literature reviewed provides some information for specific patient populations. For patients with congestive heart failure, the evidence supports enrollment in some type of coordinated care program (disease management, multidisciplinary team care, or case management). The majority of the reviews support formal coordinated care programs for patients with diabetes mellitus, depression, and other mental health illnesses. Patients hospitalized with acute stroke benefit from teams which coordinate discharge planning and postdischarge treatment plans. Patients in these clinically defined populations should consider care coordination programs as one element of evidence based therapy in their treatment regimens.

The evidence is not as clear for other patient populations that have obvious coordination needs, such as patients with multiple complex medical problems, the frail elderly living independently, patients transferring between care settings, or physically disabled persons. There are many models of care for these populations but few systematic reviews demonstrating the benefit of one coordination intervention over an alternative. However, these patients' needs are real and immediate and they must navigate today's health care system, while awaiting overall improvements in care coordination at the system level. For these patients identifying the components of coordinated care and adopting features of care coordination which can be initiated by the patient and caregivers may offer some assistance to their immediate needs.

Providers and decisionmakers at the health service delivery level are caring for patients with increasing needs for coordination services in a system that is progressively becoming more fragmented. Physicians perceive that time constraints are a major barrier to patient care. ^328^ Coordinating care for patients takes time; time that is typically not reimbursed. As the population ages, as the number of people with multiple chronic medical problems increases, and as patients see more doctors and receive care at a greater number of healthcare settings, the need to coordinate care will continue to increase. This increase in need is occurring in an environment in which cost containment efforts result in decreased access to social support services. While the need for coordination increases, healthcare providers frequently lack the infrastructure and resources to respond to their patient's needs.

Some components of care coordination can be adopted by providers at minimum cost. Routinely assessing coordination needs for patients at high risk may offer an opportunity to proactively address a need and avert a potential problem, e.g., notifying a family member to anticipate that the patient will need extra help at home following a scheduled hospital admission may prevent a delay in hospital discharge. Communication between providers and between care settings is a major problem and providers can assume the responsibility that referral letters and discharge summaries are sent in a timely manner. The current lack of interoperable electronic medical records greatly complicates this problem. Providers should also consider establishing communication links with community services and maintaining an inventory of these services. Providers should enroll willing patients in established care programs in which the evidence demonstrates improved outcomes, e.g., patients with CHF should be encouraged to enroll in coordinated care programs. As research in this field evolves, providers can work collaboratively with system level decisionmakers to adopt care coordination models that have demonstrated improved patient outcomes.

The table below lists suggestions to improve care coordination from the perspective of the patient, the provider, and the decisionmaker at the system level. Where the evidence exists based on systematic reviews, that information is presented and noted explicitly as evidence-based using bold-faced type. Many of the other approaches to improving care coordination are drawn from various intervention activities encountered in the research for this report, and should not be construed as having clear evidence of a benefit. They are selected as activities that can be done in a short time frame and possibly with minimal resources. This table is designed to help those who ask, “What can I do today to improve coordination for myself, my family or my patients?”

## Recommendations for Future Research

From our literature review, it is clear that future studies evaluating the effectiveness of care coordination interventions should explicitly define the care coordination intervention being evaluated. Much related terminology lacks standard definitions, leading to confusion about whether various approaches work. Furthermore, details of the specific interventions should be provided to enable comparisons and synthesis across studies. Further research should include analyses of the effects of specific care coordination components (e.g., mechanisms of coordination, task-specific characteristics) to determine if any particular component affects the effectiveness of the intervention.

Similarly, more research is needed to develop an understanding of conceptual frameworks to guide reporting of key variables. At this point, systematic reviewers have not been able to adopt a standard approach to evaluating care coordination interventions. Often this information is missing from the primary studies as well. Ideally, investigators would want to know what to describe and assess, and further theoretical work in this area may be helpful. Organizational theory suggests that this detail is vital to properly design interventions and programs that match the information-processing demands of the specific situation. The purpose of our review of several theories (Chapter 5) was to show the relevance of models from different fields to care coordination interventions. For example, there is no doubt interplay between patient need for coordination, level of fragmentation present in a particular setting, and any coordination intervention, but what is the best approach to conceptualize and study such interactions? More research is needed to determine theories that will be potentially useful to care coordination intervention design. ^329^

Concurrently with theoretical work, since some argue that the need for it in this area is unproven, ^330^ other research methods might be used to reach consensus about a common set of components that should be described any time an evaluation of a care coordination intervention is reported. We developed both a working definition and a list of components of care coordination to facilitate our review and analysis. The working definition allowed us to capture a broad range of interventions. We found application of the components list difficult due to the limited level of detail available in the systematic reviews. Future research might map the components from our list or that of others to interventions described in primary studies in order to define a common list, and to determine inter-rater reliability.

Determining the effectiveness of care coordination also requires more research on measures of care coordination. Assessing whether an intervention improves patient outcomes or lowers costs is the main goal of effectiveness studies. However, other coordination-oriented measures such as those that assess relational coordination, information exchange, enabling resources, and patient perceptions of coordination are important for refining interventions when they do not work. More research is needed on the validity of these measures, and about the relationship of these coordination-centric measures to outcomes of care. In addition, new measures need to be developed for areas that are not yet covered adequately (e.g., patient utilities/preferences for coordination, intensity of intervention).

Much of the work related to care coordination occurs outside of the research paradigm. Further research on observational study designs appropriate for this area is needed, and could build upon work in quasi-experimental methods, including those applied in this field. ^59^ The evaluations of the Medicare demonstration projects look promising and include rigorous experimental and observational designs. Smaller-scale quality improvement efforts may lack appropriate control groups for meaningful evaluations, and yet, development of methods to learn more from practical implementations seems particularly important for the area of care coordination.

Another promising area for additional research is to test whether interventions that work in one setting are applicable to another setting. Some of the lessons learned in one clinical domain (e.g., geriatric evaluation and management approach, comprehensive community-based treatment programs for the mentally ill) may be relevant to other areas (e.g., stroke patients, children with special needs). Our review of systematic reviews offers a list of possible interventions, many of which are currently used more intensively in specific clinical domains.

Finally, there is limited information at the systematic review level for some clinical domains and some types of interventions. It is likely that primary studies have been conducted on coordination of care for children with special needs, but the systematic review literature has not addressed this area yet.^*^ Other areas may be lacking primary studies, though ripe for future research and even new approaches. For example, a recent study applied complexity science to identify coordination issues (e.g., difficulties encountered by a complex pediatric patient and family when a CT scan appointment was cancelled) and develop potential solutions (e.g., foster relationships between families and schedulers to support contingency planning when emergency scans displace scheduled appointments). ^331^

* Paul Wise and colleagues from the Stanford-UCSF Evidence-based Practice Center have prepared a White Paper for AHRQ on Care Coordination in Children with Special Health Care Needs, which will be published soon and will help fill this gap.

The study of care coordination is challenging. Nonetheless, the impressive improvements in outcomes that were documented in the systematic reviews included in our report indicate that care coordination can work, and that appropriately designed studies can identify these improvements.