# Review of Systematic Reviews of Care Coordination Interventions

## 4A. Background

Increasingly, aspects of care coordination are being evaluated. In this chapter we provide a summary of this evidence by synthesizing systematic reviews of care coordination interventions intended to improve the quality of care of outpatients. Our intent was to describe the broad extent of the care coordination literature regarding outpatient care coordination programs. We did not limit our review to a specific clinical area or patient population.

## 4B. Methodological Approach

We sought articles reporting systematic reviews of care coordination interventions to improve quality of care provided to patients. We used our working definition of care coordination presented in the previous chapter to inform our inclusion and exclusion criteria.

### Inclusion and Exclusion Criteria

We searched for English language systematic reviews of care coordination interventions, irrespective of clinical condition, patient population, or specific outcomes. We considered an article to be a systematic review, if, at a minimum, the authors described conducting a systematic review, and performed a defined literature search.

We included reviews in which interventions were conducted either exclusively in an outpatient setting or were conducted across settings and included the outpatient setting (i.e., were started in an in-patient setting but continued in the outpatient setting). We also included systematic reviews where only a part of the review evaluated a care coordination intervention (typically, these were articles in which the reviews had a broader focus than care coordination but where some of the included articles met our definition of care coordination).

We excluded reviews where the only two participants were a clinician and the patient because these situations presumably have lower demands for coordination activities. We also excluded reviews that did not report evaluations of care coordination interventions and those reviews that were conducted solely in an inpatient setting.

### Search Strategy

We initially searched the following databases with the help of a research librarian: MEDLINE^®^ (through April 7, 2005), CINAHL^®^ (through May 17, 2005), Cochrane database of systematic reviews (through June 2, 2005), American College of Physicians Journal Club (through June 2, 2005), Database of Abstracts of Reviews of Effects (through June 2, 2005), PsychInfo (through June 2, 2005), Sociological Abstracts (through June 3, 2005), and Social Services Abstracts (through June 3, 2005). We searched with terms that were either synonymous with the term “coordination” or terms which have been used in the literature to suggest care coordination, as indicated by our work on definitions of care coordination (Chapter 3) and discussions with experts and librarians, including: “disease management,” “case management,” and “patient care planning.” We restricted our search to systematic reviews using the search strategy developed by Shojania et al. ^206^

In response to comments received by our peer reviewers, we updated our search through to September 30, 2006 for MEDLINE^®^ and to November 15, 2006 for the remaining databases. Complete search strategies for each database are presented in Appendix A *. We performed additional data abstraction (described below) on these additional reviews, referred to as “the most recent reviews.”

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/caregaptp.htm

### Data Abstraction and Evaluation

A single investigator reviewed titles and abstracts of each article identified in our search to determine whether the article met inclusion criteria. Investigators identified those articles about which they were unsure. These articles were then reviewed and discussed by the full research team and agreement on inclusion or exclusion for full text review was reached by group consensus. Two independent investigators reviewed and abstracted all articles requiring full text review. Disagreements on extracted data were discussed and resolved by the research team by reviewing the article. Additionally, the investigators met regularly and engaged in an active dialogue about specific articles.

From each of the included reviews, we abstracted data about whether the entire focus of the review or only a partial focus was on care coordination. For those reviews where the entire focus was on care coordination, we abstracted data on the research methodology used, setting of the care coordination intervention, terms and definitions used to describe the care coordination intervention, and the reported outcomes. For those reviews that only partially focused on care coordination, we limited our data abstraction to the purpose of the review, the care coordination strategies included, and outcomes. The complete full-text abstraction form is provided in Appendix B *.

In response to comments received from our peer reviewers, we also abstracted information, from the most recent reviews, on specific components of the care coordination intervention (Chapter 3, Table 6). We sought information on components of the specific care coordination intervention (e.g., case management, disease management) as well as whether details about the care coordination components were provided by the review.

### Quality Assessment of Reviews

We assessed the quality of the systematic reviews by abstracting information about specific systematic review research methodology criteria (Appendix B). These criteria have been used previously by the drug effectiveness review project of the Oregon Evidence-based Practice. ^207^

### Statistical Analysis

Given the heterogeneity of the included articles, we were limited in our ability to conduct quantitative analyses of the data. We report the results of our review as a narrative synthesis.

## 4C.Results

### Results of Literature Search and Article Review Process

The results of our search strategy and article review process are presented in Figure 1. Our searches yielded 4,730 potentially relevant articles of which 429 articles merited full-text review. Of these, 75 systematic reviews met our eligibility criteria for data abstraction. Appendix C * provides the citations of articles excluded after the full text review, along with the reason for exclusion.

Figure 1. Search results

In the sections that follow, we present 1) the results of the 43 reviews for which care coordination was the sole focus of the systematic review, 2) narrative syntheses of systematic reviews by common care coordination strategies and common patient populations, followed by the results of the 32 systematic reviews for which care coordination was only a partial focus and, 3) components of the interventions described in the most recent systematic reviews.

### Summary of Reviews With Entire Focus on Care Coordination

We identified 43 reviews that focused entirely on one or more care coordination strategy. These reviews were highly heterogeneous with respect to the care coordination interventions evaluated, their definitions, and the clinical topics evaluated (Tables 16–k).

### Quality Assessment of Reviews

Table 9 presents the results of our quality assessment of the included reviews. Overall, most of the reviews were rigorously conducted. All of them reported a research question. All but three of the reviews reported the specific search terms used and time frame covered by the search; five reviews did not provide specific inclusion/exclusion criteria. The quality of the reviews regarding the data abstraction process was mixed: 18 of the 43 reviews reported title/abstract review by at least two reviewers; 23 reported data abstraction by at least two reviewers and explained how disagreements between reviewers were resolved. About three-quarters of the included reviews provided some assessment of the validity of the articles they included in their analysis, almost all provided sufficient details on each individual article, and all provided an appropriate synthesis (either narrative, quantitative or both) of their results. Seven reviews reported using a research librarian to help with their search and 19 reviews included a topic or methods expert as part of their team (Figure 2).

Figure 2. Quality assessment of reviews

Table 9 Quality assessment of reviews with entire focus on care coordination

Reference | Purpose stated | Inclusion/ exclusion criteria stated | Dual title/ abstract review | Dual data abstraction | How disagreements resolved | Research team | Search terms reported | Time frame covered | Effort made to find all articles | Validity assessment of included articles | Sufficient details of included articles presented | Appropriate synthesis of included articles
Multidisciplinary teams
Mental health
Bower 2000 ^208^ | • | • | o | • | • | Not stated | • | • | • | • | • | •
Craven 2006 ^209^ | • | • | Not stated | • | • | ▪, ▴ | • | • | • | • | • | •
Gunn 2006 ^210^ | • | • | o | o | • | ▪, ▴ | • | • | • | o | • | •
Latimer 1999 ^211^ | • | o | o | o | o | Not stated | o | o | • | • | • | •
Marshall 2000 ^212^ | • | • | • | • | o | Not stated | • | • | • | • | • | •
Simmonds 2001 ^213^ | • | • | • | • | • | Not stated | • | • | • | • | • | •
Wadhwa 1999^†^ ^214^ | • | • | Not stated | • | • | Not stated | • | • | • | • | • | •
Ziguras 2000^†^ ^215^ | • | • | Not stated | Not stated | o | ▴ | • | • | • | • | • | •
Heart failure
Holland 2005 ^216^ | • | • | • | • | • | ▪ | • | • | • | • | o | •
McAlister 2004 ^217^ | • | • | • | • | • | ▴ | • | • | • | • | • | •
McAlister 2001* ^218^ | • | • | • | • | • | ▴ | • | • | • | • | • | •
Stroke
Langhorne 2005 ^219^ | • | • | • | • | • | ▪, ▴ | • | • | • | • | • | •
Palliative care
Higginson 2003 ^220^ | • | • | • | • | o | ▴ | • | • | • | • | • | •
No specific clinical focus
Lemieux-Charles 2006 ^221^ | • | • | Not stated | Not stated | Not stated | Not stated | • | • | • | o | • | •
Richards 2003† ^222^ | • | • | Not stated | • | o | ▴ | • | • | • | • | • | •
Disease management
Mental health
Neumeyer-Gromen 2004 ^223^ | • | • | Not stated | Not stated | o | Not stated | • | • | • | • | • | •
Heart failure
Göhler 2006 ^224^ | • | o | Not stated | • | • | ▴ | • | • | • | o | • | •
Roccoforte 2005 ^225^ | • | • | • | o | • | ▴ | • | • | • | o | • | •
Whellan 2005 ^226^ | • | o | Not stated | Not stated | Not stated | Not stated | • | • | • | o | • | •
Yu 2006 ^227^ | • | • | Not stated | Not stated | Not stated | Not stated | • | • | • | o | • | •
Diabetes
Knight 2005 ^228^ | • | • | • | Not stated | • | ▴ | • | • | • | • | o | •
Norris 2002† ^152^ | • | • | Not stated | Not stated | o | ▴ | • | • | • | • | • | •
Multiple clinical focus
Krause 2005 ^229^ | • | • | o | o | o | Not stated | • | • | • | o | o | •
Rheumatoid arthritis
Badamgarav 2003 ^230^ | • | • | • | • | • | Not stated | • | • | • | • | • | •
Case management
Mental health
Gorey 1998 ^231^ | • | o | Not stated | Not stated | o | Not stated | • | • | • | o | • | •
Marshall 1998 ^232^ | • | • | • | • | • | Not stated | • | • | • | • | • | •
Heart failure
Windham 2003 ^233^ | • | • | Not stated | Not stated | o | ▴ | • | • | • | • | • | •
No specific clinical focus
Payne 2002 ^234^ | • | • | • | • | • | ▪, ▴ | o | • | • | • | • | •
Integrated care
Mental health
Jeffery 2000† ^235^ | • | • | • | • | • | ▴ | • | • | • | • | • | •
No specific clinical focus
Briggs 2006 ^236^ | • | • | o | • | • | ▴ | • | • | • | • | • | •
Johri 2003 ^237^ | • | • | Not stated | Not stated | Not stated | Not stated | • | • | • | • | • | •
Interprofessional education
Mental health
Reeves 2001 ^238^ | • | • | o | • | • | Not stated | • | • | • | • | o | •
Pain management
Irajpour 2006 ^239^ | • | • | Not stated | Not stated | Not stated | Not stated | • | • | • | • | • | •
No specific clinical focus
Zwarenstein 2001 ^240^ | • | • | • | • | • | Not stated | • | • | • | NA | NA | NA
Other care coordination interventions
Heart failure
Philbin 1999 ^241^ | • | • | Not stated | Not stated | o | ▴ | • | • | • | o | • | •
Diabetes
Greenhalgh 1994 ^242^ | • | o | Not stated | Not stated | o | ▪, ▴ | o | o | • | o | • | •
Asthma
Ram 2005 ^243^ | • | • | • | • | • | ▪ | • | o | • | • | • | •
Cancer
Dohan 2005 ^192^ | • | • | Not stated | Not stated | Not stated | Not stated | • | • | • | o | o | •
No specific clinical focus
Grimshaw 2006 ^244^ | • | • | • | • | • | ▴ | • | • | • | o | • | •
Gruen 2003 ^245^ | • | • | • | • | • | Not stated | • | • | • | • | • | •
McCusker 2006 ^246^ | • | • | o | • | • | Not stated | • | • | • | o | • | •
Mitchell 2002 ^247^ | • | • | • | Not stated | o | Not stated | • | • | • | • | • | •
Zwarenstein 2000 ^248^ | • | • | o | o | o | Not stated | • | • | • | • | • | •

• Yes

o: No

▪: Research librarian assistance

▴: Topic or methods expert

NA: not applicable (no included studies)

* disease management programs;

† case management

### Systematic Review Characteristics

The characteristics of each systematic review are presented in Table 10. Most of the included reviews restricted their included articles to either randomized controlled trials (RCT), or other controlled trials. Nine reviews did not restrict their inclusion criteria by study design.

Table 10 Selected characteristics of reviews with entire focus on care coordination

Reference | Study designs included | Clinical focus | Population studied | Intervention setting
Multidisciplinary teams
Bower 2000 ^208^ | RCT, CBA, ITS | Mental health | General population | Outpatient
Craven 2006 ^209^ | All study designs | Mental health | General population | Community, outpatient clinic, specialist facility
Gunn 2006 ^210^ | RCT | Depression | Adult general population | Outpatient clinic
Latimer 1999 ^211^ | All study designs | Severe mental illness | General population | Outpatient clinic, home
Marshall 2000 ^212^ | RCT | Severe mental illness | General population | Community
Simmonds 2001 ^213^ | RCT, quasi-RCT | Severe mental illness | General population | Community, home
Wadhwa 1999† ^214^ | RCT, quasi-RCT | Mental illness; terminal illness | General population | Home, community, hospice
Ziguras 2000† ^215^ | Controlled studies | Severe mental illness | General population | Community
Holland 2005 ^216^ | RCT | Heart failure | General population | Home, hospital, outpatient clinic
McAlister 2004 ^217^ | RCT | Heart failure | Not stated | Home, specialist facility
McAlister 2001* ^218^ | RCT, quasi-RCT | IHD | General population | Not stated
Langhorne 2005 ^219^ | RCT | Stroke | Elderly | Community, hospital
Higginson 2003 ^220^ | All study designs | Palliative care | General population | Outpatient clinic, managed care, home, hospice
Lemieux-Charles 2006 ^221^ | All study designs with a comparison group or analyzed across time | No specific focus | General population | Outpatient clinic, home, Community, hospital
Richards 2003† ^222^ | RCT | No specific focus | Elderly | Outpatient clinic, hospital
Disease management
Neumeyer-Gromen 2004 ^223^ | RCT | Major depression | General population | Managed care
Göhler 2006 ^224^ | RCT | Heart failure | General population | Not stated
Roccoforte 2005 ^225^ | RCT | Heart failure | General population | Outpatient clinic, hospital, home
Whellan 2005 ^226^ | RCT | Heart failure | General population | Home, clinic
Yu 2006 ^227^ | RCT | Heart failure | Elderly | Home, hospital, outpatient clinic
Knight 2005 ^228^ | RCT, CBA | Diabetes | Not stated | Not stated
Norris 2002† ^152^ | All comparative studies | Diabetes | General population | Community, managed care
Krause 2005 ^229^ | Controlled studies; before-after studies | Asthma, diabetes, heart failure | General population | Home, hospital, outpatient clinic
Badamgarav 2003 ^230^ | RCT, quasi-RCT, CBA, ITS | Rheumatoid arthritis | General population | Outpatient clinic
Case management
Gorey 1998 ^231^ | RCT, quasi-RCT, pre-experimental | Severe mental illness | General population | Community
Marshall 1998 ^232^ | RCT | Severe mental illness | General population | Community
Windham 2003 ^233^ | All study designs | CHF | Elderly | Outpatient clinic, home, specialist facility
Payne 2002 ^234^ | All study designs | No specific focus | Elderly | Community, hospital, home, nursing home
Integrated care
Jeffery 2000† ^235^ | RCT | Severe mental illness; substance abuse | General population | Specialist facility
Briggs 2006 ^236^ | RCT, CBA, ITS | No specific focus | General population | Outpatient clinic
Johri 2003 ^237^ | RCT, quasi-RCT | No specific focus | Elderly | Community
Interprofessional education
Reeves 2001 ^238^ | All study designs | Mental health | General population | Not stated
Irajpour 2006 ^239^ | RCT, quasi-RCT | Pain management | General population | Community, hospital
Zwarenstein 2001 ^240^ | RCT, CBA, ITS | No specific focus | Not applicable - no included articles | Not applicable - no included articles
Other care coordination interventions
Philbin 1999 ^241^ | RCT, quasi-RCT, CBA | CHF | Elderly | Not stated
Greenhalgh 1994 ^242^ | All study designs | Diabetes | General population | Outpatient clinic, specialist facility
Ram 2005 ^243^ | RCT | Asthma | General population | Outpatient clinic
Dohan 2005 ^192^ | Not specified | Cancer | General population | Community, clinic
Grimshaw 2005 ^244^ | RCT, CBA, ITS | No specific focus | General population | Outpatient clinic
Gruen 2003 ^245^ | All study designs | No specific focus | General population | Outpatient clinic, hospital
McCusker 2006 ^246^ | All study designs | No specific focus | Elderly | Community, hospital, home, outpatient clinic
Mitchell 2002 ^247^ | RCT | No specific focus | General population | Outpatient clinic, hospital, home
Zwarenstein 2000 ^248^ | RCT, quasi-RCT, CBA, ITS | No specific focus | General population | Hospital

RCT: randomized controlled trial; CBA: controlled before-after study; ITS: interrupted time-series design;

* disease management programs;

† case management; CHF: congestive heart failure; HTN: hypertension; CAD: coronary artery disease; IHD: ischemic heart disease

The clinical topics that the included reviews addressed were varied. Care coordination interventions for improving care to patients with mental health problems (13 reviews) was the most common topic studied followed by heart failure (9 reviews) and diabetes (3 reviews). Eleven reviews did not have a specific clinical area of focus but instead studied interventions that crossed diseases, such as discharge planning or interprofessional education (i.e., training individuals from different professions interactively).

Eight of the reviews focused on elderly populations while most of the remaining reviews focused on adults in the general population for the specific disease of interest. Surprisingly, given the interest in care coordination for special need children, we did not find any reviews pertinent to this topic.

Interventions in about half the reviews were conducted across multiple settings, for example, from hospital to home or community, in outpatient clinics and at home or in outpatient and specialist clinics. Five of the reviews did not provide information on the specific settings of the interventions. Few studies provided detail on other setting-related factors (e.g., public versus private, HMO versus not, etc.).

### Care Coordination Strategies

The terms used to define the care coordination strategies were highly heterogeneous; 43 individual reviews reported 20 different care coordination interventions (Table 11). Most reviews reported on a single care coordination intervention, however, six reviews reported at least two types of interventions. ^152,^ ^214,^ ^217,^ ^219,^ ^222,^ ^235^ The most commonly used terms were multidisciplinary teams, case management, and disease management. Across reviews, there were varying definitions of the same care coordination term used (Tables 16a–k). For example, all ten reviews reporting on disease management ^152,^ ^218,^ ^223,^ ^230^ defined it differently (Tables 16a–k). Nine reviews ^217,^ ^224^ – ^226,^ ^233,^ ^235,^ ^241,^ ^244,^ ^246^ failed to provide a clear definition for the intervention under study; we included these reviews because the descriptions of the interventions of their included articles related to a care coordination strategy.

Table 11 Distribution of reviews with entire focus on care coordination by care coordination intervention

Care Coordination Intervention | No. of Reviews
Assertive community treatment | 3 ^211,^ ^212,^ ^215^
Case management | 8 ^152,^ ^214,^ ^215,^ ^222,^ ^231^ – ^233,^ ^235^
Collaborative care | 1 ^209^
Disease management | 10 ^152,^ ^218,^ ^223^ – ^230^
Geriatric assessment/evaluation and management | 2 ^222,^ ^246^
Integrated programs | 3 ^235^ – ^237^
Interprofessional education | 3 ^238^ – ^240^
Key worker assigned coordination function | 1 ^234^
Multidisciplinary clinic | 1 ^217^
Multidisciplinary program (comprehensive) | 1 ^241^
Multidisciplinary teams | 10 ^208,^ ^210,^ ^213,^ ^214,^ ^216,^ – ^218,^ ^220^ – ^222^
Navigation program | 1 ^192^
Nurse-doctor collaboration | 1 ^248^
Organized specialty clinic | 1 ^243^
Organized cooperation | 1 ^247^
Shared care | 1 ^242^
Specialist outreach clinic | 1 ^245^
System level interventions | 1 ^210^
Team coordination and delivery | 1 ^219^
Team coordination | 1 ^219^

Note: The intervention terms used in this table are the terms used by the systematic reviews; similar interventions may have slightly different terms.

Table 16 Components described or evaluated by the systematic reviews

Review | Intervention | Care Tasks/Coordination Activities* | Features* | Quantitative Patient Outcomes | Evaluation by Component(s)? | Comments
Craven ^209^ | Collaborative care | I, C | TOOL, REDESIGN | NO | NO | Provided detailed descriptions of each included study.
Gunn ^210^ | System level interventions | I, C, M | TOOL | YES (+) | NO
Holland ^216^ | Multidisciplinary interventions | A, I | IT, TOOL | YES (+) | YES | Analyzed subgroups: One on one patient education [TOOL] mattered. Patient targeting at high risk patients [ASSESSMENT] did not matter.
Lemieux-Charles ^221^ | Team | I, C, M | TOOL | NO | NO | Provided detailed descriptions of each included study.
Gohler ^224^ | Disease management | D, I, M | TOOL, TECHNIQUE | NO | PARTIALLY | Analyzed intervention characteristics (team composition, intervention mode, country and duration of followup) in order to explain heterogeneity across studies regarding mortality.
Roccoforte ^225^ | Comprehensive disease management | D, I | TOOL | YES (+) | YES | Sensitivity analysis found that multidisciplinary programs better than nurse-led interventions. [PARTICIPANT ROLE]
Whellan ^226^ | Disease management | I | - | NO | NO | Authors reported lack of information on program components in the primary studies.
Yu ^227^ | Disease management | D, I, M | IT, TOOL | YES (+) | YES | Categorized studies into effective and ineffective based on key characteristics recommended by the European Society of Cardiology. Effective DMPs were more likely to involve both cardiac nurse and cardiologist; having the PCP [PARTICIPANT ROLE] as a member of the care team also appeared to result in more promising discharge outcomes.
Knight ^228^ | Disease management | M | - | YES (+) | YES | A program involving pharmacist counseling patients and adjusting medications [MONITOR] and 2 programs involving combined physician and patient interventions were associated with greatest estimated changes in GHb. No further detail provided.
Krause ^229^ | Disease management | C | - | NO | NO | No description of intervention components.
Briggs ^236^ | Integration of primary care services | A | - | NO | NO
Dohan ^192^ | Navigation programs | I, C | | NO | NO
McCusker ^246^ | Comprehensive geriatric assessment | A, D, I, C | TOOL, TECHNIQUE, REDESIGN | NO | PARTIALLY | Narrative synthesis examined intervention characteristics to see which studies showed improvements in ED utilization. For e.g., “two RCTs evaluated multidisciplinary assessment and/or liaison intervention, a case conference and liaison with primary care; neither significantly reduced ED utilization”. “Other characteristic of interventions that may reduce ED utilization include greater integration with primary medical care and targeting of the intervention to higher risk patients. There was...insufficient number of studies to allow us to asses the effects of these factors.”
Individual studies

* A component is listed if it is obvious from the description that it was part of the intervention. Other components may well be present, but not described well enough to categorize with confidence.

Care tasks/Coordination Activities: A=Assess Patient, I=Identify Participants and Role, D=Develop care plan, C=Communication, E=Execute care plan, M=Monitor and adjust

Features: IT=Information technology, TOOL, TECHNIQUE to mitigate interface issues, REDESIGN of system to support care coordination

Our review of the evidence, provided in the sections that follow, suggests that care coordination strategies may improve health outcomes. Given the heterogeneity of the different interventions studied, it is unclear whether one particular strategy is more likely to work than others; however, interventions using multidisciplinary teams and disease management programs consistently reported improved outcomes. We provide further evidence to support this finding in our summary tables (Tables 16a–k) and in our narrative synthesis section below.

### Outcomes Reported

Due to the heterogeneity of clinical topics, settings, patient populations and interventions, the systematic reviews reported a broad range of endpoints. In many cases, there was not any quantitative summary across included studies. For the 16 systematic reviews with some patient or utilization outcome synthesized, Table 12 summarizes the specific endpoints reported quantitatively for five general categories: clinical outcomes, adherence outcomes, other patient experience outcomes, and utilization outcomes. Specific quantitative results are provided in the summary tables (Tables 16a–k).

Table 12 Quantitative outcomes reported by systematic reviews

Reference | Care coordination intervention | Clinical Outcomes | Adherence Outcomes | Other Patient Experience Outcomes | Utilization Outcomes
Gunn 2006 ^210^ | System level interventions | Recovery from depression
Marshall 2000 ^212^ | Assertive community treatment (ACT) | | Remain in contact with service | Live independently; Become homeless; Unemployed | Hospital admissions
Holland 2005 ^216^ | Multidisciplinary interventions | All-cause mortality | | | All-cause admissions; heart failure admission
McAlister 2004 ^217^ | Multidisciplinary teams | All-cause mortality | | | All-cause admissions; heart failure admission
Langhorne 2005 ^219^ | Multidisciplinary teams | Death or dependency
Higginson 2003 ^220^ | Palliative care teams | Pain; other symptoms | | Satisfaction
McAlister 2001 ^218^ | Multidisciplinary disease management | Recurrent myocardial infarction; all-cause mortality | | Cardiovascular risk factors; quality of life | Hospital admission; length of stay
Neumeyer-Gromen 2004 ^223^ | Disease management programs | Depression severity | Treatment adherence | Patient satisfaction
Göhler 2006 ^224^ | Disease management programs | All-cause mortality | | | All-cause hospitalizations
Roccoforte 2005 ^225^ | Comprehensive disease management program | Mortality | | | All-cause admissions; heart failure admission
Yu 2006 ^227^ | Disease management program | Mortality | | Quality of life | Hospital readmission
Knight 2005 ^228^ | Disease management | Glycated hemoglobin
Norris 2002 ^152^ | Disease management; case management | Glycated hemoglobin
Badamgarav 2003 ^230^ | Disease management | | | Functional status
Irajpour 2006 ^239^ | Interprofessional education | Pain severity | Documentation of pain history
Philbin 1999 ^241^ | Comprehensive, multidisciplinary program | | | Functional status; aerobic capacity; satisfaction | Hospital admission

### Costs

Background. Given the costs associated with poorly coordinated care, even intensive care coordination interventions have the potential to be cost-saving.

Results. 22 reviews reported some cost estimates or comparisons for the care coordination intervention under study (Table 13). The reported results were extremely heterogeneous. Only one review reported results from cost-effectiveness/cost-utility analysis ^223^ that suggested disease management programs were cost-effective. Another review ^229^ conducted a meta-analysis to evaluate the economic effectiveness of disease management programs. Krause ^229^ reports economic effectiveness in terms of effect size which is a summary outcome measure created from the direct economic outcome measures (cost, hospitalizations, clinic visit, emergency department visit) reported in each individual study. The findings from this review suggest that disease management programs were economically effective. Nine reviews ^213,^ ^215,^ ^217^ – ^219,^ ^222,^ ^227,^ ^231^ reported lower costs for the care coordination intervention when compared to usual care; however, none of these reviews conducted any formal cost-effectiveness analysis. Seven reviews reported mixed cost results of the intervention ^208,^ ^214,^ ^220,^ ^226,^ ^233,^ ^245,^ ^247^ and five reviews reported insufficient evidence to draw any definitive conclusions about the costs of interventions. ^211,^ ^212,^ ^232,^ ^236,^ ^241^ (Table 13).

Table 13 Reviews with entire focus on care coordination: cost results

Reference | Intervention | No. of articles reporting cost data | Results
Bower 2000 ^208^ | On-site mental health worker | 3 | Cost results were mixed; no formal cost-effectiveness analysis. There were increased costs for some patient groups and decreased costs for others.
Latimer 1999 ^211^ | Assertive community treatment (ACT) | 34 | ACT appears to have lower costs; however, reducing costs for ACT programs will be determined by the reduction in hospital use.
Marshall 2000 ^212^ | Assertive community treatment (ACT) | 9 | There was insufficient cost data reported in the articles to enable comparisons between ACT and the control intervention.
Simmonds 2001 ^213^ | Community mental health team management | 5 | Reported total cost of care; lower costs for community mental team management compared to standard care (difference ranged from 12% to 53%); data reported from articles was highly skewed
Wadhwa 1999 ^214^ | Multidisciplinary teams; case management | 10 | Cost data provided in the 10 articles was insufficient to enable a summary analysis. Half of the articles showed no difference in costs between the intervention and control group. The other half showed significant differences between the two groups with one article reporting higher costs for the intervention group.
Ziguras 2000 ^215^ | ACT; Case management | 5 | Case management was associated with lower total costs of care when compared to usual treatment [Weighted mean r = 0.13 (95% CI for r: 0.07–0.19), p=0.043].
McAlister 2004 ^217^ | Multidisciplinary teams | 18 | No formal cost-effectiveness analysis conducted. 15 of 18 articles reported interventions to be cost-saving; 3 reported interventions to be cost-neutral
McAlister 2001 ^218^ | Multidisciplinary disease management | 3 | No articles reported cost-effectiveness analysis; 2 articles reported their interventions to be cost saving.
Langhorne 2005 ^219^ | Team coordination/delivery | 11 | Total costs estimated; median cost reduction in the early supported discharge group of 20% (range 4–30).
Higginson 2003 ^220^ | Palliative care teams | 14 | Only one article reported the intervention as cost-effectiveness analysis. The remaining articles reported costs and resource use. The results from these articles were heterogeneous.
Richards 2003 ^222^ | Comprehensive discharge planning and implementation | 2 | Both articles showed lower intervention costs. Mean cost per patient was lower in one article (1989-1992 values) among those receiving the intervention ($8956.44 vs. $9262.20); average cost per patient (1982-1996 values) in the other article was significantly lower compared to controls ($3630 vs. $6661)
Neumeyer-Gromen 2004 ^223^ | Disease management | 6 | Results from cost effectiveness/cost utility analysis; cost utility ratios ranged from $9,051 to $48,500 per quality-adjusted life year
Whellan 2005 ^226^ | Disease management | 10 | 5 of the articles reported significantly lower intervention costs compared to usual care; one reported significantly higher intervention costs; and the other 4 reported no difference between the two groups.
Yu 2005 ^227^ | Disease management | 11 | 8 effective and one ineffective disease management program reported lower costs per case; one effective and one ineffective disease management program reported no significant differences in cost.
Krause 2005 ^229^ | Disease management | 67 | Overall, disease management programs were economically effective [effect size 0.311 (95% CI: 0.272–0.35)].
Gorey 1998 ^231^ | Case management | 6 | 5 of the 6 articles reported lower intervention costs.
Marshall 1998 ^232^ | Case management | 6 | The cost data reported in the articles were insufficient to allow for drawing of any definitive conclusions.
Windham 2003 ^233^ | Care management | 17 | 6 articles showed significant reduction in intervention costs compared to the control group; 6 found no difference; 5 did not report comparisons.
Briggs 2006 ^236^ | Integration of services | 2 | Inconclusive evidence of integration on cost impacts. One article found costs per patient to be higher for usual care; the other article found integration to be less costly.
Philbin 1999 ^241^ | Comprehensive, multidisciplinary program | 3 | 2 articles reported decreased costs in the intervention group; however, these were associated with decreased hospitalizations. Overall, no compelling evidence.
Gruen 2003 ^245^ | Specialist outreach clinics | 4 | Cost per patient. 2 articles found the intervention to be more expensive ($487 and $296 respectively) more per patient); however, one of these articles reported their intervention to be 7.4% more cost-effective when health outcomes were considered. 2 articles reported lower costs per patient (71 pence and AUD$173 respectively)
Mitchell 2002 ^247^ | Organised cooperation | 2 | Cost results were mixed.

Summary. We conclude that there is insufficient evidence from the included reviews to draw definitive conclusions about the costs associated with care coordination interventions.

Given the heterogeneity of the included reviews, we did a separate synthesis for selected care coordination strategies, clinical topics, vulnerable populations, and across settings. We report the results of our narrative synthesis in the following sections; the synthesis includes reviews that focused entirely on care coordination and where possible, those that focused partially on care coordination.

## Narrative Syntheses of Selected Systematic Reviews by Care Coordination Strategy

We identified five care coordination strategies that were reported in more than one systematic review: use of teams (usually multidisciplinary), case management, disease management, integrated care, and interprofessional education. Thus, we were able to provide a narrative synthesis of the evidence on each of these care coordination strategies.

### Systematic Reviews Evaluating Multidisciplinary Teams as a Care Coordination Strategy

Background. Multidisciplinary teams usually involve two or more providers from different specialties providing care to a group of patients. Presumably, teams consisting of health care personnel from different fields are more likely to address all the components of patient care, are more likely to share information and thereby, provide more coordinated care. Interventions that involve the use of multidisciplinary teams in managing a patient's care may be associated with better outcomes. ^217^

Results. Among the reviews that focused entirely on care coordination, we found 15 reviews ^208^ – ^222^ that evaluated the effects of multidisciplinary teams (Table 14a, Table 14b, Table 14g, Table 14i, Table 14j); among the reviews that partially focused on care coordination, 11 ^249^ – ^259^ included multidisciplinary teams as part of their interventions (Table 15).

Table 14a Summary of reviews with entire focus on care coordination interventions: mental health

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Bower 2000 ^208^ | To assess the effect on primary care provider behavior of adding an onsite mental health worker | On-site mental health worker: services provided by an on-site MHW were a separate activity and not part of normal primary care consultations; the PCP and MHW work for at least part of the time as part of the same clinical team | 38 | The addition of a mental health worker to the primary care team did not have any significant effects on provider behavior. The evidence did not support the addition of a mental health worker to a primary care team with the intent of changing provider behavior. | None
Craven 2006 ^209^ | To identify better practices in collaborative care for mental health | Collaborative care: “involves providers from different specialties, disciplines, or sectors working together to offer complementary services and mutual support, to ensure individuals receive the most appropriate service from the most appropriate provider in the most suitable location, as quickly as necessary, with a minimum of obstacles. Collaboration can involve better communication, closer personal contacts, sharing of clinical care, joint educational programs, and (or) joint program and system planning.” | 38 | The authors reported the following results: collaborative relationships at either a system-level or provider level require time, supportive structures and preparation; the degree of collaboration does not appear to predict outcomes; for collaboration to be effective, it should be paired with treatment guidelines; collaboration works best when clinicians and specialists are located in the same place; systematic follow-up was a strong predictor of positive clinical outcomes; patient choice about treatment may be important; and collaborative care interventions established as part of a research study may be difficult to sustain once the study is complete. | Not possible to evaluate effectiveness of different elements of collaborative care
Gunn 2006 ^210^ | To assess effectiveness of “system level” interventions for depression | System level interventions: had to include ALL of the following: (1) multi-professional approach with a GP and at least one other health professional; (2) a structured management plan; (3) scheduled patient follow up; (4) enhanced inter-professional communication through team meetings, case-conferences, feedback between care-givers | 11 | Eight articles reported an increase in the proportion of patients recovering from depression in favor of the intervention group (range 10% to 33%); however the articles did not account for attrition rates ranging from 5% to 50%. | No information on which elements of the intervention contribute to improved outcomes.
Latimer 1999 ^211^ | To determine the economic impacts of the assertive community treatment model | Assertive community treatment: “involvement of team medical personnel along with a case manager, team meetings to discuss treatment plans” | 34 | The most consistent effect of the assertive community treatment (ACT) model was the greater reduction in hospital use, particularly of programs that have higher fidelity to the ACT model. “Based on costs in Quebec, high-fidelity ACT can cut costs if patients averaged more than about 50 days hospitalization yearly”. | Poorly described methods for article searches and inclusion/exclusion criteria.
Marshall 2000 ^212^ | To determine the effectiveness of assertive community treatment (ACT) for severe mental disorders when compared to standard care, hospital-based rehabilitation and case management | Assertive community treatment: a multidisciplinary team sharing responsibility for their patients who care exclusively for a group of patients; emphasizes team working and responsibility | 26 | Patients receiving ACT were more likely to remain in contact with services [OR: 0.51 (95% CI: 0.37–0.70)], were less likely to be admitted to a hospital [0.59 (0.41–0.85)], more likely to be living independently [0.46 (0.25–0.86)], less likely to become homeless [0.24 (0.08–0.65)], and less likely to be unemployed [0.31 (0.17–0.57)] when compared to standard community care. These findings were consistent when compared to hospital-based rehabilitation. There was insufficient data to allow for comparison to case management for patients remaining in contact with services and hospitalization. There was insufficient cost data; however, limited data suggests that ACT programs are expensive. Overall, the evidence suggested that ACT is effective in caring for mentally ill patients in the community. | None.
| | | | There was insufficient data to allow for comparison to case management for patients remaining in contact with services and hospitalization. There was insufficient cost data; however, limited data suggests that ACT programs are expensive. Overall, the evidence suggested that ACT is effective in caring for mentally ill patients in the community.
Simmonds 2001 ^213^ | To assess the benefits of community mental health team management in severe mental illness | Community mental health team management: generic care (care not supplemented by assertive community treatment, intensive case management or other specific model) from a community-based multi-disciplinary team that provides a full range of interventions | 5 | Community mental health team management compared to standard care was associated with fewer deaths by suicide or suspicious circumstances, lesser loss to follow-up, reduced hospital stay, and reduced costs. The intervention showed no impact on social functioning. | None
Wadhwa 1999 ^214^ | Do multidisciplinary teams, case management, and outreach or home care improve the quality of care for vulnerable populations | Multidisciplinary teams: “comprehensive care is delivered through the coordinated action of a diverse collection of health care populations” | 3 | These interventions did not consistently demonstrate improvements in functional, clinical or psychological outcomes. Multidisciplinary outreach strategies were effective in reducing in-patient hospitalizations among mentally ill patients. Aggressive case management models also appeared to be beneficial to mentally ill patients. | None
| | Case management: “a health care professional who works with the patient and families” | 6 | Satisfaction among patients and care givers was higher among these interventions. There was insufficient cost data provided in the articles.
Ziguras 2000 ^215^ | To evaluate the effectiveness of case management in mental health | Assertive community treatment: authors recorded the definition provided in each article | 28 | Both assertive community treatment and clinical case management had positive effects on family burden, family satisfaction and costs of care. While clinical case management increased total number of admissions, it also decreased the total length of stay in the hospital. However, with assertive community treatment the total number of admissions and the proportion of clients hospitalized were reduced. Overall, assertive community treatment was more effective in reducing hospitalization compared to clinical case management. | None
| | Clinical case management: no specific definition; authors recorded the definition provided in each article. | 16
Neumeyer-Gromen 2004 ^223^ | To assess the effectiveness and cost-effectiveness of disease management programs for depression | Disease management: the program had to include all the following components: patient self management education, provider education, collaborative care, routine reporting and regular feedback between different professions, interdisciplinary discussion of treatment options and supervision by specialists | 10 | Disease management programs (DMPs) when compared with usual primary care, significantly improved depression severity [RR 0.75 (95% CI: 0.70–0.81)], adherence to treatment regimen [0.59 (0.46–0.75)] and patient [0.57 (0.37–0.87)] and provider satisfaction. This finding was applicable across different degrees of depression, settings and US populations. DMPs can be considered cost-effective (costs per QUALY: $9,051 to $49,500). The effectiveness of single elements within the programs could not be assessed since the research question aimed at answering the effectiveness of DMPs which included all components in a comprehensive care strategy. | None
Gorey 1998 ^231^ | To assess the effectiveness of case management for mentally ill patients | Case management: “outreach, identification, assessment and service planning, service linkage and monitoring, advocacy” | 24 | Among articles assessing functional status, prevention of re-hospitalization and quality of life, approximately three-quarters of patients in a case management program had better outcomes than those not in such programs. Also, approximately three-quarters of case managed care plans cost less than the average comparison care plan. Case load accounted for half of the variability observed in case management's effectiveness. | No detail on inclusion/exclusion criteria provided.
Marshall 1998 ^232^ | To assess the effectiveness of case management “as an approach to caring for severely mentally ill people in the community” | Case management: “means of coordinating services”; by a single case manager who is expected to assess that person's needs, develop a care plan, arrange for suitable care to be provided, monitor the quality of the care provided, and maintain contact with the person | 11 | Patients receiving case management were more likely to remain in contact with psychiatric services, though the effect size was small. Case management approximately doubled the rate of hospital admissions when compared to standard care. In one trial, case management found a significant increase in medication compliance, otherwise it appeared unlikely that case management showed substantial improvement in clinical or social outcomes. | None
| | | | The effect of case management on costs must be interpreted with caution; while it appears that case management increases costs to health care providers, it may reduce cost to society. Overall, the authors believe that case management is a poor alternative to standard care “because a small advantage in numbers remaining in care is off-set by a large increase in admission rates, no obvious clinical gains and considerable uncertainty over costs.”
Jeffery 2000 ^235^ | To evaluate the effectiveness of different approaches to treating patients with problems of severe mental illness and substance misuse | Integrated care programs: programs where substance misuse treatment was integrated with psychiatric care and care was provided by the same personnel team | 6 | The review looked at complex patients: patients with severe mental illness who also had problems with substance misuse. There was no clear evidence that integrated programs have different outcomes compared to programs providing psychiatric treatment alone. There was also no evidence that any particular type of integrated program was better than the others studied. However, one article found that a residential integrated program was more likely to retain patients than a non-residential program. | No definition of case management intervention
| | Case management: not defined but included a specialized five-hour per week substance misuse treatment group | 1 | Overall, there was no clear evidence that integrated care for patients with substance misuse and severe mental illness can lead to better or worse outcomes.
Reeves 2001 ^238^ | To assess the effect of interprofessional education on the care of adults with mental health problems | Interprofessional education: “when two or more professionals learn interactively together with the object of promoting collaborative practice” | 19 | All of the articles showed an improvement in the outcomes studied regarding provider education; however the author notes that the quality of the included articles was generally poor and so the evidence relating to the effectiveness of interprofessional education can be considered “patchy”. | Outcomes related to provider education and not specifically patient care.

Table 14b Summary of reviews with entire focus on care coordination interventions: heart failure

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Holland 2005 ^216^ | To determine the effectiveness of multidisciplinary interventions on improving outcomes for patients with heart failure | Multidisciplinary interventions: interventions “in which management was the responsibility of a multidisciplinary team that included medical input plus one or more of the following: a specialist nurse, a pharmacist, a health educator, a dietician, or a social worker” | 30 | Multidisciplinary interventions reduced all outcomes reported: all cause admission [RR: 0.87 (95% CI: 0.79–0.95), p=0.002], all cause mortality [0.79 (0.69–0.92), p=0.002] and heart failure admission [0.7 (0.61–0.81), p<0.001]. | None
| | | | Interventions with a home-based component or those with telephone followup were more effective than those based in the hospital or clinic; home-based interventions showed reductions in both all cause [0.8 (0.71–0.89), p<0.0001] and heart failure [0.62 (0.51–0.74), p<0.001] admissions.
| | | | Intensity of the intervention [high or low] and risk of the patient (high or low) did not appear to have an impact on effectiveness. Almost all included interventions had two elements in common: symptom monitoring and self-management advice; and one-to-one patient education.
McAlister 2004 ^217^ | Do multidisciplinary strategies improve outcomes for patients with heart failure? | Multidisciplinary heart failure clinic: not defined | 7 | Specialized follow-up by multidisciplinary teams (regardless of setting), was associated with significant reductions in all-cause mortality [RR: 0.75 (95% CI: 0.59–0.96)], all-cause hospitalization [0.81 (0.71–0.92)] and heart failure hospitalization rates [0.74 (0.63–0.87)]. The authors believe that the following 3 elements were crucial to the success of these programs: specially trained heart failure nurses, patient and caregiver education, ready access to providers trained in heart failure. | No definition of the studied interventions.
| | Multidisciplinary team providing specialized follow-up in a non-clinic setting: not defined | 8
McAlister 2001 ^218^ | To determine the effects of multidisciplinary disease management programs on outcomes among patients with coronary heart disease | Multidisciplinary disease management: Programs using multidisciplinary teams and specialized clinics | 12 | Multidisciplinary disease management programs when compared to usual care showed reduced rate of admission to hospital [RR 0.84 (95% CI: 0.76–0.94)] and length of hospital stay. There was no effect on recurrent myocardial infarctions or all cause mortality. Intervention patients were more likely to be prescribed appropriate medications. 5 of 7 trials evaluating the impact of disease management on cardiovascular risk factors (reduction in cholesterol concentration, rates of smoking cessation, reduction in blood pressure) showed significantly greater improvements in the intervention group. 5 of 8 trials measuring quality of life showed better improvements in the intervention arm, but only 3 were statistically significant. | None
Göhler 2006 ^224^ | To determine the efficacy of disease management programs for heart failure | Disease management programs: No clear definition provided by review | 36 | Disease management programs (DMP) significantly decreased all-cause mortality [Risk Difference: 3% (95% CI: 1%–5%), p<0.01] and all-cause hospitalization [8% (5%–11%), p<0.0001)]. | No clear definition of intervention term
| | | | Heterogeneity across the studies was explained by team composition (single person versus multiple persons), intervention mode (personal contact versus telephone), patient age and severity of disease and length of followup.
Roccoforte 2005 ^225^ | To evaluate the effectiveness of disease management programs for heart failure | Comprehensive disease management programs: not defined by review | 33 | Disease management programs showed significant reductions in mortality [OR: 0.8 (95% CI: 0.69–0.93), p=0.003], all-cause re-admission rates [0.76 (0.69–0.94), p< 0.00001] and HF-related admission rates [0.58 (0.5–0.67), p<0.00001] compared to usual care. Mortality was reduced in multidisciplinary interventions [0.58 (0.44–0.75)] but not in nurse-based only interventions [0.93 (0.77–1.11]; however, there was no difference in admission rates based on provider type. Length of intervention had mixed results; long term interventions (> 6 months) appeared to reduce all outcomes; however, short-term (0–3 months) and medium term (3–6 months) also reduced admission rates. | No definition of the intervention that was the focus of the review
Whellan 2005 ^226^ | To evaluate the effectiveness of disease management programs for heart failure | Disease management programs: not defined by review | 19 | Disease management programs showed a significant decrease in all-cause hospitalization; there was significant heterogeneity in the results. | No definition of the intervention that was the focus of the review; the meta-analysis did not provide actual numbers for the pooled results
Yu 2006 ^227^ | To identify key components of effective disease management programs | Disease management program (DMP): program “used multiple interventions in a systematic manner to manage heart failure across health-care delivery systems” | 21 | Categorized disease management programs into effective versus ineffective using the characteristics recommended by the European Society of Cardiology (ESC). Effective programs (n=11) significantly decreased hospital readmissions by 29%–85% (mean 44.15 +/- SD: 14.36%); four programs significantly reduced mortality rates by 28%–78% (57.6 +/- 21.9%). Effective DMPs improved quality of life and were cost saving. When comparing specific components of the intervention, effective DMPs had the following: multidisciplinary teams, or care that involved both a cardiac nurse and cardiologist; provided a wider range of in-hospital care; were more likely to include home visits; and ongoing surveillance and management. | None
Windham 2003 ^233^ | “To identify those interventions and outcome measures that should be included when designing and assessing the effectiveness of care management programs for older patients with congestive heart failure” | Care management programs: not defined by review | 32 | Characteristics of effective programs: close monitoring of patients by nurses or care managers; patient education combined with regular contact with nurse or physician. | No definition of the intervention that was the focus of the review.
| | | | Characteristics of Ineffective programs: lack of structured patient monitoring; self management alone without follow up or monitoring; problems with patient selection; lack of a structured or standardized intervention; insufficient training of personnel.
Philbin 1999 ^241^ | to evaluate the impact of comprehensive, multidisciplinary management programs on outcomes and processes of care in patients with congestive heart failure | Comprehensive, multidisciplinary program: not defined | 7 | A decrease of 50% to 85% in the rate of hospital admissions was reported in 6 articles. Improved functional status, aerobic capacity or satisfaction was reported in five articles. The economic data was weak suggesting that multidisciplinary programs may be cost-saving. | None

Table 14g Summary of reviews with entire focus on care coordination interventions: pain management

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Irajpour 2006 ^239^ | To determine if interprofessional education changes provider practice and patient outcomes | Interprofessional education: “Occasions when two or more professions learn from and about each other to improve collaboration and the quality of care” | 4 | Only one study reported improvement in patient's pain (p<0.0001) between the intervention and control groups; two studies reported no difference in pain scores. One study reported improvement in documentation of pain history between groups (p<0.001). | Some of the included articles were conducted in an in-patient setting.

Table 14i Summary of reviews with entire focus on care coordination interventions: rheumatoid arthritis

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Badamgarav 2003s ^230^ | To determine the effect of disease management programs on functional status of patients with rheumatoid arthritis | Disease management: “a multidisciplinary intervention delivered by a team of health care professionals, providing a systematic approach to care, and including a patient educationcomponent. A multidisciplinary team was defined as 2 or more disciplines cooperatively involved in patient care” | 11 | Overall, disease management did not improve functional status in patients with rheumatoid arthritis [Effect size: 0.27; 95% CI: -0.01-+0.54)]. However, when interventions were examined by duration and intensity, interventions lasting longer than 5 weeks showed significant improvements in patient functional status [0.49 (0.12–0.86)] compared with those lasting <= 5 weeks [0.13 (-0.25–0.52)]. There was no effect on functional status based on the intensity of the intervention. | Some of the included articles were conducted in an in-patient setting.

Table 14j Summary of reviews with entire focus on care coordination interventions: stroke

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Langhorne 2005 ^219^ | To assess the effectiveness of early supported discharge (ESD) services | ESD team coordination and delivery: multidisciplinary team coordinated discharge from hospital and postdischarge care and rehabilitation at home | 7 | There was a significant reduction in death or dependency in activities of daily living among patients assigned to an ESD team [OR 0.79 (95% CI 0.64–0.97), p=0.02] compared to conventional services. There finding was also seen specifically in articles with a coordinated multidisciplinary team versus those without a team [0.70 (0.56–0.88), p=0.02, vs. 1.23 (0.79–1.91), p=0.4, respectively]. Estimated costs were lower in the articles that described an ESD team (median cost reduction 20%, range 4–30). | None
| | ESD team coordination: discharge and post discharge care planned and supervised by coordinated team; however, subsequent care provided by community-based agencies | 2

Table 15 Summary of reviews with partial focus on care coordination interventions

Reference | Purpose | Results
Adli 2006 ^273^ | To discuss algorithm-guided treatment for depression | This review evaluated the effectiveness of algorithm-guided care; it included four studies on collaborative care that used algorithms to guide treatment. All studies showed improvement in different outcomes measured (e.g., symptoms, greater satisfaction with care and higher attrition rates).
Aminzaadeh 2002 ^275^ | To assess use of emergency department by older adults, risk factors associated with adverse health outcomes, and the effectiveness of intervention strategies | This review was primarily an epidemiologic review looking at the use of emergency departments (ED) by older adults; it also included the risk factors to determine ED use. One section of the review focused on interventions such as comprehensive geriatric evaluation (5 articles) and coordinated discharge planning to improve ED use; however, the data were inconclusive about the effectiveness of these strategies.
Andrews 2004 ^267^ | To explore the roles of community health workers and their effectiveness in conducting research with ethnic minority women | The review investigated using community health workers in research with ethnic minority women. In reviewing their roles, there were 4 articles that considered community health workers as case managers but this was integrated with their other roles as educators or outreach workers. The authors reported that “using community health workers as case managers was more successful in retaining subjects than using them for outreach only”
Ara 2004 ^262^ | To evaluate the effectiveness of cardiovascular disease management programs in managed care populations | The different interventions included in the different disease management programs suggest some effectiveness in improving outcomes for cardiovascular diseases. The specific interventions that demonstrated effectiveness included case management, physician reminders and feedback, patient education and self-management. Specifically for CHF disease management programs, case management and intensive patient monitoring were effective strategies.
Badamgarav 2003 ^263^ | To evaluate the effectiveness of disease management programs for depression | This review searched for disease management programs for depression; however, it included several different interventions, of which multidisciplinary teams were one component. The review, however, did not specifically provide results for the effectiveness of multidisciplinary teams on outcomes but provided results for disease management programs as a whole. Overall, the pooled results indicated statistically significant outcomes for patients with depression who received disease management programs. The results also indicated that these programs can increase treatment costs.
Bijl 2004 ^266^ | To evaluate the effectiveness of disease management programs in recognizing, diagnosing and treating major depression | The review did not define disease management. Only one of the 6 included studies met our definition for care coordination. That study showed improvements in the intervention group for the outcomes reported: reductions of depressive symptoms [OR 3.45 (95% CI: 2.71–4.38)]; higher rates of treatment [2.98 (2.34–3.79)]; more satisfaction with care; lower depression severity; less functional impairment and greater quality of life.
Campbell 1999 ^276^ | To review the effectiveness and problems of programs providing cancer care in rural and remote areas | This review searched for all programs providing rural cancer care services. Programs with shared care of patients in rural areas between primary care physicians and specialists in cancer care were included in the review. The review was unable to make any recommendations about the provision of shared care services for cancer in remote and rural areas due to the limitations of article designs and the variability of outcomes reported.
Crawford 2004 ^252^ | To identify factors that promote or impede continuity of care for patients with severe mental illness | Most of the evidence in this review came from qualitative articles that identified factors that are important for continuity of care. Meta-analyses of care coordination interventions such as case management, assertive community treatment and community mental health teams suggest that use of such interventions can decrease the likelihood that patients will lose contact with services.
Dennis 2004 ^251^ | To assess the effectiveness of interventions to prevent postpartum depression | Only one article in the review reported on an element of care coordination: team midwifery. There were no significant differences between the two groups (team midwifery versus standard care) with respect to depression scores. There was insufficient evidence to recommend any of the interventions studied.
Draper 2000 ^255^ | To evaluate the outcomes of acute service delivery to older people with mental disorders | This review provided on overview of the provision of old age psychiatry services in the hospital and the community. One section reported results from 5 randomized controlled trials that provided these services in a community setting. These results indicate that community old age psychiatry services are effective.
Druss 2006 ^256^ | To evaluate interventions to improve general medical care in patients with mental and addictive disorders | The review provided an overview of all interventions designed to improve medical care. One study included a case manager and one included a multidisciplinary team with a facilitated referral to the community. The first study reported an improvement in the physical score of the SF-36 in the intervention group; the second study reported no difference between groups.
Duffy 2004 ^250^ | To assess the evidence on nonpharmacological strategies for heart failure management | This review assessed all nonpharmacological approaches to heart failure management, including those that were not specifically related to care coordination. Eight of the 15 included articles appeared to have some element of care coordination: multidisciplinary or case management. Overall, there appeared to be improvement in quality of life and hospital admissions in those articles with a care coordination component.
Eastwood 1996 ^277^ | To assess the effectiveness of different methods of organization of asthma care | The review evaluated different methods of organizing asthma care, one of which was shared care between general practitioners and specialists. Only 1 of the 27 included articles reported this intervention and suggested that the effectiveness of shared care is comparable to conventional outpatient care. Overall, the review reported a lack of conclusive evidence favoring any particular way of organizing asthma care.
Gilbody 2003 ^269^ | To evaluate the effectiveness of educational and organizational interventions to improve the management of depression | Improved treatment adherence and/or improved depression outcomes were seen with the more complex interventions: collaborative care, quality improvement (both organizational and educational interventions included), case management, pharmacist-provided information and education, guideline implementation strategies that were accompanied by complex organizational interventions.
Gonseth 2004 ^260^ | To assess the effectiveness of disease management programs in reducing hospital re-admission among elderly patients with heart failure | This review included all disease management programs; however, only 8 of the 54 included articles reported some element of care coordination. The effectiveness of these specific articles was not analyzed. Overall, meta-analysis of 27 RCTs showed significant decrease in re-admission for heart failure or cardiovascular cause [RR 0.70, (95% CI: 0.62–0.79], all-cause readmission [0.88 (0.79–0.97)] and readmission or death [0.82 (0.72–0.94)] for participants in disease management programs compared to usual care. 10 of these articles estimated costs and results indicated that the implementation of a disease management program was cost-effective. Similar results were observed in the non-randomized trials. These results were observed among a heterogeneous group of patients and in diverse health care systems.
Griffin 1998 ^274^ | To assess the effectiveness of general practice versus hospital care for diabetes | This review included “shared care” as an intervention strategy; however, this was not defined. Two of the 5 included articles reported some element of care coordination; however, the review did not analyze the effect of this on outcomes. Overall, the review reported the effectiveness of computerized recall with prompting in improving outpatient care in the short term.
Halcomb 2004 ^268^ | To describe the role of practice nurses in heart failure management | The authors identified two articles in which nurses played a role in coordinating care as part of a multifaceted intervention. Care coordination promoted follow up and decreased hospitalization but did not affect health outcomes.
Handford 2006 ^257^ | To assess the effectiveness of the setting and organization of care on outcomes among patients living with HIV/AIDS | The authors identified three studies evaluating case management and six studies evaluating either multidisciplinary or multi-faceted care. Case management was defined differently for each study but always included a distinct case manager; multidisciplinary care involved use of two or more providers other than standard clinician; multi-faceted care was the use of two or more treatment programs other than standard clinician care. All three case management studies showed improvements in selected outcomes (mortality, medication use, continuity of care); one study showed no difference in health care utilization use. Multidisciplinary or multi-faceted care studies showed mixed results for use of medications and health care utilization with some studies associated with increased used of medications and others not.
Harding 2005 ^249^ | To assess the effectiveness of different models of providing palliative care on outcomes for patients with HIV/AIDS | The review included all models of palliative care and did not search specifically for care coordination interventions. 15 of the included 34 articles had some element of care coordination: multidisciplinary teams, case management, integrated care. However, because the analysis did not focus specifically on the coordination elements, it is not possible to draw any conclusions about the effect of care coordination on patient outcomes. Overall, the evidence indicated that palliative care at home and inpatient hospice significantly improved pain and symptom control, insight, spiritual well-being and anxiety.
Harvey 2001 ^278^ | To determine the effectiveness of existing interventions in improving health professionals' management of obesity or patient outcomes | The review searched for interventions aimed at professionals (e.g., education, reminders) as well as organizational interventions (e.g., multidisciplinary teams). Only one article that primarily addressed organizational interventions was included. This article aimed at improving collaboration between general practitioners and a hospital based obesity clinic through shared care and integration of services. This article “indicated some positive effects in the short term....but these were not sustained over the long term”
Hastings 2005 ^279^ | To assess the effectiveness of interventions aimed at improving outcomes for elderly patients discharged from the emergency department (ED) | The review included five observational, descriptive studies and six RCTs that met our definition for care coordination. Of these, three RCTs reported improvements in functional status of intervention patients. All three studies included use of a specially trained nurse to perform geriatric assessment and home-based care. The review also reports that the targeting of high risk patients may result in interventions being more effective.
Heideman 2005 ^258^ | To assess effectiveness of interventions aimed at improving diagnosis and management of patients with anxiety disorders by general practitioners (GP) | The review assessed the effectiveness of professional and organizational interventions to improve care for patients with anxiety disorders. It included two studies on collaborative care; one of which appeared to have a positive effect on anxiety outcomes. The intervention for this study included a psychologist working collaboratively with the GP to provide care.
Hwang 2005 ^259^ | “To summarize the existing evidence on interventions to improve health-related outcomes in homeless people” | The review studied all interventions assessing health-related outcomes among homeless people. It included 13 studies that had some component of case management and 6 studies that included the use of assertive community treatment teams. Overall, the review reported improved outcomes among interventions providing coordinated treatment and support.
Ingersoll 2005 ^271^ | To summarize the literature on the role of nurses as care coordinators or case managers for patients with diabetes | Overall, there were 9 included studies; however, only 4 studies involved care coordination with multiple providers. The remaining 5 studies were substitution studies with nurses providing care instead of physicians. The care coordination studies showed improvements in the respective outcomes studied (HbA1c, hospital admissions). One study intervention involved the referral of patients by primary care physicians to specialist care and showed significant decreases in mean HbA1c levels of 1.75 (95%CI: 1.4%-1.9%).
Mitchell 2002 ^253^ | To examine factors related to the delivery of palliative care by general practitioners | The review provided an overview of general practitioner (GP) provision of palliative care, including their self-assessment and training. There was only one paragraph of the review that briefly addressed the importance of having GPs be a part of a palliative care team and suggested that when GPs and specialists work together there is an improvement in “diagnostic accuracy, application of evidence-based treatments, identification of systematic problems in the delivery of care, and improved ability to facilitate deaths at home.”
Ofman 2004 ^261^ | To assess the effects of disease management programs in patients with chronic disease | 58 of 102 (56% of the included articles) used multidisciplinary teams as a strategy for care; however, the specific effect of this strategy was not reported. Disease management programs incorporating different strategies such as patient education, provider education, reminders and provider feedback, appeared to be beneficial for diabetes, depression, hypertension, coronary artery disease, and hyperlipidemia. Less benefit was shown for COPD and chronic pain.
Pearson 2003 ^264^ | To assess the effectiveness of interventions to improve medication use in managed care settings | The review included articles with several interventions (including education, disease management, feedback) with most articles having multiple components. 25 of the 48 included articles reported disease management as the primary strategy. Disease management programs that focused primarily on depression and diabetes were effective in changing processes of care and improving short-term outcomes. These results did not extend to those articles that examined outcomes beyond 12 months.
Phillips 2004 ^270^ | To evaluate the efficacy of comprehensive discharge planning and postdischarge support on outcomes among older patients with CHF | 12 of the 18 included articles reported some element of care coordination: increased communication between providers, coordination of home care and case management. Interventions involving home visits or extended care services were associated with significantly lower readmission rates. The results should be interpreted with caution due to quantitative heterogeneity among articles within intervention effects.
Renders 2001 ^254^ | To assess interventions targeting health care professionals or the health care system on the management of diabetes | This review examined a variety of interventions to improve diabetes management that target providers and the organization. Included in the interventions were some articles that had some element of care coordination: multidisciplinary teams or case management. However, these components were combined with other strategies such as education or follow-up, making it difficult to assess the effect of the care coordination component on outcomes. Most articles that included these care coordination components as part of the intervention showed improved outcomes.
Sin 2003 ^265^ | To evaluate the effects of anti-COPD therapies (pharmacological and nonpharmacological) on patient outcomes | The review evaluated several commonly used anti-COPD therapies, including disease management programs. 8 of the included articles addressed disease management and the interventions mostly focused on education, self-management and follow-up. The intent of the disease management programs was to integrate and coordinate care. Overall, there was insufficient evidence to support the efficacy of disease management programs for patients with COPD.
Vergouwen 2003 ^272^ | To assess the effectiveness of interventions to improve adherence to antidepressant medications | 9 of the 11 collaborative care articles showed significantly improved adherence and depression outcomes in the intervention group vs. the control group. Most of the collaborative care interventions included components (such as increased patient education, treatment training, longer and more frequent visits) targeting the patient, physician and the health care system so it was not possible to know which components accounted for improved adherence.
Weingarten 2002 ^148^ | To evaluate the effectiveness of disease management programs for chronic diseases | The authors searched for articles evaluating disease management programs and then classified the different components of the intervention (e.g., patient education, provider education, reminders). None of the intervention components had a clear care coordination focus. Overall, the review reported that all of the interventions showed improvements in disease control and provider adherence to guidelines.

Mental Health. Two systematic reviews ^212,^ ^215^ examined the effect of assertive community treatment for patients with severe mental disorders (Table 14a). Assertive community treatment (ACT) has been defined as an approach to providing care that is characterized by a multidisciplinary team who care exclusively for a group of patients and share responsibility for their patients; it emphasizes team work and coordination of activities. Marshall and Lockwood ^212^ included 26 articles in their review of severely mentally ill patients, and found significantly improved outcomes for patients receiving ACT when compared to standard care, or hospital-based rehabilitation. Patients receiving ACT were less likely to be admitted to a hospital [0.59 (0.41–0.85)], be unemployed [0.31 (0.17–0.57)], or become homeless [0.24 (0.08–0.65)]. They were also more likely to remain in contact with services [OR: 0.51 (95% CI: 0.37–0.70)], and more likely to be living independently [0.46 (0.25–0.86)] when compared to standard care. These findings were consistent when compared to hospital-based rehabilitation; there was insufficient data to allow comparison to case management. In their meta-analysis of 19 articles that compared ACT to usual treatment, Ziguras and Stuart ^215^ found improved outcomes for assertive community treatment for severely mentally ill patients when compared to standard care (Table 14a). ACT had a significant positive effect on hospital days [Weighted mean r = 0.28 (95% confidence interval 0.24–0.32), p<0.001]; clients receiving ACT were likely to have more contact with mental health services [0.18 (0.12–0.23), p<0.001); lower dropout rates from mental health services [0.37 (0.27–0.46), p<0.001) and greater family satisfaction [0.46 (0.33–0.58), p<0.001). The review also found that both assertive community treatment and case management reduced hospitalization, but assertive community treatment was more effective in reducing hospitalization (p<0.001 for difference in effect sizes between the two groups).

Gunn et al. ^210^ also studied the effect of “system interventions” to improve recovery from depression (Table 14a). Their definition specifically included multidisciplinary teams and enhanced communication. They included eight trials that reported an increase in the proportion of patients recovering from depression in favor of the intervention group (range 10% to 33%); however the included studies did not account for attrition rates ranging from 5% to 50%.

Wadhwa and Lavizzo-Mourey ^214^ studied whether multidisciplinary teams and case management models improved care for patients with either mental or terminal illness. Neither of these interventions improved functional, clinical, or psychological outcomes; although multidisciplinary teams were effective in reducing hospitalizations among mentally ill patients (Table 14a).

Craven and Bland ^209^ evaluated the effectiveness of collaborative care for mental health; however, their definition of collaborative care includes health care professionals from different disciplines working together (Table 14a). The authors did not conduct a quantitative analysis, but provide data on each included study. They reported the following best practices for collaborative care: collaborative relationships at either a system-level or provider level require time, supportive structures and preparation; the degree of collaboration does not appear to predict outcomes; for collaboration to be effective, it should be paired with treatment guidelines; collaboration works best when clinicians and specialists are located in the same place; systematic followup was a strong predictor of positive clinical outcomes; patient choice about treatment may be important; and collaborative care interventions established as part of a research study may be difficult to sustain once the study is complete. Based on their review, it was not possible to evaluate the effectiveness of different elements of collaborative care.

Crawford et al. ^252^ reported their results of a review on providing continuity of care for patients with severe mental illness (Table 15). They included 60 articles identifying factors that either promoted or impeded the continuity of care among these patients; assertive community treatment and community mental health teams were among two of the care coordination strategies evaluated in some of the included articles. The authors categorized continuity of care as either longitudinal (continuity of care over a period of time, most likely characterized by the provision by a single provider) or cross-sectional (continuity of care between different services, characterized mostly by different providers or settings). Care coordination was an important component in the provision of care between primary and secondary services and between medical, social and other services. Unfortunately, most of the included articles did not define continuity of care and the articles addressing care coordination were limited to epidemiologic studies, nonrandomized trials and qualitative research. However, the review identified three meta-analyses of care coordination interventions, such as case management, assertive community treatment and community mental health teams (already included in our reviews that focused entirely on care coordination ^212,^ ^213,^ ^232^ ), which suggested that the use of such interventions can decrease the likelihood that patients will lose contact with services.

Heart Failure. McAlister et al. ^217^ and Holland et al. ^216^ both examined the effect of multidisciplinary teams on the management of heart failure patients (Table 14b). The review by Holland et al. ^216^ was an update of the McAlister review, with nearly double the included studies; therefore, there was considerable overlap of the included studies between the two reviews. McAlister et al. ^217^ did not provide a definition of multidisciplinary teams; however, Holland et al. ^216^ provided a clear definition. Both studies reported improvements in outcomes when interventions included multidisciplinary teams. McAlister et al. ^217^ reported that follow-up by a specialized multidisciplinary team reduced mortality [risk ratio (RR) 0.75, (95% confidence interval (CI) 0.59–0.96)], and hospitalizations (heart failure hospitalizations: [0.74 (0.63–0.87)]; all-cause hospitalizations: [0.81 (0.71–0.92)] (Table 14b). Holland et al. ^216^ reported similar results: multidisciplinary team interventions reduced all cause admission [RR: 0.87 (95% CI: 0.79–0.95), p=0.002], all cause mortality [0.79 (0.69–0.92), p=0.002] and heart failure admission [0.7 (0.61–0.81), p<0.001]. Holland et al. ^216^ also conducted subgroup analysis to determine the effect of setting and intensity. Interventions with a home-based component or those with telephone follow-up were more effective than those based in the hospital or clinic; home-based interventions showed reductions in both all cause [0.8 (0.71–0.89), p<0.0001] and heart failure [0.62 (0.51–0.74), p<0.001] admissions. Intensity of the intervention [high or low] and risk of the patient (high or low) did not appear to have an impact on effectiveness. It was not possible to evaluate the effect of specific intervention components; however, almost all the included interventions had two elements in common: symptom monitoring and self-management advice; and one-to-one patient education.

Pain Management. Higginson et al. ^220^ conducted a meta-regression and meta-analysis that included 44 articles to determine if palliative care teams improve patient outcomes and found significant improvements on patients' pain [OR 0.38 (95% confidence interval 0.23–0.64)] and other symptoms [0.51 (0.30–0.88)] (Table 14h).

Table 14h Summary of reviews with entire focus on care coordination interventions: palliative care

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Higginson 2003 ^220^ | To determine the effectiveness of palliative care teams on patient outcomes | Palliative care teams: “two or more health care workers, at least one of whom had specialist training or worked principally in palliative or hospice care” | 44 | Palliative care teams showed a significant improvement in pain [OR 0.38 (95% CI: 0.23–0.64)] and other symptoms [0.51 (0.30–0.88)]. There was a trend toward improved satisfaction and therapeutic interventions but this was not significant. There was insufficient evidence on economic outcomes. Overall, the review supported the positive effect of palliative care teams, though their effect size was small. | None

Stroke. Langhorne et al. ^219^ studied the effect of early supported discharge interventions among elderly stroke patients (Table 14j). They assessed whether team coordination and delivery (seven studies) or team coordination alone (two studies) had any effect on death or dependency in activities of daily living. They specifically examined the amount of effort that would be required by teams (staffing levels, case load) as well as how teams worked together (effect of weekly team meetings, an example of a coordinating process in one conceptual model on organizational theory described in Chapter 5). They found that coordination of teams through weekly team meetings were more effective in reducing the risk of death or dependency (OR: 0.70, 95% CI: 0.56–0.88, p=0.02) compared to no team coordination (Table 14j).

No Specific Clinical Focus. Lemieux-Charles and McGuire ^221^ conducted a systematic review to study the overall effectiveness of health care teams for a general patient population (Table 14k). They reported information on 12 studies evaluating the effectiveness of team versus no team interventions; nine studies evaluating team redesign interventions; and 12 multi-site field studies. The authors presented descriptions of the included studies and provided a narrative analysis. They suggested that the diversity and type of clinical expertise involved in team decisionmaking may account for improved patient care and organizational effectiveness. Some factors likely to influence staff satisfaction and perceived team effectiveness are: collaboration, conflict resolution, participation and cohesion. They also stated, however, that the existing evidence does not provide clear direction on how to design or maintain high-functioning teams. The lack of quantitative synthesis makes it difficult to evaluate their findings.

Table 14k Summary of reviews with entire focus on care coordination interventions: no specific clinical topic

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Lemieux-Charles 2006 ^221^ | To provide an overview of health care team effectiveness, including conceptualization of terms and a model on how to approach evaluating team effectiveness | Health care team: “a collection of individuals who are interdependent in their tasks, who share responsibility for outcomes, who see themselves and who are seen by others as an intact social entity embedded in one or more larger social systems (for example, business unit or corporation), and who manage their relationships across organizational boundaries” | 33 | Reported information on 12 studies evaluating effectiveness of team versus no team interventions; 9 studies evaluating team redesign interventions; and 12 multi-site field studies. The authors present descriptions of the included studies and provide a narrative analysis. They suggest that the diversity and type of clinical expertise involved in team decisionmaking may account for improved patient care and organizational effectiveness. Some factors likely to influence staff satisfaction and perceived team effectiveness are: collaboration, conflict resolution, participation and cohesion. They also state, however, that the existing evidence does not provide clear direction on how to design or maintain high-functioning teams. | The lack of quantitative results makes it difficult to assess the effectiveness of health care teams.
Richards 2003 ^222^ | To evaluate the effectiveness and costs of interventions that influence access to post-discharge services | - Geriatric consultation teams (GCTs): Provision of needs assessment by a multidisciplinary team followed by recommendations for subsequent patient care; - In-patient geriatric evaluation and management (GEM): Provision of needs assessment by a multidisciplinary team followed by implementation of treatment plans; concerned with patient management on the ward and recommendations for discharge planning.; - Outpatient GEM: Provision of needs assessment by a multidisciplinary team followed by implementation of treatment plans; patient management concerned with postdischarge care.; - Coordinator role: improve access to postdischarge services by combining the needs assessment and care plan with facilitating joint working with community agencies. | 3 | The review evaluated different methods of providing needs assessment and then linking the care plan with the provision of services after discharge from the hospital to determine the effectiveness of each method. There was some evidence that interventions that emphasized implementation of care plans after discharge were more effective than those that focused solely on needs assessment and discharge planning. | It is difficult to separate the effects of the post-discharge intervention and inpatient care received on outcomes since the two are inextricably combined.
| | | 7
| | | 5
| | | 5
Payne 2002 ^234^ | To assess the effectiveness of existing methods in the transfer of patient information between hospital and community | Discharge coordination and key worker: A key worker is one who can provide a point of contact for workers form hospital and community. Their presence is associated with improved discharge planning and coordination of services. | 31 | Current methods for transfer of patient information are inadequate. Information transfer can be facilitated by key workers; however, there was insufficient evidence to determine where the worker should be located (hospital or community) or their professional background. Community-based practitioners reported a lack of provision of appropriate and sufficient information. The barriers to effective information transfer identified were: lack of time and coordination, lack of discharge planning as a priority, fragmentation of information, and assumptions about the availability of family support post-discharge. | Most of the included articles were cross-sectional; US-based articles excluded.
Briggs 2006 ^236^ | To assess the effects of integration of primary care services on health care delivery and health status | Integration of services: “a variety of managerial or operational changes to health systems to bring together inputs, delivery, management, and organisation of particular service functions. Integration aims to improve the service in relation to efficiency and quality” | 5 | The results did not indicate any clear pattern of benefit or harm from integration of primary care services. Based on this review, no conclusions can be drawn about the effects of integration on health services delivery or health status in middle or low income countries. There was neither a strong case for or against integration of primary care services compared to the existing provision of health care. | None
Johri 2003 ^237^ | To analyze the impact of community-based long term care reforms and to common factors of an effective integrated care program for the elderly | Integrated care program: comprehensive integration of acute and long-term care services | 7 | Identified 7 successful integrated care programs. There was no synthesis of outcomes; results are presented in a narrative fashion describing each of the 7 included programs. The authors identified the following common elements in effective integrated care programs: a single entry point system, case management, geriatric assessment and multidisciplinary teams, and the use of financial incentives. | Only describes the successful integrated programs.
Zwarenstein 2001 ^240^ | To assess the usefulness of interprofessional education interventions when compared to education in which the same professions learn separately from one another | Interprofessional education: when members of more than one health and/or social care profession learn interactively together, for the explicit purpose of improving interprofessional collaboration and/or the health/well being of patients/clients; requires active learner participation and active exchange between learners from different professions | 0 | Since no articles met the inclusion criteria, there was insufficient rigorous evidence to evaluate the effect of interprofessional education on professional practice and health outcomes. | No included articles.
Grimshaw 2006 ^244^ | To evaluate the effectiveness of interventions to improve referrals from primary care to secondary care | No specific care coordination intervention studied | 17 | The authors included all interventions (education, organizational, financial) aimed specifically at influencing referral behavior. Improvements in the referral process may occur in the following instances: if guidelines for referrals are distributed with standard forms and involve consultants in education, or if a second opinion or enhanced services are provided before a referral. There was insufficient evidence to determine the effectiveness of financial interventions on referrals. | No specific care coordination intervention was studied
Gruen 2003 ^245^ | To determine the effectiveness of specialist outreach clinics | Specialist outreach clinics: planned/regular visits by a specialist practitioner from a usual location to primary care or rural setting; multifaceted outreach involved increased collaboration between primary care providers and specialists | 9 | Specialist outreach can improve measures of access (decreased cost, distance and travel time for patients), attendance to clinics, quality of care (guideline-concordant care and adherence to treatment) and health outcomes. The included articles can be regarded more as collaborative care initiatives since they utilized outreach as a way of integrating specialist and community services. | Most of the studies were conducted in an urban setting where specialist outreach is least likely to be useful; need for more research in rural settings.
McCusker 2006 ^246^ | To assess the effectiveness of comprehensive geriatric assessment interventions on reducing emergency department (ED) utilization | Comprehensive geriatric assessment: No clear definition of the intervention provided; appears to include all interventions that include geriatric assessment | 26 | The setting of the intervention and type of patient targeted may have affected rates of ED utilization. Interventions in primary care and/or outpatient settings or home care settings appeared to reduce ED utilization; whereas hospital-based interventions appeared to have little effect on ED utilization. Interventions with greater integration with primary medical care and those targeting high-risk patients also appear to reduce ED utilization. | No clear definition of the intervention term
Mitchell 2002 ^247^ | To assess the effectiveness of formal cooperation and liaison between general practitioners and specialists on patient outcomes | Organised cooperation: a formal arrangement that links general practitioners with specialists in the care of patients | 7 | Organised cooperation had mixed success for physical and functional health outcomes. There was a modest benefit of this intervention for some chronic mental health conditions. The costs associated with establishing this formal relationship could not be established. | None
Zwarenstein 2000 ^248^ | To evaluate the effect of interventions to improve nurse-doctor collaboration | Nurse-doctor collaboration: “collaboration was taken to mean sharing of information, coordination of work, and join decisionmaking on aspects of patient care” | 2 | There was limited evidence that structured nurse-doctor collaborations can improve length of stay without adversely affecting mortality. Neither of the two included articles provided evidence on improved collaboration. | Both reviews were conducted in an in-patient setting; no outpatient reviews were included.

Summary. Multidisciplinary teams have been shown to improve select patient outcomes in stroke, heart failure, severe mental illness, and terminal conditions. Specifically, the evidence suggests that among patients with mental illness, multidisciplinary teams can reduce hospitalizations and improve the rates with which clients remain in contact with services. Furthermore, in the clinical areas of heart failure and stroke, multidisciplinary teams can improve mortality and dependency. Hospital admissions are also reduced by this intervention for heart failure patients. For patients needing palliative care, a team approach can reduce symptoms. The evidence also suggests that multidisciplinary teams are more effective when team members deliberately coordinate their activities (e.g., schedule regular team meetings to facilitate exchange of information). ^219^

### Systematic Reviews Evaluating Disease Management as a Care Coordination Strategy

Background. In the reviews we identified, disease management has been defined in numerous ways and there does not appear to be a consensus from systematic reviewers about specific components that should be included in a disease management program. Disease management programs include the involvement of both patients and clinicians. The intent of all the disease management programs, however, is to improve the coordination of patient care, provide support to patients, and improve patient outcomes.

Results. Among the reviews that focused entirely on care coordination, we found ten reviews ^152,^ ^218,^ ^223^ ^230^ (Tables 16a–k) that evaluated the effects of disease management; we found eight reviews ^148,^ ^260^ – ^266^ among those that focused partially on care coordination using a disease management approach (Table 15).

Mental Health. Neumeyer-Gromen et al. ^223^ conducted a meta-analysis of disease management programs for depression (10 included articles). Disease management programs when compared with usual primary care, significantly improved depression severity [RR 0.75 (95% CI: 0.70–0.81)], adherence to treatment regimen [0.59 (0.46–0.75)] and patient [0.57 (0.37–0.87)] and provider satisfaction. They also reported on the cost-effectiveness of disease management programs which were reported in six articles that were deemed high quality by the authors. The cost utility ratios (not defined by the review) per quality adjusted life years ranged from $9,051 to $49,500 (Table 14a).

Heart Failure. We included four reviews ^224^ – ^227^ that studied the effectiveness of disease management programs on improving outcomes for patients with heart failure (Table 14b). Three of the four reviews conducted meta-analyses of the included studies; there was considerable overlap of the included studies across all four reviews. Disease management was not well-defined by any of the reviews, though two reviews ^225,^ ^227^ provided extensive descriptions of the disease management programs reported in each included study. The meta-analysis by Roccoforte et al. ^225^ found that disease management programs significantly reduced mortality [OR: 0.8 (95% CI: 0.69–0.93), p=0.003], all-cause re-admission rates [0.76 (0.69–0.94), p< 0.00001] and HF-related admission rates [0.58 (0.5–0.67), p<0.00001] compared to usual care. They also conducted sensitivity analysis looking at type of care provider and duration of intervention. Type of care provider had an effect on outcomes: mortality was reduced in multidisciplinary interventions [0.58 (0.44–0.75)] but not in nurse-based only interventions [0.93 (0.77–1.11]. Length of intervention had mixed results; long term interventions (> 6 months) appeared to reduce all outcomes; however, short-term (0–3 months) and medium term (3–6 months) also reduced admission rates. Yu et al. ^227^ categorized the disease management programs for heart failure patients into effective or ineffective on the basis of the characteristics for disease management programs recommended by the European Society of Cardiology (ESC). Effective programs (n=11) significantly decreased hospital readmissions by 29%–85% (mean 44.15 +/- SD: 14.36%); four programs significantly reduced mortality rates by 28%–78% (57.6 +/- 21.9%). They also reported that effective disease management programs improved quality of life and were cost saving. When comparing specific components of the intervention, effective disease management programs had the following: multidisciplinary teams, or care that involved both a cardiac nurse and cardiologist; provided a wider range of in-hospital care; were more likely to include home visits; and ongoing surveillance and management.

Diabetes. Knight et al. ^228^ also studied the effectiveness of diabetes disease management programs and found a mean reduction in glycated hemoglobin of 0.5 (95% CI: 0.3–0.6) percentage points among disease management programs (Table 14c). They also reported that programs associated with the greatest decrease in glycated hemoglobin involved pharmacists counseling patients and combined physician and patient interventions. The specific components of the interventions were not reported by the review.

Table 14c Summary of reviews with entire focus on care coordination interventions: diabetes

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Knight 2005 ^228^ | To determine the effectiveness of diabetes disease management programs | Disease management: “an approach to patient care that coordinates medical resources for patients across the entire health care delivery system” | 24 | There was a mean reduction in GHb of 0.5 (95% CI: 0.3–0.6) percentage points among disease management programs. Those programs associated with greatest decrease involved pharmacist counseling patients and combined physician and patient interventions. | Intervention components of included studies not reported; this limited the ability to determine which components played a key role.
Norris 2002 ^152^ | To examine the effectiveness of disease management and case management on diabetes outcomes and care | Disease management: “organized, proactive multicomponent approach to healthcare delivery...care is focused on and integrated across the entire spectrum of disease and its complications, the prevention of comorbid conditions, and the relevant aspects of the delivery system” | 27 | There was an improvement in GHb among both disease management [median net change: -0.5% (interquartile range: -1.35% to -0.1%)] and case management [-0.4% (-0.06% to -0.16%)] interventions. The case management interventions showed similar improvements in GHb when implemented with or without disease management interventions. Disease management showed improvement in provider screening and monitoring of selected outcomes (foot lesions, peripheral neuropathy, lipid concentrations, proteinuria, GHb and retinopathy). There was insufficient data to estimate the economic effects of the interventions. The findings for disease management are applicable to managed care and community settings in the US and Europe; findings for case management can only be applied to a US managed care setting. | None
| | Case management: “a set of activities whereby the needs of populations of patients at risk for excessive resource utilization, poor outcomes or poor coordination of services are identified and addressed through improved planning, coordination and provision of care” | 15
Greenhalgh 1994 ^242^ | To determine factors that contributed to the success or failure of shared care for diabetes | Shared care: care of patients is shared between a general practitioner and a specialist; care is characterized by enhanced information and exchange | 24 | Shared care that is structured and supported by a liaison team of general practitioners and specialists produced comparable levels of care to that provided in hospitals. Successful shared care programs appear to have the following common elements: tailoring of the shared care program to the needs and resources identified and a highly trained and experienced liaison nurse whose role it is to serve as a coordinator and facilitator in the program. | None

GHb: glycated hemoglobin

Table 14d Summary of reviews with entire focus on care coordination interventions: asthma

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Ram 2005 ^243^ | To assess the effectiveness of organized asthma care through primary care based asthma clinics | Organized asthma clinics: clinics are nurse-led and usually doctor supported | 1 | There was limited evidence from one article that organized asthma clinics can improve certain outcomes (provision of peak flow meters; reduction in waking at night with asthma attack). | Only one included article.

Table 14e. Summary of reviews with entire focus on care coordination interventions: cancer.

Table 14e Summary of reviews with entire focus on care coordination interventions: cancer

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Dohan 2005 ^192^ | To assess if navigation programs reduce barriers to disparities in cancer care | Navigation program: Not clearly defined; program aimed at reducing disparities in cancer care by addressing barriers | 62 | The review reports descriptions of 11 navigation programs to reduce barriers to cancer care and distinguish between the types of personnel who serve as navigators. There is limited data evaluating whether these programs address barriers; the existing literature “suggests that navigation is associated with improved rates of screening and follow-up, lower clinical stage of presentation, and higher patient satisfaction.” There is also some indication that “navigation services improve the clinic's ability to engage, track, and support patients and to develop communication and trust between clinics and disadvantaged populations.” | No clear definition of intervention studied

Norris et al. ^152^ studied the effectiveness of both disease management (27 articles) and case management (15 articles) on outcomes for patients with diabetes. They reported improvements in glycemic control [median net change: -0.5% (interquartile range: -1.35% to -0.1%)] and on screening for and monitoring of lipid concentrations [15.6% (4% to 39%)], dilated eye exams [9% (3% to 20%)] and foot exams [26.5% (10.9% to 54%)] among patients who received the disease management program. These improvements were applicable to adults with diabetes in both community clinics and managed care organizations in the U.S. and Europe (Table 14c).

Multiple Clinical Focus. Krause ^229^ examined economic outcomes of disease management programs (Table 14f). His meta-analysis included 67 studies on disease management programs for asthma, diabetes or heart failure. Overall, there was a positive effect on economic outcomes for disease management programs [effect size 0.311 (95% CI: 0.272–0.35)]. Program interventions were significantly different, with team-based interventions being the most effective: team-based [0.395 (0.32–0.47)], self-managed [0.916 (0.148–0.243)], and nurse-based [0.306 (0.253–0.359)]. Disease severity significantly affected economic outcomes of programs; interventions aimed at more severely and moderately ill patients were more effective than those aimed at patients with mixed severity [0.35 (0.306–0.396) versus 0.175 (0.142–0.208), respectively]. The effect on economic outcomes did not differ by disease type (asthma, diabetes or heart failure).

Table 14f Summary of reviews with entire focus on care coordination interventions: multiple clinical topics

Reference | Purpose | Care coordination intervention and definition | No. of articles | Results | Limitations to usefulness of review
Krause 2005 ^229^ | To determine the economic effectiveness of disease management programs | Disease management: “a system of coordinated health interventions and communications for populations with conditions in which patient self-care efforts are significant” | 67 | Overall, disease management programs had positive economic outcomes [effect size 0.311 (95% CI: 0.272–0.35)]. Program interventions were significantly different with team-based interventions being the most effective; self-managed [0.916 (0.148–0.243)], nurse-based [0.306 (0.253–0.359)] and team-based [0.395 (0.32–0.47)]. Disease severity significantly affected economic outcomes; interventions aimed at more severely and moderately ill patients were more effective than those aimed at patients with mixed severity [0.35 (0.306–0.396) vs 0.175 (0.142–0.208), respectively]. Effect on economic did not differ by disease type (asthma, diabetes or heart failure). | None

Rheumatoid Arthritis. Badamgarav et al. ^230^ evaluated the effects of disease management programs on the functional status of patients with rheumatoid arthritis (11 included articles). Overall, disease management did not improve functional status in patients with rheumatoid arthritis [Effect size: 0.27; 95% CI: -0.01–+0.54)]. The authors performed a sensitivity analysis to determine the effect of intervention intensity and duration. Interventions lasting longer than 5 weeks showed significant improvements in patient functional status [0.49 (0.12–0.86)] compared with those lasting <= 5 weeks [0.13 (–0.25–0.52)]; the intensity of the intervention did not have a similar effect (Table 14i).

Among the reviews that only partially focused on care coordination, eight included disease management programs (Table 15). ^148,^ ^260^ ^266^ Even though the definition of disease management as provided by the authors did not indicate a clear care coordination component, we included these reviews because the intent of all the programs was to improve the coordination of care through a disease management program. Furthermore, the descriptions provided for the interventions of the included articles within the reviews suggested a care coordination element. The reviews included heterogeneous interventions. Five of the reviews ^148,^ ^260,^ ^261,^ ^263,^ ^264^ reported an overall positive effect of disease management programs on outcomes. One review ^262^ reported promising results in its study of disease management programs for congestive heart failure, hypertension and hyperlipidemia-coronary artery disease. However, all of the reviews lacked a focused analysis on coordination-related activities and functions (e.g., clear definition, intensity, and structure).

Summary. Disease management programs appear to be effective in improving depression severity and adherence to treatment in patients with mental illness, glycemic control in patient with diabetes and mortality and re-admission rates in patients with heart failure. However, the heterogeneity of the definitions of disease management and the limited analysis on the specific components that may contribute to the effectiveness of disease management programs makes it difficult to interpret the findings with respect to the overall effectiveness of care coordination. Some of the reviews suggest improved outcomes based on patient targeting, multi-disciplinary teams, home visits, ongoing monitoring, pharmacist counseling on medications, and other less-well specified factors.

### Systematic Reviews Evaluating Case Management as a Care Coordination Strategy

Background. Case management (also referred to as care management in some instances - particularly in the United Kingdom — without any distinction in meaning) typically involves the assignment of a single person (case manager or “key worker”, so named in one study ^234^ ) who coordinates all aspects of a patient's care (e.g., providing information to multiple providers, seeing that the patient receives services in a timely manner etc.). The assumption behind case management is that having one person perform all the coordinating functions for a patient's care is likely to lead to improved coordination and possibly better outcomes.

Results. Among the reviews that focused entirely on care coordination, we found nine reviews ^152,^ ^214,^ ^215,^ ^222,^ ^231^ – ^235^ (Tables 16a–k) that evaluated the effects of case management on patient outcomes; among those reviews that only partially focused on care coordination, 12 ^249,^ ^250,^ ^252,^ ^254,^ ^256,^ ^257,^ ^259,^ ^267^ – ^271^ (Table 15) included case management as part of their included interventions.

Mental Health. Gorey et al. ^231^ evaluated the effectiveness of case management in improving outcomes for mentally ill patients (24 articles). They found that case management was effective in reducing re-hospitalization (mean effect size r-index: 0.277, standard deviation: 0.235). They also analyzed characteristics of case management (e.g., case load) and found that patients receiving more intense case management (case load of less than 15 per case manager) were 30% less likely to be re-hospitalized (Table 14a).

Wadhwa and Lavizzo-Mourey ^214^ studied whether multidisciplinary teams and case management models improve care for patients with either mental or terminal illness. Their results suggested that aggressive case management may be beneficial to patients with mental illness; however, they only included one study of case management among patients with terminal cancer which did not report any significant differences between the intervention and control group with respect to functional, clinical, or psychological outcomes (Table 14a).

Gilbody et al. ^269^ conducted a systematic review to evaluate whether organizational and educational interventions improve management of depression in primary care (Table 15). Since they were unsuccessful in their attempt to identify active components of successful interventions, they provided examples of successful and unsuccessful strategies that improved outcomes such as treatment adherence, depression outcomes and improved uptake of therapy. Most of the effective strategies presented in the review included some elements of care coordination. These were: collaborative care, defined as programs that included shared care among different care providers; stepped collaborative care, which included enhanced collaborative management by a psychiatrist in the primary care setting; quality improvement programs that included nurse case management and integration with specialist care; and case management, which was usually done by nurses and involved some element of follow up.

Heart Failure. Windham et al. ^233^ studied the effect of care management interventions for congestive heart failure among older patients (32 articles). The purpose of their review was to identify components of successful care management programs. They found that the key elements of an effective care management program (defined as a program in which most of the outcomes measured were significantly positive) included employing a physician and either a nurse or case manager to coordinate care; close monitoring and follow up of patients by nurses or case managers; and patient education combined with regular contact with a nurse or a physician (Table 14b).

Diabetes. Norris et al. ^152^ studied the effectiveness of both disease management (27 articles) and case management (15 articles) on outcomes for patients with diabetes. They reported improvements in glycemic control [median net change: -0.4% (interquartile range: -0.6% to -0.16%)] and provider monitoring in patients receiving case management.

No Specific Clinical Focus. Payne et al. ^234^ assessed the effectiveness of different methods of transferring information from the hospital to the community at the time of discharge in 31 articles (Table 14k). Presumably, good and effective information transfer forms the basis for improved care coordination. They found that using a key worker to facilitate information transfer improved the quality of the information provided, improved patient and caregiver satisfaction and increased “patient concordance” with services; however, they were unable to report sufficient evidence as to the professional background of such a worker or where this person should be located (community or hospital).

Summary. Case management as a care coordination strategy appears to improve patient outcomes for patients who have mental health problems, heart failure or diabetes. Among the included reviews, there was insufficient evidence to make a summary determination as to the training required for effective case managers (e.g., nurse, social worker, other provider), the ideal qualifications of effective case managers, and the specific duties that should be performed for case management to be effective. Close patient monitoring was identified as an important component in two reviews.

### Systematic Reviews Evaluating Integrated Care as a Care Coordination Strategy

Background. Integration of patient services either across diseases or between providers may improve care coordination. In both situations, health personnel work closely together and have the opportunity to share information, which should lead to improved coordination. The reviews included here focused on integrating care programs as an approach to improving care coordination.

Results. Among reviews that focused entirely on care coordination, we identified three ^235^ – ^237^ that evaluated the effectiveness of integrated care programs (Tables 16a, 16k). Jeffery et al. ^235^ studied the effect of integrating services for patients with mental illness and substance misuse (offering treatment to address both problems in a single location) (Table 14a). Briggs et al. ^236^ studied integration of primary care services (bring together different types of services, for example, packaging together services around a particular set of needs such as sexually transmitted disease services integrated with provision of contraceptives and/or family planning) (Table 14k). Both reviews found a lack of evidence regarding any clear benefit or harm from integrating services.

Johri et al. ^237^ reported a narrative synthesis of seven successful integrated care programs that provided care to the elderly (Table 14k). They did not summarize their findings but instead reported the key elements that were common across the seven programs. However, since they only reported on the successful programs and did not provide information on unsuccessful programs, it is difficult to analyze the effectiveness of integrated care programs from their review.

Summary. There is insufficient evidence to either support or refute the effectiveness of integrated care programs.

### Systematic Reviews Evaluating Interprofessional Education as a Care Coordination Strategy

Background: Interprofessional education is defined as the provision of training and education to professionals from different health and social areas, who learn together interactively. The aim of interprofessional education is to improve the coordination of patient care by improving the way professionals collaborate with each other. We considered this a care coordination strategy since it is an approach to improving patient care through improved coordination among multiple providers.

Results. Among the reviews that focused entirely on care coordination, we identified three reviews ^238^ – ^240^ that evaluated the usefulness of interprofessional education. Zwarenstein et al. ^240^ were unable to find any articles of methodological rigor that met their inclusion criteria (Table 14k). Reeves ^238^ extended the work by Zwarenstein et al. ^240^ by broadening the inclusion criteria to articles of all study designs. His review concluded that the evidence relating to the effectiveness of interprofessional education was “patchy” (Table 14a). Irajpour et al. ^239^ found that the evidence was “broadly supportive” of interprofessional education, but was insufficient to determine the best way to improve pain management (Table 14g).

Summary. There is insufficient evidence to determine the effectiveness of interprofessional education in improving collaboration among professionals.

## Narrative Syntheses of Systematic Reviews by Selected Clinical Topic, Population, and Setting

### Systematic Reviews of Care Coordination Strategies Among Patients With Mental Health Problems

Among our included reviews that focused entirely on care coordination, we found that care coordination interventions were most often studied among patients with mental health problems (mental illness, severe mental illness, depression). These patients are more likely to require complex care and services across different areas, thereby putting them at higher risk for poorly coordinated care. Among reviews that focused entirely on care coordination, we identified 13 reviews that focused on patients with mental health problems (Table 14a); among reviews that focused only partially on care coordination, we identified 15 reviews ^251,^ ^252,^ ^254^ – ^256,^ ^258,^ ^261,^ ^263^ – ^266,^ ^269,^ ^270,^ ^272,^ ^273^ that included patients with mental health problems (Table 15). A variety of different care coordination strategies were evaluated among this population: multidisciplinary teams, assertive community treatment, case management, collaborative care, disease management, integrated care programs and interprofessional education. Most of the reviews reported improved outcomes within each strategy studied. Several reviews compared different types of intervention, and no single strategy appeared to be more effective than other strategies. Since the interventions were not always described in enough detail, we are unable to draw any firm conclusions, but it appeared that strategies that included a more intense approach and involved community outreach (e.g., assertive community treatment, community mental health teams) were associated with positive outcomes, including better contact with services, fewer suicides, and reduced hospitalizations (or days hospitalized). Given the heterogeneity of the strategies studied and the lack of evidence pointing toward the success of one strategy over another, we were limited in our ability to interpret the findings with respect to the comparative effectiveness of any particular strategy for improving outcomes among patients with mental health problems.

### Systematic Reviews of Care Coordination Strategies Among Patients With Heart Failure

Among our included reviews that focused entirely on care coordination, we found nine reviews that focused on patients with heart failure or heart disease (Table 14b); among reviews that focused partially on care coordination, we identified five reviews ^250,^ ^260,^ ^262,^ ^268,^ ^270^ that included patients with heart failure (Table 15). Multidisciplinary teams and disease management were the two main care coordination interventions evaluated in these reviews. Four reviews ^224^ – ^227^ reported reductions in either readmission rates or mortality associated with disease management programs; four reviews ^216^ – ^218,^ ^241^ also reported the effectiveness of multidisciplinary teams in reducing readmission rates or mortality. However, there was considerable overlap of the included studies across these reviews. Holland et al. ^216^ reported significant reductions in all-cause admission, all-cause mortality and heart failure admission in interventions with multidisciplinary teams. They also reported that interventions with a home-based component or telephone follow-up were more effective than those based in the hospital or a clinic. Intervention intensity and patient risk did not have an impact on effectiveness. Roccoforte et al. ^225^ reported that disease management programs were also associated with reductions in mortality, and all-cause and heart failure readmission rates; additionally, mortality was significantly reduced in interventions provided by multidisciplinary teams but not in nurse-based only interventions. Length of intervention did not appear to have an impact on effectiveness. Our findings suggest that multidisciplinary teams and disease management programs are associated with improved outcomes for patients with heart failure. However, it is unclear what components of the interventions contribute toward this improvement since the findings regarding intensity of intervention were mixed and there was insufficient analysis on specific intervention components. Furthermore, most of the reviews did not provide a clear definition of the care coordination intervention. Although some specific components of multidisciplinary teams and disease management programs that were associated with positive outcomes were described in some of the reviews, further research is needed to assess relative contributions of these components for improving outcomes among patients with heart failure or heart disease.

### Systematic Reviews of Care Coordination Strategies Among Patients With Diabetes

Among our included reviews that focused entirely on care coordination, we found only three reviews that included patients with diabetes (Table 14c); among our reviews that focused partially on care coordination, we identified four reviews ^148,^ ^254,^ ^271,^ ^274^ that included patients with diabetes (Table 15). One review evaluated the effectiveness of disease management and case management on diabetes outcomes and care. ^152^ Norris et al. ^152^ found that both disease management and case management improved glycemic control (Table 14c); disease management also improved screening and monitoring of selected outcomes associated with diabetes; one review evaluated the effectiveness of diabetes disease management programs; ^228^ and the third review focused on identifying factors that contributed to the success or failure of shared care where care of the patient was shared by a general practitioner and a specialist. ^242^ Given the heterogeneity of the care coordination strategies evaluated and the few studies evaluating care coordination strategies for diabetes care, we are limited in our ability to synthesize the evidence and draw any definitive conclusions about the comparative effectiveness of different coordination strategies in improving outcomes among patients with diabetes. However, disease management and case management both showed improved outcomes, including reductions in glycated hemoglobin.

The remaining clinical areas (stroke, rheumatoid arthritis, asthma, pain management, and palliative care) were each studied in a single systematic review and so were not further synthesized.

### Systematic Reviews of Care Coordination Strategies Among Elderly Patients

Elderly patients are likely to have co-morbid conditions with poorly coordinated care and constitute a vulnerable population that we were interested in. Among the reviews that focused entirely on care coordination, we identified eight ^219,^ ^222,^ ^227,^ ^233,^ ^234,^ ^237,^ ^241,^ ^246^ that included articles on care coordination strategies to improve care for elderly patients (Tables 16a–k). Three studies focused on heart failure patients, and one on stroke patients. The remaining four did not have a specific clinical focus. An assortment of care coordination strategies were evaluated (e.g., multidisciplinary teams, case management, disease management, geriatric assessment and evaluation) in these reviews, and most reported improved outcomes associated with each individual strategy studied. Overall, the results indicate that the use of care coordination strategies may improve outcomes among elderly patients (particularly reduction in hospital admissions); however, the heterogeneity of the included strategies do not permit any further synthesis that would allow us to assess the effectiveness of one particular strategy over another.

### Systematic Reviews of Care Coordination Strategies Across Settings

When patient care is provided across different settings (e.g., discharge from the hospital or emergency department, patients are referred by primary care physicians for specialist care), it is possible for the care to be poorly coordinated. The transition of patient care from one setting to another constitutes another area we were interested in. Among the reviews that focused entirely on care coordination, we identified 12 reviews that studied different interventions specifically aimed to improve patient care across settings. Four reviews ^242,^ ^244,^ ^245,^ ^247^ evaluated the effectiveness of interventions that linked primary care with specialist care. Greenhalgh ^242^ evaluated the effect of shared care between general practitioners and specialists for patients with diabetes and reported the common elements of successful shared care programs (Table 14c). Mitchell et al. ^247^ evaluated the effect of a introducing a formalized arrangement to link general practitioners with specialists which they referred to as organized cooperation (Table 14k). They reported mixed success for physical and functional health outcomes and a modest benefit of this intervention for some chronic mental health conditions. Gruen et al. ^245^ studied the effects of regular, planned visits by a specialist practitioner from a usual location to a primary care or rural setting, a multifaceted outreach that involved increased collaboration between primary care providers and specialists. They found that this type of specialist outreach can improve measures of access (decreased cost, distance and travel time for patients), attendance to clinics, quality of care (guideline-concordant care and adherence to treatment) and health outcomes (Table 14k). Grimshaw et al. ^244^ studied interventions to improve referrals from primary care to specialists and reported that such improvements may occur if guidelines for referrals are distributed with standard forms and involve consultants in education, or if a second opinion or enhanced services are provided before a referral (Table 14k). There was insufficient evidence to determine which intervention is effective in linking primary care with specialist care.

Three reviews ^235^ – ^237^ evaluated the effect of integrating services received by patients in different settings into one setting (Tables 16a, 16k). The evidence was insufficient to determine the effectiveness of this strategy in improving patient care.

Four reviews ^219,^ ^222,^ ^234,^ ^246^ studied different interventions aimed at improving discharge planning for patients from hospital or the emergency department to reduce future readmissions. Langhorne et al. ^219^ reported the effectiveness of multidisciplinary teams in reducing death or dependency, for patients who had a stroke, when coordinating discharge from the hospital and providing post-discharge care and rehabilitation at home (Table 14j). McCusker ^246^ and Richards ^222^ both evaluated the use of comprehensive geriatric assessment and evaluation. Richards ^222^ found limited evidence that implementation of care plans after discharge was effective. McCusker ^246^ reported that interventions with greater integration with primary medical care were effective (Table 14k). Payne et al. ^234^ studied current methods for transfer of patient information at discharge and found them to be inadequate (Table 14k). They also reported insufficient evidence to determine where key workers, who can facilitate information transfer, should be located or what their professional qualifications should be. There was insufficient evidence to determine the effectiveness of a specific intervention in improving discharge planning to reduce future admissions.

One review ^192^ aimed at reducing disparities in cancer care by addressing barriers to care. The authors evaluated whether navigation programs reduce barriers. The review reports descriptions of 11 navigation programs to reduce barriers to cancer care and distinguish between the types of personnel who serve as navigators. There is limited data evaluating whether these programs address barriers; the existing literature “suggests that navigation is associated with improved rates of screening and follow-up, lower clinical stage of presentation, and higher patient satisfaction.” There is also some indication that “navigation services improve the clinic's ability to engage, track, and support patients and to develop communication and trust between clinics and disadvantaged populations.” (Table 14k)

In summary, the reviews studying transition of patient care across different settings evaluated a wide variety of interventions. The included interventions were not clearly defined in most of the reviews and only one review provided clear evidence of the effectiveness of its intervention (multidisciplinary teams for hospital discharge and post-discharge of stroke patients). The heterogeneity of the included interventions and the lack of quantitative analysis do not permit any further synthesis that would allow us to determine the effectiveness of any particular care coordination intervention to improve patient care across settings.

### Summary of Reviews With Partial Focus on Care Coordination

We included 32 reviews that had a partial focus on care coordination (Table 15). All of these reviews aimed at evaluating the effectiveness of a broad set of interventions across a variety of clinical conditions (e.g., nonpharmacological approaches to improving heart failure outcomes, strategies to improve medication use). As a result of these broad inclusion criteria, some of the articles included in these reviews involved interventions with a care coordination component. The care coordination strategies included in these reviews were highly heterogeneous and included the following: multidisciplinary teams, case management, disease management, integrated care, collaborative care and shared care, among others. The effect of these different strategies on outcomes was difficult to assess since most of the reviews failed to present analysis related to individual strategies but instead presented overall results for the broad set of included interventions.

## Narrative Synthesis of Recent Systematic Reviews by Coordination Component

Decisionmakers are interested in a more granular analysis of the effect of components of care coordination interventions. As described in Chapter 3, we developed a components list of essential tasks of care for a patient, associated care coordination activities, and features to support the activities. We reviewed 15 recent systematic reviews to assess if the reviews provided any information on specific components of the care coordination intervention. We mapped the information provided to the components deemed important when evaluating care coordination interventions (Table 16). Of the 15 reviews, 13 provided some detail on either the care coordination intervention or details on the individual studies included in the review; six reviews performed some analysis by selected components; four provided quantitative analysis.

When we apply this type of components list, we see that some interventions are aimed at (or incorporate delivery of) a subset of tasks and may have a few specific features to accomplish those tasks. Our ability to determine the presence or absence of each component reflects some assumptions, given the modest level of detail typically supplied for the intervention reviewed. Fairly uniformly, the systematic reviews provide little to no meaningful analysis at the component level. However, the application of a component list allows us to observe potentially important nuances. For example, one of the systematic reviews compared multidisciplinary teams to nurse-led teams, and found the former to appear more effective. We note that the tasks specified in the review were fairly limited - care planning and communication. The authors did not describe details about assessment, execution of care plan, monitoring and evaluation tasks, even though these activities may have been present. They noted that the nurse-led interventions tended to be more focused on patient education and follow-up visits or calls. Therefore the differences between the two types of interventions are more complex than simply “nurse-led” or “multidisciplinary”, and application of the list reminds us to examine each component that could affect the outcomes.

Summary. The current evidence base does not support a granular, component-level analysis from systematic reviews. Our impression from the literature reviews presenting detailed intervention descriptions of the primary studies is that they also will fall short of being able to address the question of what components of interventions are most critical for a given coordination challenge. Therefore, we anticipate that new primary research with appropriate (and likely novel) designs is necessary as a basis for later syntheses to provide definitive answers on what to do for each coordination challenge.

## 4D. Discussion

Our review of systematic reviews evaluating care coordination interventions suggests that many care coordination strategies have demonstrated effectiveness for selected outcomes within a particular clinical area, though the cumulative evidence across systematic reviews is less clear. Our review had the following key findings: First, care coordination interventions that have been evaluated are highly heterogeneous and tend to focus on several discrete clinical areas. Second, coordination strategies are defined differently across reviews, with no single definition for very similar strategies. Third, the evidence suggests that care coordination interventions can improve outcomes in different diseases (mortality and hospital re-admission in patients with heart failure, glycemic control in patients with diabetes, depression severity and treatment adherence in patients with mental illness, death or dependency in patients with stroke); however, there is a lack of evidence about the superiority of one particular strategy over another. Finally, there is insufficient evidence regarding the costs and cost-effectiveness of care coordination interventions. In summary, the diversity of the care coordination interventions evaluated, the heterogeneity of the definitions of the interventions, and the diversity across clinical conditions and populations limit our ability to synthesize the reviews; however, the evidence does suggest that multidisciplinary teams, case management and disease management programs are associated with improved outcomes.

## 4E. Limitations

This review has several limitations. First, we attempted to find all reviews that addressed some element of care coordination; however, we may have missed certain reviews that were not clearly focused on care coordination but which may have included articles that addressed care coordination as a result of a part of a broader search. Second, the included reviews were highly heterogeneous with respect to the care coordination interventions included. Many reviews failed to provide a clear definition of the care coordination intervention being studied. Additionally, a single care coordination term (e.g., disease management, assertive community treatment) was defined in different ways across different reviews, making it impossible to draw firm conclusions across reviews. Third, care coordination interventions were studied across several different clinical topics (heart failure, mental illness, diabetes, asthma, stroke, rheumatoid arthritis, pain management, palliative care) and it was unclear if interventions that were effective in one area would be effective in another area. Fourth, because reviews did not always have a clear focus on the analysis of the care coordination process or structure, it was difficult to interpret the effectiveness of care coordination in improving outcomes. Finally, we were limited by the methodology used for this chapter; our strategy of reviewing systematic reviews left us unable to review the primary findings of the articles included in the reviews. Therefore, it is possible that key pieces of information were missed since they were not provided in our included reviews.

## 4F. Summary Answers to Key Questions

### Research Question 5: Which Care Coordination Interventions Have Been Evaluated by Systematic Reviewers and How Were They Defined?

Among our included reviews, we identified various care coordination interventions that have been evaluated. The terms used to define the care coordination strategies were highly heterogeneous. The 43 individual reviews that focused entirely on care coordination referred to 20 different care coordination interventions. The most common strategy evaluated the use of multidisciplinary teams involving two or more providers from different specialties providing care to a group of patients (15 reviews); the terms applied to this strategy included multidisciplinary teams, team coordination, assertive community treatment, collaborative care, integrated programs, and shared care. The next most common strategy evaluated was disease management (ten reviews). It was defined variably or not at all in the included reviews and there did not appear to be a consensus about the components that should be included in a disease management program; however, the intent of all the disease management programs reviewed was to improve the coordination of patient care, provide support to patients, and improve patient outcomes. Finally, nine reviews assessed the role of case management (also referred to as care management) which typically involves the assignment of a single person (case manager or “key worker”, so named in one study) who coordinates all aspects of a patient's care (e.g., providing information to multiple providers, seeing that the patient receives services in a timely manner etc.). The qualifications and exact duties of case managers were poorly described in most reviews. Other strategies evaluated were integration of care (three reviews), and interprofessional education, defined as the provision of training and education to professionals from different health and social areas, who learn together interactively (three reviews).

### Research Question 6: What is the Evidence Regarding the Health Benefits of These Care Coordination Interventions as Summarized in the Systematic Review(s)? In Particular, is the Effectiveness of Care Coordination Interventions Related to the Setting in Which Care is Being Coordinated, the Component of Care Being Coordinated, or the Type of Disease or Patients for Whom Care is Being Coordinated?

Numerous care coordination interventions were evaluated across several diseases among the included systematic reviews, with different outcomes being reported within each review. Only three care coordination strategies-multidisciplinary teams, case management, and disease management-were evaluated across different clinical topics (e.g., heart failure, diabetes). Overall, the reviews reported a positive effect of these strategies on the outcomes studied (improved mortality and hospital readmission rates in patients with heart failure, improved glycemic control in patients with diabetes, improved service continuity in patients with mental illness). The remaining reviews evaluated other care coordination strategies (comprehensive, multidisciplinary program, integrated care, shared care, organized clinic) within a single clinical topic thereby limiting our ability to synthesize the evidence on the effectiveness of those care coordination strategies across clinical topics.

Interventions were conducted across different settings (home, community, outpatient clinic), with half of the reviews conducting interventions across multiple settings. One review ^216^ reported that interventions with a home-based component or telephone follow-up were more effective than those based in the hospital or clinic; however, due to a lack of analysis of the effectiveness of the care coordination intervention by setting, there is insufficient evidence to allow for any definitive conclusions regarding the effect of setting on the effectiveness of care coordination interventions. Furthermore, there was also insufficient evidence to determine the effectiveness of any particular care coordination intervention in improving patient outcomes across care boundaries.

In our included systematic reviews, care coordination interventions were frequently evaluated among patients with mental health problems. Several different strategies were studied among this population. Most of the reviews reported improved outcomes for each strategy; however, there was insufficient evidence that one particular strategy was more effective than others in improving outcomes. Care coordination interventions among patients with heart failure were also studied extensively, with multidisciplinary teams and disease management being the main interventions. While the reviews reported improved outcomes (mortality, hospital re-admission) associated with both these interventions, there was considerable overlap of the included studies across the reviews. The remaining reviews evaluated care coordination interventions among a diverse group of clinical conditions (diabetes, asthma, heart condition, stroke, rheumatoid arthritis) thereby limiting our ability to synthesize the findings for a given intervention.

Most of the included systematic reviews evaluated care coordination interventions in adults in the general population. Eight of the reviews evaluated interventions among the elderly, a vulnerable group more likely to have poorly coordinated care. The findings from these reviews suggest that care coordination strategies may improve outcomes among elderly patients (specifically by decreasing hospital admissions); however, the heterogeneity of the included strategies do not permit any further synthesis that would allow us to assess the effectiveness of one particular strategy over another.

The intervention descriptions provided by the most recent systematic reviews were generally not adequate enough for a complete categorization of the intervention components. The current evidence does not support a granular, component-level analysis from systematic reviews.

The overall quality of the included systematic reviews was very good, with most reviews providing detailed search terms, inclusion/exclusion criteria and appropriate synthesis of their included articles.

### Research Question 7: Have the Costs of Care Coordination Interventions Been Evaluated in any of These Systematic Reviews, and if so What is Known?

Costs were evaluated in approximately half of the included reviews that focused solely on care coordination; however, only one of the reviews reported findings on the cost-effectiveness/cost-benefit of the care coordination intervention. The evidence from this review suggests that comprehensive disease management programs are cost-effective for improving outcomes in patients with depression. One other review reported a summary effect size of the economic effectiveness of disease management programs indicating that disease management programs were economically effective. The remaining reviews provided some cost estimates of the interventions evaluated; however, the evidence was insufficient to allow for any definitive conclusions regarding the costs and benefits of the care coordination interventions evaluated.