# Definitions of Care Coordination and Related Terms

## 3A. Background and Objectives

Confusion about the definition of care coordination makes studying this topic particularly challenging. Throughout the project, experts have underscored the critical need for a consensus definition. Without a common definition, it was not feasible to determine what should be included as a care coordination intervention in our review of systematic reviews. As a result, we aimed in this chapter to develop a list of available definitions, discuss their common elements, and ultimately present a working definition to guide our review of systematic reviews. Although a more involved consensus process is advisable for developing a universally accepted definition, we expect that the development of our working definition will be a helpful initial step for others attempting standardization in this area.

## 3B. Methodological Approach

We adopted an iterative literature search approach to identify definitions of care coordination, from which we developed a preliminary working definition of care coordination. Table 4 presents examples of targeted literature search strategies of the PubMed^®^, CINAHL^®^, and Health and Psychological Instruments (HaPI) databases. Articles from these searches fell broadly into three categories: 1) presentations of explicit definitions or conceptual frameworks related to care coordination, 2) empirical studies that directly evaluated coordination processes, and 3) studies describing the development of measures of coordination processes. Given the breadth of coordination-related research identified in our preliminary searches, and because the purpose of this report was to provide a cross-cutting overview of the state of the science of care coordination research, searches were not used to perform a systematic review of primary studies of care coordination interventions. We instead retrieved selected articles from these searches for this chapter and Chapter 5 (conceptual frameworks), and did not attempt to be exhaustive.

Table 4 Initial search strategies used to identify definitions of care coordination

Database | Search criteria
PubMed | “Coordination” and ((provider*) or (physician*)) and (“care” or (practice*) or (service*) or (task*)) and (“communication” or (organization*) or “programming” or “feedback”)
| Coordinat* and “care” and ((theor*) or “model” or “framework” or (concept*) or (defin*))
| Coordinat* and “care” and measure* and (“testing” or “validation”)
CINAHL | ((Coordinat$ and care.mp and (instrument.mp or exp Instrument Validation/)
HaPI | Coordinat$ and care.mp

* and $ are truncation symbols so that all terms starting with the letters before the truncation symbol are searched. For example, searching with the term theor* would include terms such as theory and theoretical.

## 3C. Key Elements in Care Coordination Definitions

Our searches found more than 40 distinct definitions of care coordination that were extremely heterogeneous (Table 5).

Table 5 Definitions for care coordination and related concepts

Citation | Definition
AAP 1999 ^13^ | “Care coordination is a process that links children with special health care needs and their families to services and resources in a coordinated effort to maximize the potential of the children and provide them with optimal care.” (1999)
AAP 2005 ^68^ | “Care coordination is a process that facilitates the linkage of children and their families with appropriate services and resources in a coordinated effort to achieve good health.” (2005)
Allred 1995 ^89^ | “Coordination is the ability to achieve the requisite unity of effort or teamwork across individuals, departments, and organizations so that the activities necessary for the organization's success do not go unperformed. Coordination implies collaboration or an integration of efforts, of which communication among individuals and groups is the basis.”;“Coordination is the technique used to satisfy the information needs of the numerous and diverse providers (differentiation) that are required to contend with patient care problems that arise in a complex, rapidly changing, unpredictable, and uncertain practice environment.” (citing Charns 1976)
Allred 1995 ^90^ | “Coordination refers to the regulation of activity between the nurse and the case manager so that necessary patient activities do not go unperformed” (citing Charns 1976)
Bickell 2001 ^91^ | “We developed a conceptual framework that posited 6 dimensions of coordination for early-stage breast cancer: standardization of work, feedback mechanisms, patient support, monitoring the quality of care, information systems, and location of care sites.”
Bodenheimer 1999 ^92^ | “The PCP [primary care practitioner] as coordinator assists patients in receiving the full range of medical services from the multitalented team of specialists and other caregivers”
Bolland 1994 ^93^ | - “Coordination is a term that is often used without any exact referent, and in some cases, researchers report lack of coordination without either (a) indicating an empirical basis for their conclusions, or (b) indicating what empirical findings they would accept as evidence of coordination”;; - “Integrative coordination”: “when the interorganizational system is structurally fragmented, coordination is low; when it is structurally integrated, coordination is high”
Brown 2004 ^42^ | “The term ‘care coordination’ has no well-established definition. Rather, it is generally understood to mean a process of improving communication among the various medical professionals with whom patients come in contact and between these professionals and the patients themselves (and their families).”
Cassady 2000 ^94^ | “Coordination addressed only the actual integration of services between a primary care provider and specialty care, because consumers might not know the characteristics of the practice (structure) that facilitate coordination of care”
Chen 2000 ^32^ | - “There does not seem to be a clear, universally accepted definition of coordinated care for chronic illness.”; - “Coordinated care programs, by our definition, are those that target chronically ill persons ‘at risk’ for adverse outcomes and expensive care and that meet their needs by filling the gaps in current health care. They remedy the shortcomings in health care for chronically ill people by (1) identifying the full range of medical, functional, social, and emotional problems that increase patients' risk of adverse health events; (2) addressing those needs through education in self-care, optimization of medical treatment, and integration of care fragmented by setting or provider; and (3) monitoring patients for progress and early signs of problems. Such programs hold the promise of raising the quality of health care, improving health outcomes, and reducing the need for costly hospitalizations and medical care.”
Cooley 2003 ^95^ | Coordination themes: role definition, family involvement, child and family education, assessment of needs/plans of care, resource information and referrals, advocacy
Fletcher 1984 ^96^ | - Coordinated care components: “written evidence that the other physician was aware of the primary physician's involvement, and that 1) the primary physician arranged visit to the other physician or knew about it beforehand; or 2) the primary physician was aware of the patient's visit to the other physician after the visit”; - Fletcher et al. “did not consider these components acts of coordination in themselves, but rather conservative markers of the coordinating process.”
Flocke 1998 ^97^ | “Coordination of care refers to the incorporation of information from referrals to specialists and previous health care visits into the current and future medical care of the patient.”
Flocke 1997 ^98^ | “Coordination of care is defined as the patients' perception of their physician's knowledge of other visits and visits to specialists, as well as the follow-up of problems through subsequent visits or phone calls.”
Forrest 2000 ^99^ | “Optimal coordination involves the documentation of patient care activities, interprovider communication, and the integration of service delivery into a single medical home” (citing Institute of Medicine 1996 ^100^ and Starfield 1998 ^101^ )
Gilbert 1995 ^102^ | “Coordinated care is a multi-disciplinary approach that focuses on achieving patient outcomes within effective time frames which have been established by all members of the health care team involved in the treatment of specific patient populations. The key to this model is the development of critical paths which serve as a guideline for interventions to be accomplished to achieve the desired outcome. Deviations from the critical path are documented and analyzed to determine system issues. An assigned coordinator is responsible for initiating the critical paths and monitoring patient progress.”
Gittell 2000 ^103^ | “Relational co-ordination: co-ordination carried out by front-line workers with an awareness of their relationship to the overall work process and to other participants in that process. Relational co-ordination is characterized by frequent, timely problem solving communication and by helping, shared goals, shared knowledge, and mutual respect among workers. It is essentially a network of communication and relationship ties among workers, and can be thought of as a form of organizational social capital likely to enhance organizational performance.”
Gittell 2002 ^104^ | “Coordination may be facilitated by certain design elements but it is more fundamentally a process of interaction among participants...Relational coordination reflects the role that frequent, timely, accurate, problem-solving communication plays in the process of coordination, but it also captures the oft-overlooked role played by relationships...specifically, coordination is carried out through relationships of shared goals, shared knowledge, and mutual respect.”
Gittell 2004 ^105^ | Coordination is an “activity that is fundamentally about connections among interdependent actors who must transfer information and other resources to achieve outcomes”
Glasgow 2005 ^106^ | Follow-up/Coordination: “Arranging care that extends and reinforces office-based treatment, and making proactive contact with patients to assess progress and coordinate care”
Guastello 2005 ^107^ | “Coordination occurs when two or more people do the same or complementary tasks simultaneously.”
Healey 2004 ^108^ | “Coordination refers to a team's performance enhancement of function through managing and timing activities and tasks.”
Hoenig 2001 ^109^ | “Coordination of care was measured according to (a) number of different staff meetings, b) how often the therapists at team meetings (rounding therapists) were the same therapists treating the patient (treating therapists) versus someone providing a report from the treating therapist, and (c) use of paid escorts to transport patients to therapy.”
IOM 1996 ^100^ | “Coordination ensures the provision of a combination of health services and information that meets a patient's needs and specifically means the connections within and across those services and settings - putting them in the right order and appropriately using resources of the community. The goal is to focus on interactions with patient and family and their health concerns, clarify clinical care decisions, advise hospitalized patients and their families, and help patients and their families cope with the social and emotional implications of disease or illness.”
IOM 2004 ^110^ | “To establish and support a continuous healing relationship, enabled by an integrated clinical environment and characterized by the proactive delivery of evidence-based care and follow-up. Clinical integration is further defined as the extent to which patient care services are coordinated across people, functions, activities and sites overtime so as to maximize the value of services delivered to patients. Coordination encompasses a set of practitioner behaviors and information systems intended to bring together health services, patient needs, and streams of information to facilitate the delivery of care in accordance with the six aims set forth in the Quality Chasm report. Such coordination can be facilitated by procedures for engaging community resources, including social and public health services.” (synthesized from several sources ^2,^ ^6,^ ^111^ )
Kibbe 2001 ^112^ | “Care coordination is a term that encompasses a variety of care management methods - from case to disease management - that aim to improve the quality of care provided to patients with chronic illness while decreasing avoidable costs associated with their delivery...care coordination is viewed by its practitioners (mostly specially trained nurse case managers) as a method for decreasing the fragmentation of health delivery sites and, through better planning and monitoring of patient care plans, ending the confusion and uncertainty that often attend care for patients with complicated illnesses or multiple medical problems. Care coordination also is a means to increase the likelihood that patients with chronic illness will achieve recommended care and adhere to best practices for specific illnesses and conditions. Finally, care coordination is a collaborative and team approach that recognizes the importance of keeping the attending physicians informed while enhancing information sharing and communication among providers so as to maintain a fabric of continuity.”
Kinsman 2000 ^113^ | - “[Coordination] pertains to the systems aspect of the service delivery system.”; - “[Coordination requires models of team functioning. The complexity of spina bifida...requires the perspectives, knowledge bases and skills of a wide variety of professionals. How these different groups work together and integrate is what comprises [coordination].”
Kodner 2002 ^114^ | “Coordination, the middle ground in integrated care, entails the development of formal structures and mechanisms to bridge the gap between providers and institutions, as well as work around system weaknesses and barriers, without fundamentally changing these systems per se. A variety of techniques are employed, including uniform assessment procedures, care management, joint care planning, team care, standardized guidelines and protocols, and common clinical and service records.”
Lima & Brooks 1985 ^115^ | Assessment of coordination between medical and community mental health center: “Coordination of care with the [community mental health center] was noted as present if a telephone call, or letter, or a review of the psychiatric chart had taken place...coordination with the medical clinic could have taken place through a telephone call, a letter, or a review of the medical chart.”
Longest & Klingensmith 1994 ^116^ | - “Conceptually and historically, coordination has been defined as the conscious activity of assembling and synchronizing differentiated work efforts so that they function harmoniously in attainment of organization objectives.”; - Extending the definition to encompass both inter- and intraorganizational situations: “coordination is conscious activity aimed at achieving unity and harmony of effort in pursuit of shared objectives within an organization or among a set of organizations participating in a multiorganizational arrangement of some kind.”
Malone & Crowston 1994 ^117^ | “Coordination is managing dependencies between activities.”
Massachusetts Consortium for Children with Special Health Care Needs Care Coordination Work Group 2006 ^118^ | “Care coordination is a central component of an effective system of care for children and youth with special health care needs and their families. Care coordination is an ongoing process which engages families in development of a care plan and links them to health and other services that address the full range of their needs and concerns. Principles of care coordination reflect the central role of families and the prioritization of child and family concerns, strengths and needs in effective care of children with special health care needs. Activities of care coordination may vary from family to family, but start with identification of individual child and family needs, strengths and concerns, and aim simultaneously at meeting family needs, building family capacity and improving systems of care.”
McGuiness & Sibthorpe 2003 ^119^ | “We conceived of coordination as a complex construct, incorporating both overall impacts of care as well as discrete key processes. Questionnaire items were designed to capture aspects of coordination that were grouped into six domains: identification of need, access to care (drugs, tests or imaging, and services); patient participation, including empowerment; patient-provider communication; inter-provider communication; and global assessment of care.”
National Quality Forum 2006 ^120^ | “Care coordination is a function that helps ensure that the patient's needs and preferences for health services and information sharing across people, functions, and sites are met over time. Coordination maximizes the value of services delivered to patients by facilitating beneficial, efficient, safe, and high-quality patient experiences and improved healthcare outcomes.”
Ohlinger 2003 ^121^ | Coordination components: communication, multidisciplinary input, consistency in practice
Parchman 2005 ^122^ | “Coordination of care refers to the degree to which information from various sources is incorporated by the physician into the care the patient receives.”
Parkerton 2004 ^123^ | “Practice Coordination” is referred to as “system continuity”
Pollack 2003 ^124^ | Coordination construct: “Degree to which relationships with other units in the hospital facilitate ICU performance”
Reid 2002 ^125^ | - “The core element of the interaction between an individual and health care providers helps distinguish continuity from other concepts that are often used synonymously. For instance, if the focus is on the interaction among providers, then the concept reflects co-ordination and integration not continuity. As [the] Director of Research at the Alberta Mental Health Board ... said, ‘Continuity is how patients experience co-ordination between providers.’”; - Management continuity refers to “the provision of separate types of healthcare over time in ways that complement each other so required services are not missed, duplicated or poorly timed.”; - “Although co-ordination refers specifically to the interaction between providers - and thus is not strictly continuity - it should result in the patient sensing ‘management continuity’, which means the care received from different providers is connected in a coherent way.”; - Management “continuity is measured by the extent to which care is given in the correct sequence, at the proper time and in the clinically appropriate manner.”
Rosenbach & Young 2000 ^50^ | - “There is no standard definition of care coordination.”; - “Care coordination programs tend to use a broader social service model that considers a patient's psychosocial context (such as housing needs, income, and social suppor may coordinate a full range of medical and social support services offered within and outside the managed care plan...typically arrange covered and non-covered services for patients.”
Shortell 1994 ^126^ | “Coordination refers to the extent to which functions and activities both within the unit and between units are brought together in a way that promotes cost-effective continuous care.” (citing Longest & Klingensmith 1994 ^116^ )
Sprague 2003 ^127^ | “All of these concepts [disease management, case management, care coordination, care management] have in common the principle of getting a person clinically appropriate care in a timely manner without wasting resources. Care coordination seeks primarily to help a patient navigate the system, working across care settings and providers and frequently accessing other services, such as personal care or community programs, as well.”
Starfield 1979 ^128^ | “Coordination of care was defined as the recognition of information (problems, therapies, intervening visits and tests) about patients from one visit to a follow-up visit.”
Temkin-Greener 2004 ^129^ | “The degree to which: work activities within a team are coordinated through formal plans, protocol, schedules; and face to face interactions are perceived as effective.”
U.S. Department of Veterans Affairs Office of Care Coordination ^84^ (Accessed August 29,2005) | “Care coordination in VHA is the wider application of care and case management principles to the delivery of health care services using health informatics, disease management, and telehealth technologies to facilitate access to care and improve the health of designated individuals and populations with the intent of providing the right care in the right place at the right time”
Van de Ven 1976 ^130^ | “Coordination means integrating or linking together different parts of an organization to accomplish a collective set of tasks.”
Wehr 2000 ^131^ | - “No validated measure of the quality of care coordination exists. Indeed, there is no single, generally accepted definition of ‘care coordination’.”; - “Care coordination was ‘opening doors’ to needed services for Medicaid enrollees and helping them with non-medical problems that could compromise their health.”; - “The purpose of care coordination is to assist persons with special health care needs and their families gain access to services covered under their Medicaid managed care plan and to other services available in their communities.”; - “Care coordination is support by an information system dedicated to care coordination and linked to other MCO information systems...requires a written plan of care based on a comprehensive assessment of the goals, capacities, and medical condition of the consumer and the needs and goals of family caretakers...includes monitoring to assure that services are received, to identify problems in the quality of care, to reassess and revise care plans, and to advocate on behalf of enrollees and family caretakers.”
Wenger 2004 ^132^ | Coordination is a “'process by which the elements and relationships of medical care during any one sequence of care are fitted together in an overall design....coordination involves the sharing of information about past findings, evaluation, and decisions, and the use of these in current management, among a number of providers to achieve a coherent scheme of management” (citing Donabedian 1980 ^133^ ); “matching the patient's needs with the appropriate level and type of medical, health, and social services” (citing JCAHO ^134^ )
Young 1998 ^135^ | “Coordination has been defined as the conscious activity of assembling and synchronizing differentiated work efforts so that they function harmoniously in attainment of organizational objectives.” (citing Haimann & Scott 1990)

From a review of these definitions and related studies, we identified five key elements comprising care coordination:

1 Numerous participants are typically involved in care coordination;
2 Coordination is necessary when participants are dependent upon each other to carry out disparate activities in a patient's care;
3 In order to carry out these activities in a coordinated way, each participant needs adequate knowledge about their own and others' roles, and available resources;
4 In order to manage all required patient care activities, participants rely on exchange of information; and
5 Integration of care activities has the goal of facilitating appropriate delivery of health care services.

The subsequent sections provide more detail about each of these five themes and how they relate to the health care setting.

### Participants Involved in a Patient's Care

Patients, family caregivers, physicians, nurses, pharmacists, social workers, other professionals, and support staff are often involved in delivery of health care services. As care needs become more complex, the number of potential participants and relationships among participants tends to increase. For example, care of an otherwise healthy patient with uncomplicated hypertension may be effectively managed by a single primary care physician. In contrast, care for seriously mentally ill patients could typically include physicians, nurses, social workers, psychologists, and pharmacists as core team members, but might also involve occupational or recreational therapists, dietitians, and chaplains depending on the specific patient's unique needs. ^136^ Similarly, management of care for frail community-dwelling elderly people optimally involves primary care physicians, nurse practitioners, clinic and home health nurses, social workers, occupational and physical therapists, dietitians, healthcare workers or aides, recreation therapists, and transportation workers, as evidenced by the Program of All-Inclusive Care for the Elderly (PACE). ^129^ Regardless of the number of participants, the patient and his or her needs are highlighted in care coordination definitions from several prominent organizations (e.g., AAP, IOM, NQF).

### Interdependence of Participants

Coordination for patients with complex health care needs often involves multiple participants who individually provide specialized knowledge, skills, and services^*^, and who together potentially provide a comprehensive, coherent, and continuous response to a patient's unique care needs.^**^ Three vignettes in a recent policy monograph by the American College of Physicians provide concrete examples highlighting the need for highly coordinated delivery of care when multiple participants depend on each other to provide appropriate care.^†^

* Organizational theory refers to this concept as “differentiation,” while health care often uses the term specialization.

** Similarly, organizational theory calls this concept “complementarity,” while the health care field would simply refer to this situation as providing patient care.

† In one of the cases, an internist asked a home healthcare nurse to assess an 85-year old woman with congestive heart failure, atrial fibrillation, type 2 diabetes mellitus, and possible dementia who had been deteriorating at home. After evaluating the patient, the nurse provided a video link to the patient's home and discussed the patient's situation with the internist who recommended that paramedics be called. While the paramedics prepared to transfer the patient to the hospital, the nurse notified the granddaughter. The patient was stabilized in the hospital, received a cardiology consultation, and was finally discharged home with ongoing monitoring supported by the home healthcare nurse, granddaughter, and internist.

### Adequate Knowledge About Available Resources and Participants' Roles

In order to make appropriate and timely medical decisions, participants in patient care activities require information about available resources (e.g., information systems, urgent care facility availability at a particular hour, standardized protocols). They also need adequate information about the experience, skills, plans, relationships, and preferences of all participants in order to determine a plan of care. ^13,^ ^95,^ ^103,^ ^104,^ ^113,^ ^116,^ ^137^ – ^139^ Clinicians involved in a patient's care may also have differing opinions about the roles they and others should assume in a patient's care. ^140^ Such discrepancies in perceptions about roles may lead to ineffective navigation back and forth across boundaries related to professions, geography, information systems, and organizations. ^8,^ ^9,^ ^12,^ ^141^ Effective coordination depends on adequate knowledge about roles and interdependencies among participants, ^117^ and ways to reduce system weaknesses and barriers through “bridging gaps” in information flow. ^142^

### Information Exchange Among Participants

Many of the definitions in Table 5 and studies of coordination interventions describe the pivotal role of exchange of critical patient-related information to facilitate effective coordination and medical decisionmaking. ^90,^ ^96,^ ^98,^ ^99,^ ^102,^ ^115,^ ^122,^ ^143,^ ^144^ Several studies have found that referring clinicians and specialists exchange information infrequently ^99,^ ^145,^ ^146^ and in non-standardized ways that may have adverse consequences for patient care. ^91^

### The Aims of Care Coordination

Most definitions of care coordination state a purpose for coordination. While approaches to coordinating care may vary greatly, the general intent of these strategies is to facilitate delivery of the right health care services in the right order, at the right time, and in the right setting. ^100,^ ^127,^ ^147^ Thus, care coordination occurs with the deliberate purpose of achieving a goal, such as the appropriate delivery of health care. Such delivery is particularly challenging wherever care must span role, physical, or time boundaries (e.g., the primary care/specialty care interface; the health care/community interface; continuity of services among various care sites such as inpatient, outpatient, and nursing home for the elderly; and transitions over time in cases such as adolescents moving into adult services).

## 3D. Proposed Working Definition of Care Coordination

We brought together the key elements found in the published definitions of care coordination and developed a definition that addresses these elements in a single brief statement. We also recognized that we would need to apply the proposed working definition to our literature review, and therefore attempted to keep it as simple and inclusive as possible. We purposefully chose to be broad and inclusive because we did not want to miss systematic reviews that might be relevant to any reasonable concept of care coordination. Narrower definitions may be useful for other purposes. In Section 3F, we introduce a components list to guide analysis of care coordination interventions.

We define care coordination as the deliberate organization of patient care activities between two or more participants (including the patient) involved in a patient's care to facilitate the appropriate delivery of health care services. Organizing care involves the marshalling of personnel and other resources needed to carry out all required patient care activities, and is often managed by the exchange of information among participants responsible for different aspects of care.

## 3E. Terminology Closely Related to Care Coordination

Several terms have often been used synonymously or in conjunction with care coordination: collaboration, teamwork, continuity of care, disease management, case management, care management, Chronic Care Model, and care or patient navigator. As is the case with care coordination, some of these terms lack a consensus regarding their definition and use in actual practice, ^64,^ ^125,^ ^148^ – ^150^ making it difficult to interpret how these concepts relate to each other and to care coordination. However, each of these models seeks to reduce fragmentation and improve health care delivery through better coordination. ^32,^ ^42,^ ^151,^ ^152^

Since the boundaries between these terms is blurry and each of the models they represent have substantial overlap with care coordination (as described in our working definition), we retained these additional terms in our searches to identify articles possibly relevant to care coordination.

### Collaboration

Numerous investigators have defined inter-professional collaboration ^153^ – ^163^ as interactions based on shared power and authority ^153^ and mutual respect for the unique abilities of each participant. ^154^ Ideal collaborative relationships among health professionals result in cooperative problem-solving and decisionmaking, ^155^ where participants achieve better patient care by working together than would have been possible individually. ^156^ While some classify coordination as a concept that is a subset of collaboration, ^163^ others describe collaboration as one possible approach to coordinating care. ^117^ Thus, there is agreement that the concepts of collaboration and coordination are related, even if there is ambiguity about how they overlap.

### Teamwork

In health care, multidisciplinary teams commonly include “individuals from different disciplines who contribute specialized knowledge in nonhierarchical relationships and who act according to situational demands rather than traditional organizational roles.” ^136^ Identifying determinants of successful teamwork in health care has generated much interest. ^164^ – ^168^ For example, mutual adjustments among participants to coordinate care is logically necessary as the level of interdependence among the participant's separate activities increases. ^130^

### Continuity of Care

This concept is often mentioned in conjunction with care coordination or care transitions, ^96,^ ^132,^ ^169^ and also has multiple definitions. ^170^ – ^178^ Described by some as the “existence of some thread, individual, practitioner, group, or medical record that binds together episodes of care,” ^96^ continuity of care has also been defined as “effective information exchange, within satisfactory patient-clinician relationships”. ^179^ While some investigators define coordination as one of several domains within continuity of care, ^180^ others suggest that coordination results from continuity of care. ^125^

The interested reader is referred to discussion papers ^125,^ ^181,^ ^182^ and a recent review commissioned by several Canadian organizations ^183^ for a synthesis of the conceptual work on continuity of care. In brief, their work organizes continuity of care into three dimensions: informational continuity, or the “use of information on past events and personal circumstances to make current care appropriate for each individual;” interpersonal continuity, defined as an “ongoing therapeutic relationship between a patient and one or more clinicians;” and management continuity, defined as a “consistent and coherent approach to management of a health condition that is responsive to patient's changing needs.” Continuity of care represents an individual patient's experience of coordination over time with either a single clinician or with multiple clinicians (i.e., the extent to which the appropriate care is perceived to occur at the right time and in the right order). ^125,^ ^181,^ ^183^

### Disease Management

The Disease Management Association of America defines this term as “a system of coordinated healthcare interventions and communications for populations with conditions in which patient self-care efforts are significant. Disease management supports the physician or practitioner/patient relationship and plan of care, emphasizes prevention of exacerbations and complications utilizing evidence-based practice guidelines and patient empowerment strategies, and evaluates clinical, humanistic, and economic outcomes on an ongoing basis with the goal of improving overall health.” ^184^ Full-service disease management programs include the following six components: processes to identify specific population, evidence-based practice guidelines, practice models based on collaboration between physicians and other supporting service providers, self-management education for patients, measurement of process and outcomes, routine reporting to provide a feedback loop among participants. ^184^ In addition, disease management and case management programs have been included together under the umbrella of “coordinated care models” in reports intended to guide the Medicare Coordinated Care Demonstration Projects. ^32,^ ^42^

### Case Management

The Case Management Society of America defines case management as “a collaborative process of assessment, planning, facilitation and advocacy for options and services to meet an individual's health needs through communication and available resources to promote quality cost-effective outcomes”. ^185^ According to a Mathematica report that included case management in its definition of care coordination, “case management implicitly enhances care coordination through the designation of a case manager whose specific responsibility is to oversee and coordinate care delivery [targeted to] high-risk patients [with a] diverse combinations of health, functional, and social problems.” ^32^

### Care Management

This term is often used interchangeably with care coordination. In a background paper, Mechanic states “care management programs apply systems, science, incentives, and information to improve medical practice and help patients manage medical conditions more effectively. The goal of care management is to improve patient health status and reduce the need for expensive medical services. The principal challenge is finding effective ways to change physician and patient behavior.” ^67^

### Chronic Care Model

Initially named by Wagner and colleagues as a “Model for Effective Chronic Illness Care”, the basic premise of this model is that “effective chronic illness care requires an appropriately organized delivery system linked with complementary community resources available outside the organization” and is sustained by productive interactions between multidisciplinary primary care teams and “activated patients.” ^142,^ ^149,^ ^186^ – ^189^ A multidisciplinary primary care practice team has responsibility for organizing and coordinating care through a number of activities: performing comprehensive patient assessments; helping patients set goals and solve problems for improved self-management; applying clinical and behavioral interventions that prevent complications and optimize disease control and patient well-being; and ensuring continuous follow-up. To achieve effective patient management, the Chronic Care Model promotes comprehensive system change encompassing six broad areas: health care organization, linkages to community resources, self-management support, delivery system redesign, decision support, and information systems. Further extensions (Barr et al's Expanded Chronic Care Model ^190^ , WHO Model of Innovative Care), ^191^ include components that provide more detail on community linkages, offer supplementary aims of population health through preventive services and health promotion, and add a policy environment level.

### Care Navigator or Patient Navigator

These terms appear on web sites of health care organizations, particularly for cancer care, and in reports in the medical literature. ^192^ Recent studies report patient navigator interventions in inner-city women with breast abnormalities, ^193^ a university hospital head and neck cancer service, ^194^ a community hospital using lay people as navigators for cancer patients, ^195^ and as part of a collaborative community health initiative for uninsured patients. ^196^ While there is no standard definition of a patient navigator, authors of a literature review recently recommend defining a navigator as “someone who helps assist patients overcome barriers to care,” instead of employing the other common service-based definition. ^192^ Thus, patient navigation refers to the assistance offered to patients in “navigating” through the complex health-care system to overcome barriers in accessing quality care and treatment (e.g., arranging financial support, coordinating among providers and setting, arranging for translation services, etc). The National Cancer Institute also emphasizes a patient-centric model, noting that “a navigator is someone who understands the patient's fears and hopes, and who removes barriers to effective care by coordinating services, increasing a cancer patient's chances for survival and quality of life.” ^197^ Although more commonly available for cancer patients, patient navigation is used for underserved patients with other chronic conditions.

One other related area deserves special mention: telehealth and information systems. As noted in Chapter 2, the VA's central care coordination program relies on the role of information technologies to connect patients to services. This approach is covered by two other AHRQ Evidence Reports, and is therefore not duplicated in our review. The RAND EPC produced both a searchable tool ^198^ and a review of the evidence from existing published articles regarding the costs, benefits, and barriers to implementing health information technologies. ^199^ The Oregon Health Sciences EPC recently updated an evidence report on telemedicine for the Medicare population that focused on health outcomes and access to care for store-and-forward, home-based and office/hospital-based services. ^200^ While neither of these reports directly addressed the role of information systems to improve care coordination, they both offer some relevant findings. The Oregon report identified several studies showing benefits of home-based telemedicine interventions in chronic diseases, apparently resulting partially from enhanced communication with health care providers and dependent to some degree upon changes in staffing as well as the technology enhancements. The RAND report concluded that the evaluative evidence base for effects of information technologies on patient-centeredness is sparse, and described only one study that commented on enhanced coordination. A recent overview noted that the emerging telehealth environment poses a critical need to clarify roles and assess skills for effective interaction between patients and clinicians. ^201^

## 3F. Components of Care Coordination

Peer reviewers of a draft of this report suggested that care coordination be broken into component parts for the purpose of analysis of care coordination interventions. Since there is no standard set of components of care coordination, we developed our own list of components that make up various care coordination interventions. We assembled this list from multiple sources, including the ongoing demonstration projects noted in Chapter 2, elements of our working definition and related terms discussed earlier in Chapter 3, ideas from the concepts present in frameworks described in Chapter 5, and recent work by the National Quality Forum (NQF) ^120^ and Mathematica under contract to CMS. ^202^ We then grouped related ideas and developed a more parsimonious list of tasks related to care coordination and features to support the tasks. The essential tasks are focused on the clinician-patient interaction (e.g., assess the patient), and the associated coordination activities (e.g., identify need for coordination), while the common features typically involve systems, resources or even policy changes to enable these tasks (e.g., personal health record to supply necessary information to multiple providers). Table 6 summarizes our component list and the correspondence of each component to the domains (and principles) from two other systems (NQF, Mathematica). The NQF system aimed to provide a framework for development of measures of care coordination, and drew from medical home concepts articulated by AAP, AAFP and ACP as well as other input from multiple sources. Mathematica has been evaluating best practices in care coordination to guide CMS demonstration projects, and continues to evolve a classification framework with readily observed program features, in order to relate domains of care coordination to program impacts.

Table 6 Components of care coordination

Component | NQF Domains and Principles | Mathematica Domains
ESSENTIAL CARE TASKS and Associated Coordination Activity
ASSESS PATIENT | Highlights specific populations more vulnerable to disconnected care [Principle] | Initial Assessment
Determine Likely Coordination Challenges
DEVELOP CARE PLAN Plan for Coordination Challenges and Organize Separate Care Plans | “Proactive Plan of Care and Follow-up- established and current care plan”[Domain] | Problem Identification and Care Planning
Plan for Coordination Challenges and Organize Separate Care Plans
IDENTIFY PARTICIPANTS IN CARE AND SPECIFY ROLES | “Healthcare ‘home’ - source of usual care selected by patient” [Domain] | Program Staffing
Specify Who Is Primarily Responsible For Coordination | | Provider Practice
COMMUNICATE TO PATIENTS AND ALL OTHER PARTICIPANTS | “Communication-available to all team members, including patients and family” [Domain] | Communication
Ensure Information Exchange Across Care Interfaces
EXECUTE CARE PLAN | | Service Arranging
Implement Coordination Interventions
MONITOR AND ADJUST CARE | | Ongoing Monitoring
Monitor For And Address Coordination Failures
EVALUATE HEALTH OUTCOMES | As appropriate, measurement targeted all participants [Principle] | Quality Management/ Outcomes Measurement
Identify Coordination Problems That Impact Outcomes
COMMON FEATURES OF INTERVENTIONS TO SUPPORT COORDINATION ACTIVITIES and Examples
INFORMATION SYSTEMS Electronic medical record; Personal health record; Continuity of care record, Decision support; Used for population identification for intervention | “Information systems - the use of standardized, integrated electronic information” [Domain] | Information Technology and Electronic Records
TOOLS | | Patient Education
Standard protocols, Evidence-based guidelines, Self-management program, Clinician education on coordination skills, Routine reporting/feedback
TECHNIQUES TO MITIGATE INTERFACE ISSUES | “Transitions/Handoffs - transitions between settings of care are a special case because currently they are fraught with numerous mishaps” [Domain]
Multidisciplinary teams for specialty and primary care interface; Case manager or patient navigators to network and connect between medical and social services; Collaborative practice model to connect different setting or levels of care; Medical home model to support information exchange at interfaces
SYSTEM RE-DESIGN
Paying clinicians for time spent coordinating care; Changes that reduce access barriers including system fragmentation, patient financial barriers - lack of insurance, underinsurance, physical barriers - distance from treatment facilities

The goal of our list of components of care coordination is to help answer the question: what intervention components are required for each permutation of specific circumstances that complicate the delivery of coordinated care? We could hypothesize that patients who have mental illnesses see multiple caregivers, and therefore interventions with components that emphasize communication among caregivers might be particularly important to successful coordination. In other words, an intervention without this active ingredient—an effective communication strategy, perhaps depending on a feature such as the proposed Continuity of Care Record ^203,^ ^204^ —would not improve coordination among mentally ill patients. Likewise, we might hypothesize that medication reconciliation is vital for frail elderly patients transitioning between settings, and that interventions with systems that support this activity (e.g., a standard procedure to review medications with a patient or family member prior to prescribing) would work better than those without such a component. As various interventions are developed, the common features list could be expanded-with new categories and more examples. In addition, the task categories may be more or less than needed.

We developed this list as a tool to characterize the presence and absence of intervention components in recent systematic reviews. We demonstrate the approach here with a recent article of an ongoing study, “Geriatric Resources for Assessment and Care of Elders (GRACE) model”, that was devoted entirely to a comprehensive description of an intervention to improve coordination and delivery of high quality care to low-income seniors, a group particularly vulnerable to system disconnects. ^205^ Table 7 shows our decomposition of this intervention into coordination-related components from our list.

Table 7 Application of component list to well-described primary study

Intervention Description | Component Categorization | Rationale
GRACE support team acts as catalyst, provides care management, and consists of a nurse practitioner and a social worker | Care Task: Identify Participants/ Specify Roles | Support team members specified and given role of coordinator
| Associated Coordination Activity: Specify Who is Responsible for Coordination
Upon enrollment, the GRACE support team meets with the patient in the home to conduct an initial comprehensive geriatric assessment | Care Task: Assess Patient | Comprehensive assessment anticipates social, medical and other needs for coordination
| Associated Coordination Activity: Determine Coordination Challenges
The support team meets with GRACE interdisciplinary team (including a geriatrician, pharmacist, physical therapist, mental health social worker, and community-based services liaison) to develop an individualized care plan including activation of GRACE care protocols for common geriatric conditions | Care Task: Identify Participants | Interdisciplinary team members identified explicitly
| Care Task: Develop Care Plan | Standard protocols are tools to support coordination with primary care physician and other participants
| Feature to Support Coordination Activities :Tools
The GRACE support team meets with the patient's primary care physician (PCP) to discuss and modify the plan | Care Task/Coordination Activity: Communicate/ Ensure Information Exchange Across Care Interfaces | Primary care-specialty care interface addressed with a technique— a meeting
| Feature to Support Coordination Activity: Technique to Mitigate Interface Issues
Collaborating with the PCP, the support team implements the plan | Care Task: Execute Care Plan
With support of electronic medical record and longitudinal Web-based care management tracking system, the GRACE support team provides ongoing care management and coordination of care across geriatric syndromes, providers, and care sites | Care Task/Coordination Activity: Monitor and Adjust Care/ Monitor and Address Coordination Failures | Electronic medical record (info system), a tracking tool (tool) and support team (technique) used to monitor coordination across providers and settings
| Features to Support Coordination Activity: Information Systems, Tool, Technique to Mitigate Interface Issues
The goal of the GRACE model is to optimize health and functional status, decrease excess healthcare use, and prevent long-term nursing home placement | Care Task: Evaluate Health Outcomes | Evaluation built into model, including measures to flag coordination issues
| Coordination Activity: Identify Coordination Problems that Impact Outcomes

## 3G. Summary Answers to Key Questions

### Research Question 3: What Definitions Exist for Care Coordination?

The term, “care coordination,” is referred to often in the health services literature, but is less frequently explicitly defined. The more than 40 definitions of coordination identified in our search pertain to a diverse set of patient populations, healthcare scenarios, and organizational situations. While definitions vary depending on their purpose and audience, they share common elements. We combined these elements into a working definition for application to our systematic review, and potential use by others. Table 8 shows how these common elements are specified in our working definition.

Table 8 Elements common to care coordination definitions, and linkage to our working definition

Common element | Phrase from our working definition
Coordination has a purpose or goal | “the deliberate organization...to facilitate the appropriate delivery of health care services”
Numerous participants involved in a patient's care | “organization of patient care activities between two or more participants involved in a patient's care”
Adequate knowledge about available resources and participants' roles | “organizing care involves the marshalling of personnel and other resources needed to carry out all required patient care activities”
Information exchange among participants | “managed by the exchange of information among participants”
Coordination is necessary when participants are interdependent | “participants responsible for different aspects of care”

### Research Question 4: What Definition Could be Formulated To Apply to Systematic Reviews?

Systematic reviews require clear definitions to determine reliably which articles are within the scope of a review. We chose to define care coordination to meet two objectives: 1) to incorporate the main elements of other definitions, and 2) to simplify decisions about whether an article is pertinent to the topic of care coordination or not. Our working definition of care coordination presented in this chapter is purposely broad enough to include interventions that are sometimes defined by their own related terminology (e.g., disease management, case management, teamwork, collaboration, Chronic Care Model). It is also applicable to programs, such as the Medicare demonstration projects to improve care for those with chronic illness. The objective of these interventions and programs is to improve quality of care, in part or in total by enhancing coordination between participants for the benefit of the patient (improved outcomes) and the system (reduced costs).

We also developed a list of components of care coordination to support a more granular analysis of interventions. The components are separated into essential care tasks (e.g., identify participants and their roles), their associated coordination activities (e.g., coordinate among care plans), and common features of interventions to support coordination activities (e.g., standardized protocol, multidisciplinary team). The list draws extensively from components described by clinical professional organizations, recent consensus development efforts by the National Quality Forum, and intervention evaluators.