# Technical Expert Panel and Peer Reviewers

## Technical Expert Panel

Jeremy Grimshaw, M.B.Ch.B., Ph.D., F.R.C.G.P., University of Ottawa, Cochrane Collaboration Effective Practice and Organisation of Care Group (EPOC)

Andrew Oxman, M.Sc., M.D., Department of Health Services Research, Norwegian Directorate for Health and Social Welfare, EPOC

Russell Glasgow, Ph.D., Kaiser Permanente, Colorado

Martin Eccles, M.D., F.Med.Sci., F.R.C.P., F.R.C.G.P., M.F.P.H.M., Centre for Health Services Research, University of Newcastle upon Tyne, EPOC

Harmon Jordan, Sc.D., previously with New England Medical Center Evidence-based Practice Center, currently at ABT Associates

Val Lawrence, M.D., The University of Texas Health Science Center at San Antonio and South Texas Veterans Health Care System

James L. Zazzali, Ph.D., M.P.H., RAND Corporation

Charles Homer, M.D., M.P.H., National Institute for Children's Health Care Quality

## Peer Reviewers

David Atkins, M.D., M.P.H., Chief Medical Officer, Agency for Healthcare Research and Quality, Center for Outcomes and Evidence

Caroline Blaum, M.D., M.S., Associate Professor of Internal Medicine, Division of Geriatric Medicine, University of Michigan Research Scientist, Ann Arbor DVAMC GRECC Geriatrics Center

Beth Branthaver, M.S., M.H.A., Manager, Quality and Performance Improvement, Care Management Institute, Kaiser Permanente

Neale R. Chumbler, Ph.D., VA HSR&D/RR&D Rehabilitation Outcomes Research Center, NF/SG Veterans Health System, VA Stroke QUERI, & Assistant Professor, Department of Health Services Research, Management and Policy, University of Florida.

Adams Darkins, M.D., M.P.H.M., Chief Consultant for Care Coordination, Veterans Health Administration

Liza Greenberg, Consultant, Case Management Society of America

Halsted R Holman, M.D., Professor of Medicine, Emeritus, Department of Medicine, Immunology and Rheumatology and Center for Clinical Immunology, Stanford University

Denise Myers, R.N., M.P.H., Kaiser Permanente, Oakland, CA

Deborah Peikes, Ph.D., M.P.A., Mathematica Policy Inc., Princeton, New Jersey

John Santa, M.D., Assistant Director for Health Projects, Center for Evidence-based Policy, Oregon Health and Sciences University

Vincenza Snow, M.D., F.A.C.P., Senior Medical Associate, Scientific Policy, American College of Physicians

Reva Winkler, M.D., M.P.H., Clinical Consultant, National Quality Forum, Washington, DC

Merrick Zwarenstein, M.B., B.Ch., M.Sc., Principal Investigator, Knowledge Translation Program, Continuing Education, University of Toronto, Senior Scientist, Institute for Clinical Evaluative Sciences