# List of Excluded Reviews

## References

Best care for the dying is listening to their needs: individual needs should dictate care decisions. Patient-Focused Care and Satisfaction. 1998;6(4):44–6. Not a systematic review
Case management of patients with chronic renal insufficiency did not improve outcomes over usual care. Research Activities. 1999;225:9. Not a systematic review
Continuity of caregivers during pregnancy and childbirth. Pract Midwife. 1999;2(1):10–1. Not a systematic review
Delegation and referral in primary healthcare teams. Nursing Standard. 1997;11(49):32–3. Not a systematic review
Hospital CM and managed care growth link questioned: 74% of acute care facilities have CM departments. Hospital Case Management. 1999; 7(8):138. Not a systematic review
Medicare hospital discharge planning: report from the DHHS Office of the Inspector General. Continuum: An Interdisciplinary Journal on Continuity of Care. 1998;18(1):11–6. Not a systematic review
Patient management benefits clients, agency, and hospital. Hospital Home Health. 1992;9(4):52–4. Not a systematic review
Pilot project: proactive protocol for diabetes: can CM make a difference in diabetes outcomes? Hospital Case Management. 2001;9(10):147–9. Not a systematic review
Transitional care from hospital to home improves health of seniors while saving money. Nursingmatters. 1999;10(12):13. Not a systematic review
Treatment outlines for the management of schizophrenia. The Quality Assurance Project. Aust N Z J Psychiatry. 1984;18(1):19–38. Not care coordination
Abbott J, Young A, Haxton R, Van Dyke P. Collaborative care: a professional model that influences job satisfaction. Nursing Economics. 1994;12(3):167-9. Not a systematic review. [pmid: 7969557].
Abercrombie PD. Improving adherence to abnormal Pap smear follow-up. J Obstet Gynecol Neonatal Nurs. 2001;30(1):80-8. Not care coordination.
Abir F, Bell R. Assessment and management of the obese patient. Crit Care Med. 2004;32(4 Suppl):S87-91. Not a systematic review. [pmid: 15064667].
Adair CE, McDougall GM, Beckie A, et al. History and measurement of continuity of care in mental health services and evidence of its role in outcomes. Psychiatric Services. 2003;54(10):1351-6. Not care coordination. [pmid: 14557520].
Adatia FA, Damji KF. Chronic open-angle glaucoma. Review for primary care physicians. Can Fam Physician. Sep. 2005;51:1229-37. Not a systematic review. [pmid: 16190176]. [pmcid: 1479464].
Alberts MJ, Hademenos G, Latchaw RE, et al. Recommendations for the establishment of primary stroke centers. Brain Attack Coalition. JAMA. 2000;283(23):3102-9. Not care coordination. [pmid: 10865305].
Alexander DA, Klein S. Biochemical terrorism: too awful to contemplate, too serious to ignore: subjective literature review. Br J Psychiatry. 2003;183:491-7. Not a systematic review. [pmid: 14645019].
Allen D, Lyne P, Griffiths L. Fraying seams... the divisions between health and social services should be invisible to those who use them... a version of this article appeared in Nursing Times. Therapy Weekly. 2001;28(22):4. Not available.
Allred CA, Arford PH, Michel Y, Veitch JS, Dring R, Carter V. Case management: the relationship between structure & environment. Nursing Economics. 1995;13(1):32-41. Not a systematic review. [pmid: 7760946].
Amruso NA, O'Neal ML. Pharmacist and physician collaboration in the patient's home. Ann Pharmacother. 2004;38(6):1048-52. Not a systematic review. [pmid: 15113983].
Anderson JL. Nursing management of the cancer patient in pain: a review of the literature. Cancer Nurs. 1982;5(1):33-41. Not care coordination. [pmid: 6175393].
Anderson MA, Helms LB. Quality improvement in discharge planning: an evaluation of factors in communication between health care providers. Journal of Nursing Care Quality. 1994;8(2):62-72. Not a systematic review. [pmid: 8312595].
Anderson MA, Tredway C. Focus on research. Care manager communication in home health care referrals. Chart. 1998;95(1):5. Not a systematic review.
Andlin-Sobocki P. Economic evidence in addiction: a review. Eur J Health Econ. 2004;5(Suppl 1):S5-12. Not care coordination. [pmid: 15754074].
Armitage SK, Kavanagh KM. The discharge liaison nurse at the interface of hospital and community nursing services. International Journal of Nursing Practice. 1996;2(4):215-21. Not a systematic review.
Aronson N, Lefevre F, Piper M, et al. Management of chronic asthma. Evid Rep Technol Assess (Summ). 2001;(44):1–10. Not care coordination
Bachrach LL. Young adult chronic patients: an analytical review of the literature. Hosp Community Psychiatry. 1982;33(3):189-97. Not a systematic review. [pmid: 7061053].
Balas EA, Krishna S, Kretschmer RA, Cheek TR, Lobach DF, Boren SA. Computerized knowledge management in diabetes care. Med Care. 2004;42(6):610-21. Not care coordination. [pmid: 15167329].
Barlow JH, Ellard DR. Psycho-educational interventions for children with chronic disease, parents and siblings: an overview of the research evidence base. Child Care Health Dev. 2004;30(6):637-45. Not care coordination. [pmid: 15527474].
Barr H, Hammick M, Koppel I, Reeves S. Systematic review of the effectiveness of interprofessional education: towards transatlantic collaboration. J Allied Health. 1999;28(2):104-8. Not a systematic review. [pmid: 10389055].
Bauer M, Nay R. Family and staff partnerships in long-term care. A review of the literature. J Gerontol Nurs. 2003;29(10):46-53. Not a systematic review. [pmid: 14558235].
Baxter E. Patients, caregivers, and managing care. Geriatrics. 1997;52(2):S48-9. Not a systematic review. [pmid: 9307588].
Bayley EW, Carrougher GJ, Marvin JA, Knighton J, Rutan RL, Weber BF. Research priorities for burn nursing: rehabilitation, discharge planning, and follow-up care. Journal of Burn Care & Rehabilitation. 1992;13(4):471-6. Not a systematic review. [pmid: 1331118].
Bazzoli GJ, Dynan L, Burns LR, Yap C. Two decades of organizational change in health care: what have we learned?. Med Care Res Rev. 2004;61(3):247-331. Not care coordination. [pmid: 15358969].
Beaudin CL, Lammers JC, Pedroja AT. Patient perceptions of coordinated care: the importance of organized communication in hospitals. Journal for Healthcare Quality. 1999;21(5):18-23. Not a systematic review. [pmid: 10620880].
Beavis D, Simpson S, Graham I. A literature review of dementia care mapping: methodological considerations and efficacy. J Psychiatr Ment Health Nurs. 2002;9(6):725-36. Not care coordination. [pmid: 12472826].
Bechel DL, Myers WA, Smith DG. Does patient-centered care pay off?. Joint Commission Journal on Quality Improvement. 2000;26(7):400-9. Not a systematic review. [pmid: 10897457].
Bell R. Continuity of care: were we providing continuity of care for our clients?. Perspectives. 1996;20(4):17-20. Not a systematic review. [pmid: 9287837].
Berk M, Berk L, Castle D. A collaborative approach to the treatment alliance in bipolar disorder. Bipolar Disord. 2004;6(6):504-18. Not care coordination. [pmid: 15541066].
Bernard-Bonnin AC, Stachenko S, Bonin D, Charette C, Rousseau E. Self-management teaching programs and morbidity of pediatric asthma: a meta-analysis. J Allergy Clin Immunol. 1995;95(1 Pt 1):34-41. Not care coordination. [pmid: 7822662].
Betz CL. Transition of adolescents with special health care needs: review and analysis of the literature. Issues in Comprehensive Pediatric Nursing. 2004;27(3):179-241. Not care coordination. [pmid: 15371115].
Bhui K, Stansfeld S, Hull S, Priebe S, Mole F, Feder G. Ethnic variations in pathways to and use of specialist mental health services in the UK. Systematic review. Br J Psychiatry. 2003;182:105-16. Not care coordination. [pmid: 12562737].
Bhutta ZA, Darmstadt GL, Hasan BS, Haws RA. Community-based interventions for improving perinatal and neonatal health outcomes in developing countries: a review of the evidence. Pediatrics. Feb. 2005;115(2 Suppl):519-617. Not care coordination. [pmid: 15866863].
Birthistle K, Carrington D. Fetal varicella syndrome—a reappraisal of the literature. A review prepared for the UK Advisory Group on Chickenpox on behalf of the British Society for the Study of Infection. J Infect. 1998;36(Suppl 1):25-9. Not care coordination. [pmid: 9514105].
Blaiss MS. Asthma disease management: a critical analysis. Ann Allergy Asthma Immunol. Nov. 2005;95(5 Suppl 1):S10-6. Not a systematic review. [pmid: 16312157].
Blenkinsopp A, Anderson C, Armstrong M. Systematic review of the effectiveness of community pharmacy-based interventions to reduce risk behaviours and risk factors for coronary heart disease. J Public Health Med. 2003;25(2):144-53. Not care coordination. [pmid: 12848404].
Bloemen-Vrencken JH, de Witte LP, Post MW. Follow-up care for persons with spinal cord injury living in the community: a systematic review of interventions and their evaluation. Spinal Cord. Aug. 2005;43(8):462-75. Not an evaluation of an intervention. [pmid: 15838530].
Blondel B, Breart G. Home visits for pregnancy complications and management of antenatal care: an overview of three randomized controlled trials. Br J Obstet Gynaecol. 1992;99(4):283-6. Not a systematic review. [pmid: 1533787].
Boockvar K, Fishman E, Kyriacou CK, Monias A, Gavi S, Cortes T. Adverse events due to discontinuations in drug use and dose changes in patients transferred between acute and long-term care facilities. Archives of Internal Medicine. 2004;164(5):545-50. Not a systematic review. [pmid: 15006832].
Bower P, Sibbald B. Systematic review of the effect of on-site mental health professionals on the clinical behaviour of general practitioners. BMJ. 2000;320(7235):614-7. Duplicate publication. [pmid: 10698881]. [pmcid: 27305].
Bower P. Primary care mental health workers: models of working and evidence of effectiveness. Br J Gen Pract. 2002;52(484):926-33. Not a systematic review. [pmid: 12434963]. [pmcid: 1314446].
Bowlyow JE. Acute and long-term care linkages: a literature review. Med Care Rev. 1990;47(1):75-103. Not a systematic review. [pmid: 10106526].
Bradley P, Lindsay B. Epilepsy clinics versus general neurology or medical clinics. Cochrane Database Syst Rev. 2001(1):CD001910. Not care coordination
Bradley P, Lindsay B. Specialist epilepsy nurses for treating epilepsy. Cochrane Database Syst Rev. 2001(4):CD001907. Not care coordination
Brickman R, Axelrod R, Roberson D, Flanagan C. Clinical process improvement as a means of facilitating health care system integration. Joint Commission Journal on Quality Improvement. 1998;24(3):143-53. Not a systematic review. [pmid: 9568554].
Brigden M, McKenzie M. Treating cancer patients. Practical monitoring and management of therapy-related complications. Can Fam Physician. 2000;46:2258-68. Not care coordination. [pmid: 11143585]. [pmcid: 2145068].
Briggs CJ, Capdegelle P, Garner P. Strategies for integrating primary health services in middle- and low-income countries: effects on performance, costs and patient outcomes. Cochrane Database Syst Rev. 2001(4): CD003318 Duplicate publication
Bryan YE, Hitchings KS, Fox MA, Kinneman MT, Young MJ. The evaluation of hospital restructuring efforts: satisfaction, quality, and costs. Quality Management in Health Care. 1998;6(3):22-34. Not a systematic review. [pmid: 10182537].
Bull MJ. Patients' and professionals' perceptions of quality in discharge planning. Journal of Nursing Care Quality. 1994;8(2):47-61. Not a systematic review. [pmid: 8312594].
Bunn F, Byrne G, Kendall S. Telephone consultation and triage: effects on health care use and patient satisfaction. Cochrane Database Syst Rev. 2004(4):CD004180. Not care coordination
Burns T, Knapp M, Catty J, et al. Home treatment for mental health problems: a systematic review. Health Technol Assess. 2001;5(15):1-139. Not care coordination. [pmid: 11532236].
Cabana MD, Jee SH. Does continuity of care improve patient outcomes?. J Fam Pract. 2004;53(12):974-80. Not care coordination. [pmid: 15581440].
Caley LM, Shipkey N, Winkelman T, Dunlap C, Rivera S. Evidence-based review of nursing interventions to prevent secondary disabilities in fetal alcohol spectrum disorder. Pediatr Nurs. Mar–Apr. 2006;32(2):155-62. Not an evaluation of an intervention. [pmid: 16719426].
Cameron ID. Coordinated multidisciplinary rehabilitation after hip fracture. Disabil Rehabil. Sep 30–Oct 15. 2005;27(1819):1081-90. Not a systematic review. [pmid: 16315427].
Campbell MK, Daly C, Wallace SA, et al. Evidence-based medicine in nephrology: identifying and critically appraising the literature. Nephrol Dial Transplant. 2000;15(12):1950-5. Not care coordination. [pmid: 11096139].
Cannon CP, Hand MH, Bahr R, et al. Critical pathways for management of patients with acute coronary syndromes: an assessment by the National Heart Attack Alert Program. Am Heart J. 2002;143(5):777-89. Study conducted in an in-patient setting only. [pmid: 12040337].
Casalino L, Gillies RR, Shortell SM, et al. External incentives, information technology, and organized processes to improve health care quality for patients with chronic diseases. JAMA. 2003;289(4):434-41. Not a systematic review. [pmid: 12533122].
Casciano R. A pharmacoeconomic evaluation of major depressive disorder. Manag Care Interface. 2003;Suppl B:16–21. Not care coordination
Castrucci BC, Kamb ML, Hunt K. Assessing the Center for Disease Control and Prevention's 1994 HIV Counseling, Testing, and Referral: Standards and Guidelines: how closely does practice conform to existing recommendations?. Sexually Transmitted Diseases. 2002;29(7):417-21. Not a systematic review. [pmid: 12170132].
Caton CLM, Goldstein JM, Serrano O, Bender R. The impact of discharge planning on chronic schizophrenic patients. H&CP: Hospital & Community Psychiatry. 1984;35(3):255-62. Not a systematic review.
Challis D, Darton R, Hughes J, Huxley P, Stewart K. Emerging models of care management for older people and those with mental health problems in the United Kingdom. Journal of Case Management. 1998;7(4):153-60. Not a systematic review. [pmid: 10703382].
Chan KH, Winslow CP, Levin MJ, et al. Clinical practice guidelines for the management of chronic sinusitis in children. Otolaryngology Head and Neck Surgery. 1999;120(3):328-34. Not a systematic review. [pmid: 10064633].
Chang JT, Morton SC, Rubenstein LZ, et al. Interventions for the prevention of falls in older adults: systematic review and meta-analysis of randomised clinical trials. BMJ. 2004;328(7441):680. Not care coordination. [pmid: 15031239]. [pmcid: 381224].
Chapman JL, Zechel A, Carter YH, Abbott S. Systematic review of recent innovations in service provision to improve access to primary care. Br J Gen Pract. 2004;54(502):374-81. Not care coordination. [pmid: 15113523]. [pmcid: 1266174].
Chelf JH, Agre P, Axelrod A, et al. Cancer-related patient education: an overview of the last decade of evaluation and research. Oncol Nurs Forum. 2001;28(7):1139-47. Not care coordination. [pmid: 11517847].
Chen CC, Kenefick AL, Tang ST, McCorkle R. Utilization of comprehensive geriatric assessment in cancer patients. Crit Rev Oncol Hematol. 2004;49(1):53-67. Not a systematic review. [pmid: 14734155].
Christakis DA, Wright JA, Koepsell TD, Emerson S, Connell FA. Is greater continuity of care associated with less emergency department utilization?. Pediatrics. 1999;103(4 part 1):738-42. Not a systematic review. [pmid: 10103295].
Cifu DX, Stewart DG. Factors affecting functional outcome after stroke: a critical review of rehabilitation interventions. Arch Phys Med Rehabil. 1999;80(5 Suppl 1):S35-9. Not care coordination. [pmid: 10326901].
Cloonan PA, Belyea MJ. Limits of using patient characteristics in predicting home health care coordination. Western Journal of Nursing Research. 1993;15(6):742-51. Not a systematic review. [pmid: 8284931].
Connors HR. Impact of evaluation of a statewide continuing education program. Journal of Continuing Education in Nursing. 1989;20(2):64-69. Not a systematic review. [pmid: 2495306].
Corser WD. A complex sense of advocacy: the challenges of contemporary discharge planning. Case Manager. 2003;14(3):63-9. Not a systematic review. [pmid: 12750690].
Costich TD, Lee FC. Improving cancer care in a Kentucky managed care plan: a case study of cancer disease management. Disease Management. 2003;6(1):9-20. Not a systematic review. [pmid: 12899563].
Coulton CJ, Dunkle RE, Goode RA. Discharge planning and decision making. Health and Social Work. 1982;7(4):253-61. Not a systematic review. [pmid: 6819214].
Cox K, Wilson E. Follow-up for people with cancer: nurse-led services and telephone interventions. J Adv Nurs. 2003;43(1):51-61. Not care coordination. [pmid: 12801396].
Cox WK, Penny LC, Statham RP, Roper BL. Admission Intervention Team: medical center based intensive case management of the seriously mentally ill. Care Management Journals: Journal of Case Management, The Journal of Long Term Home Health Care. 2003;4(4):178-84. Not a systematic review. [pmid: 15628650].
Cram P, Ettinger WH Jr. Generalists or specialists—who does it better?. Physician Exec. 1998;24(1):40-5. Not care coordination. [pmid: 10180486].
Currell R, Urquhart C. Nursing record systems: effects on nursing practice and health care outcomes. Cochrane Database Syst Rev. 2003(3):CD002099. Not care coordination
da Cruz ICF, Larrubia EO, de Azevedo NM, et al. Strategic plan for developing nursing professional standards at an university hospital, Rio de Janeiro, Brazil. Online Brazilian Journal of Nursing. 2002;1(3). Not a systematic review
Dallas C, Burton L. Health disparities among men from racial and ethnic minority populations. Annu Rev Nurs Res. 2004;22:77-100. Not care coordination. [pmid: 15368769].
Daneels M, Cannoodt L. Child-oriented emergency care: a literature survey. Paediatr Nurs. 2003;15(2):14-9. Not care coordination. [pmid: 12677853].
Davidson G, Moscovice I, McCaffrey D. Allocative efficiency of case managers for the elderly. Health Services Research. 1989;24(4):539-54. Not a systematic review. [pmid: 2681082]. [pmcid: 1065582].
Delaney B, Moayyedi P, Deeks J, et al. The management of dyspepsia: a systematic review. Health Technol Assess. 2000;4(39):iii–v, 1–189. Not care coordination
Dellefield ME. Interdisciplinary care planning and the written care plan in nursing homes: a critical review. Gerontologist. Feb. 2006;46(1):128-33. Not a systematic review. [pmid: 16452293].
Dephillips H. Advancing care management: from utilization review to evidence-based medicine. Lippincotts Case Manag. Sep–Oct. 2005;10(5):265-7. Not a systematic review. [pmid: 16205211].
Doleys DM, Marino L, Howell M, Nicholson B. Pain management programs in hand therapy: a literature review and appraisal. J Hand Ther. 1997;10(2):175-82. Not care coordination. [pmid: 9188036].
Dorman T, Angood PB, Angus DC, et al. Guidelines for critical care medicine training and continuing medical education. Crit Care Med. 2004;32(1):263-72. Not a systematic review. [pmid: 14707590].
Dreachslin JL, Hunt PL, Sprainer E. Communication patterns and group composition: implications for patient-centered care team effectiveness... including commentary by Snook ID Jr. Journal of Healthcare Management. 1999;44(4):252-68. Not a systematic review. [pmid: 10539199].
Eakin EG, Bull SS, Glasgow RE, Mason M. Reaching those most in need: a review of diabetes self-management interventions in disadvantaged populations. Diabetes Metab Res Rev. 2002;18(1):26-35. Not care coordination. [pmid: 11921415].
Edwards J, Reiley P, Morris A, Doody J. An analysis of the quality and effectiveness of the discharge planning process. Journal of Nursing Quality Assurance. 1991;5(4):17-27. Not a systematic review. [pmid: 1904884].
Eke N, Eke FU. Collaboration in urological practice in the new millennium. Niger Postgrad Med J. 2002;9(3):167-72. Not a systematic review. [pmid: 12501273].
Engstrom S, Foldevi M, Borgquist L. Is general practice effective? A systematic literature review. Scand J Prim Health Care. 2001;19(2):131-44. Not care coordination. [pmid: 11482415].
Ensor T, Ronoh J. Impact of organizational change on the delivery of reproductive services: a review of the literature. Int J Health Plann Manage. Jul–Sep. 2005;20(3):209-25. Not a systematic review. [pmid: 16138735].
Erstad TL. Analyzing computer based patient records: a review of literature. J Healthc Inf Manag. 2003;17(4):51-7. Not a systematic review. [pmid: 14558372].
Evans R, Stone D, Elwyn G. Title Organizing palliative care for rural populations: A systematic review of the evidence. Source Family Practice. 2003;20(3):304-310. Not care coordination.
Every NR, Hochman J, Becker R, Kopecky S, Cannon CP. Critical pathways: a review. Committee on Acute Cardiac Care, Council on Clinical Cardiology, American Heart Association. Circulation. 2000;101(4):461-5. Not a systematic review. [pmid: 10653841].
Fahey T, Schroeder K, Ebrahim S. Educational and organisational interventions used to improve the management of hypertension in primary care: a systematic review. Br J Gen Pract. Nov. 2005;55(520):875-82. Not care coordination. [pmid: 16282005]. [pmcid: 1570766].
Farris KB, Kirking DM. Assessing the quality of pharmaceutical care. II. Application of concepts of quality assessment from medical care. Ann Pharmacother. 1993;27(2):215-23. Not a systematic review. [pmid: 8439702].
Finley PR, Crismon ML, Rush AJ. Evaluating the impact of pharmacists in mental health: a systematic review. Pharmacotherapy. 2003;23(12):1634-44. Not care coordination. [pmid: 14695043].
Finucane TE, Harper GM. Attempting resuscitation in nursing homes: policy considerations. J Am Geriatr Soc. 1999;47(10):1261-4. Not care coordination. [pmid: 10522963].
Fleming E, Carter B, Gillibrand W. The transition of adolescents with diabetes from the children's health care service into the adult health care service: a review of the literature. J Clin Nurs. 2002;11(5):560-7. Not care coordination. [pmid: 12201882].
Fonarow GC, Gheorghiade M, Abraham WT. Importance of in-hospital initiation of evidence-based medical therapies for heart failure-a review. Am J Cardiol. 2004;94(9):1155-60. Not a systematic review. [pmid: 15518610].
Foster SA, Goode JV, Small RE. Home blood glucose monitoring. Ann Pharmacother. 1999;33(3):355-63. Not a systematic review. [pmid: 10200862].
French J, Bilton D, Campbell F. Nurse specialist care for bronchiectasis. Cochrane Database Syst Rev. 2003(3):CD004319. Not care coordination
Frich LM. Nursing interventions for patients with chronic conditions. J Adv Nurs. 2003;44(2):137-53. Not care coordination. [pmid: 14521681].
Frick KD, Lantz PM. Selection bias in prenatal care utilization: an interdisciplinary framework and review of the literature. Med Care Res Rev. 1996;53(4):371-96. Not a systematic review. [pmid: 10162957].
Gagliardi A. Use of referral reply letters for continuing medical education: a review. Journal of Continuing Education in the Health Professions. 2002;22(4):222-9. Not care coordination. [pmid: 12613057].
Garg AX, Adhikari NK, McDonald H, et al. Effects of computerized clinical decision support systems on practitioner performance and patient outcomes: a systematic review. JAMA. 2005;293(10):1223-38. Not care coordination. [pmid: 15755945].
Gibson PG, Powell H, Coughlan J, et al. Self-management education and regular practitioner review for adults with asthma. Cochrane Database Syst Rev. 2003(1):CD001117. Not care coordination
Gibson PG, Powell H. Written action plans for asthma: an evidence-based review of the key components. Thorax. 2004;59(2):94-9. Not care coordination. [pmid: 14760143]. [pmcid: 1746945].
Ginsberg BH, Tan MH, Mazze R, Bergelson A. Staged diabetes management: computerizing a disease state management program. J Med Syst. 1998;22(2):77-87. Not a systematic review. [pmid: 9571514].
Goldfarb N, Weston C, Hartmann CW, et al. Impact of appropriate pharmaceutical therapy for chronic conditions on direct medical costs and workplace productivity: a review of the literature. Dis Manag. 2004;7(1):61-75. Not care coordination. [pmid: 15035834].
Goodall TA, Halford WK. Self-management of diabetes mellitus: a critical review. Health Psychol. 1991;10(1):1-8. Not a systematic review. [pmid: 2026125].
Green JM, Renfrew MJ, Curtis PA. Continuity of carer: what matters to women? A review of the evidence. Midwifery. 2000;16(3):186-96. Not care coordination. [pmid: 10970752].
Grundel BL, White GL Jr, Eichold BH 2nd. Diabetes in the managed care setting: a prospective plan. South Med J. 1999;92(5):459-64. Not a systematic review. [pmid: 10342889].
Guevara JP, Wolf FM, Grum CM, Clark NM. Effects of educational interventions for self management of asthma in children and adolescents: systematic review and meta-analysis. BMJ. 2003;326(7402):1308-9. Duplicate publication. [pmid: 12805167]. [pmcid: 161636].
Guevara JP. Self-management education of children with asthma: a meta-analysis. LDI Issue Brief. 2003;9(3):1-4. Not care coordination. [pmid: 14959726].
Gurses AP, Xiao Y. A systematic review of the literature on multidisciplinary rounds to design information technology. J Am Med Inform Assoc. May–Jun. 2006;13(3):267-76. Study conducted in an in-patient setting. [pmid: 16501176]. [pmcid: 1513658].
Gustafsson F, Arnold JM. Heart failure clinics and outpatient management: review of the evidence and call for quality assurance. Eur Heart J. 2004;25(18):1596-604. Not care coordination. [pmid: 15351158].
Gutierres SL, Welty TE. Point-of-care testing: an introduction. Ann Pharmacother. 2004;38(1):119-25. Not care coordination. [pmid: 14742805].
Guzman J, Esmail R, Karjalainen K, Malmivaara A, Irvin E, Bombardier C. Multidisciplinary bio-psycho-social rehabilitation for chronic low back pain. Cochrane Database Syst Rev. 2002(1):CD000963. Not care coordination
Gwadry-Sridhar FH, Flintoft V, Lee DS, Lee H, Guyatt GH. A systematic review and meta-analysis of studies comparing readmission rates and mortality rates in patients with heart failure. Arch Intern Med. 2004;164(21):2315-20. Not care coordination. [pmid: 15557409].
Haaga D. Review: case management in primary health care improves symptoms and drug adherence in people with major depression. Evidence-Based Mental Health. Aug. 2006;9(3):79. Abstract. [pmid: 16868198].
Hakansson S, Gavelin C. What do we really know about the cost-effectiveness of telemedicine?. J Telemed Telecare. 2000;6(Suppl 1):S133-6. Not care coordination. [pmid: 10793998].
Hall JE. Mental health integrated care pathways in the UK: a review of their content. Journal of Integrated Care Pathways. 2004;8(1):14-8. Not a systematic review.
Halstead LS. Team care in chronic illness: a critical review of the literature of the past 25 years. Arch Phys Med Rehabil. 1976;57(11):507-11. Not a systematic review. [pmid: 985051].
Hampson JP, Roberts RI, Morgan DA. Shared care: a review of the literature. Fam Pract. 1996;13(3):264-79. Not care coordination. [pmid: 8671136].
Hampson SE, Skinner TC, Hart J, et al. Behavioral interventions for adolescents with type 1 diabetes: how effective are they?. Diabetes Care. 2000;23(9):1416-22. Not care coordination. [pmid: 10977043].
Hampson SE, Skinner TC, Hart J, et al. Effects of educational and psychosocial interventions for adolescents with diabetes mellitus: a systematic review. Health Technol Assess. 2001;5(10):1-79. Not care coordination. [pmid: 11319990].
Hangsleben KL. Transition to fatherhood: literature review. Issues Health Care Women. 1980;2(56):81-97. Not a systematic review. [pmid: 7028835].
Hanlon JT, Lindblad CI, Gray SL. Can clinical pharmacy services have a positive impact on drug-related problems and health outcomes in community-based older adults?. Am J Geriatr Pharmacother. 2004;2(1):3-13. Not care coordination. [pmid: 15555474].
Harrigan RC, Ratliffe C, Patrinos ME, Tse A. Medically fragile children: an integrative review of the literature and recommendations for future research. Issues Compr Pediatr Nurs. 2002;25(1):1-20. Not care coordination. [pmid: 11934119].
Harrington J, Noble LM, Newman SP. Improving patients' communication with doctors: a systematic review of intervention studies. Patient Educ Couns. 2004;52(1):7-16. Not care coordination. [pmid: 14729285].
Harris R. Review: hospital based case management does not reduce length of hospital stay or readmissions in adults. Evidence-Based Nursing. Apr. 2006;9(2):54. Study conducted in an in-patient setting. [pmid: 16622931].
Harvey EL, Glenny AM, Kirk SF, Summerbell CD. A systematic review of interventions to improve health professionals' management of obesity. Int J Obes Relat Metab Disord. 1999;23(12):1213-22. Duplicate publication. [pmid: 10643676].
Harvey EL, Glenny AM, Kirk SF, Summerbell CD. An updated systematic review of interventions to improve health professionals' management of obesity. Obes Rev. 2002;3(1):45-55. Duplicate publication. [pmid: 12119659].
Hasman A, Safran C, Takeda H. Quality of health care: informatics foundations. Methods Inf Med. 2003;42(5):509-18. Not a systematic review. [pmid: 14654885].
Hawley DJ. Psycho-educational interventions in the treatment of arthritis. Baillieres Clin Rheumatol. 1995;9(4):803-23. Not care coordination. [pmid: 8591655].
Hersh WR, Helfand M, Wallace J, et al. Clinical outcomes resulting from telemedicine interventions: a systematic review. BMC Med Inform Decis Mak. 2001;1(1):5. Not care coordination. [pmid: 11737882]. [pmcid: 60664].
Hodnett ED, Fredericks S. Support during pregnancy for women at increased risk of low birthweight babies. Cochrane Database Syst Rev. 2003(3):CD000198. Not care coordination
Hodnett ED. Continuity of caregivers for care during pregnancy and childbirth. Cochrane Database Syst Rev. 2000(2):CD000062. Not care coordination
Houde SC. Methodological issues in male caregiver research: an integrative review of the literature. J Adv Nurs. 2002;40(6):626-40. Not care coordination. [pmid: 12473041].
Househ MS, Lau FY. Collaborative technology use by healthcare teams. J Med Syst. Oct. 2005;29(5):449-61. Not care coordination. [pmid: 16180481].
Howgego IM, Yellowlees P, Owen C, Meldrum L, Dark F. The therapeutic alliance: the key to effective patient outcome? A descriptive review of the evidence in community mental health case management. Australian and New Zealand Journal of Psychiatry. 2003;37(2):169-83. Not care coordination. [pmid: 12656956].
Hughes L, Joyce B, Staley D. Does the family make a difference?... family involvement in discharge planning and its effect on readmission rates to a psychiatric unit. Journal of Psychosocial Nursing and Mental Health Services. 1987;25(8):8-13. Not a systematic review.
Hulscher ME, Wensing M, Grol RP, van der Weijden T, van Weel C. Interventions to improve the delivery of preventive services in primary care. Am J Public Health. 1999;89(5):737-46. Not care coordination. [pmid: 10224987]. [pmcid: 1508735].
Humphris D. Disturbance and resilience: an overview of evidence based practice. J Tissue Viability. 1998;8(2):16-8. Not a systematic review. [pmid: 10531930].
Iglehart AP. Discharge planning: professional perspectives versus organizational effects. Health and Social Work. 1990;15(4):301-9. Not a systematic review. [pmid: 2276692].
Ioannidis JP, Lau J. Evidence on interventions to reduce medical errors: an overview and recommendations for future research. J Gen Intern Med. 2001;16(5):325-34. Study conducted in an in-patient setting only. [pmid: 11359552]. [pmcid: 1495210].
Issel LM. Comprehensive case management: implications for program managers. Health Care Supervisor. 1997;15(3):39-50. Not a systematic review. [pmid: 10165428].
Jaber R, Braksmajer A, Trilling JS. Group visits: a qualitative review of current research. J Am Board Fam Med. May–Jun. 2006;19(3):276-90. Not care coordination. [pmid: 16672681].
Jackson B, Swanson C, Hicks LE, Prokop L, Laughlin J. Bridge of continuity from hospital to nursing home — part I: a proactive approach to reduce relocation stress syndrome in the elderly. Continuum: An Interdisciplinary Journal on Continuity of Care. 2000;20(1):3-8. Not a systematic review.
Jacobson VJ, Szilagyi P. Patient reminder and patient recall systems to improve immunization rates. Cochrane Database Syst Rev. 2005(3):CD003941. Not care coordination
Jakobsson B, Haard US, Bergroth A, Selander J, Ekholm J. Improved cooperation in vocational rehabilitation with systematic rehabilitation group meetings. Disability and Rehabilitation. 2002;24(14):734-40. Not a systematic review. [pmid: 12452134].
Jennett PA, Hall LA, Hailey D, et al. Title The socio-economic impact of telehealth: A systematic review. Source Journal of Telemedicine & Telecare. 2003;9(6):311-320. Not care coordination.
Johnson A, Sandford J, Tyndall J. Written and verbal information versus verbal information only for patients being discharged from acute hospital settings to home. Cochrane Database Syst Rev. 2003(4):CD003716. Not care coordination
Kadushin G, Kulys R. Patient and family involvement in discharge planning. Journal of Gerontological Social Work. 1994;22(3/4):171-99. Not a systematic review.
Karjalainen K, Malmivaara A, van Tulder M, et al. Multidisciplinary biopsychosocial rehabilitation for subacute low back pain among working age adults. Cochrane Database Syst Rev. 2003(2):CD002193. Not care coordination
Karjalainen K, Malmivaara A, van Tulder M, et al. Multidisciplinary biopsychosocial rehabilitation for subacute low back pain in working-age adults: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine. 2001;26(3):262-9. Duplicate publication. [pmid: 11224862].
Kennedy S, Stone A, Rachelefsky G. Factors associated with emergency department use in asthma: acute care interventions improving chronic disease outcomes. Ann Allergy Asthma Immunol. 2003;90(1):45-50. Not a systematic review. [pmid: 12546337].
Khanna N, Phillips MD. Adherence to care plan in women with abnormal Papanicolaou smears: a review of barriers and interventions. J Am Board Fam Pract. 2001;14(2):123-30. Not care coordination. [pmid: 11314919].
Kibby MY, Tyc VL, Mulhern RK. Effectiveness of psychological intervention for children and adolescents with chronic medical illness: a meta-analysis. Clin Psychol Rev. 1998;18(1):103-17. Not care coordination. [pmid: 9455625].
Koopman RJ, Mainous AG III, Baker R, Gill JM, Gilbert GE. Continuity of care and recognition of diabetes, hypertension, and hypercholesterolemia. Archives of Internal Medicine. 2003;163(11):1357-61. Not a systematic review. [pmid: 12796073].
Kopelowicz A, Liberman RP. Biobehavioral treatment and rehabilitation of schizophrenia. Harv Rev Psychiatry. 1995;3(2):55-64. Not a systematic review. [pmid: 9384930].
Krasnoff M, Moscati R. Domestic violence screening and referral can be effective. Annals of Emergency Medicine. 2002;40(5):485-92. Not a systematic review. [pmid: 12399791].
Krichbaum K, Aarestad V, Buethe M. Exploring the connection between self-efficacy and effective diabetes self-management. Diabetes Educ. 2003;29(4):653-62. Not care coordination. [pmid: 13677176].
Kroll DA, Brummitt CF, Berry BB. A users group approach to quality improvement across an integrated healthcare delivery system. Journal for Healthcare Quality. 2000;22(1):39-43. Not a systematic review. [pmid: 10787787].
Krueger KP, Felkey BG, Berger BA. Improving adherence and persistence: a review and assessment of interventions and description of steps toward a national adherence initiative. J Am Pharm Assoc (Wash DC). 2003;43(6):668-78. quiz 678–9. Not care coordination.
Krupat E, Rosenkranz SL, Yeager CM, Barnard K, Putnam SM, Inui TS. The practice orientations of physicians and patients: the effect of doctor-patient congruence on satisfaction. Patient Education and Counseling. 2000;39(1):49-59. Not a systematic review. [pmid: 11013547].
Kuklierus A, Mayer G, Day T. Case management — a new marketing focus for tertiary medical centers. Case Manager. 1999;10(6):45-8. Not a systematic review.
Kurtz LF, Bagarozzi DA, Pollane LP. Case management in mental health. Health and Social Work. 1984;9(3):201-11. Not a systematic review. [pmid: 6479752].
Lacey KO, Chyun DA, Grey M. An integrative literature review of cardiac risk factor management in diabetes education interventions. Diabetes Educ. 2000;26(5):812-20. Not care coordination. [pmid: 11140009].
Laffel LMB, Brackett J, Ho J, Anderson BJ. Changing the process of diabetes care improves metabolic outcomes and reduces hospitalizations. Quality Management in Health Care. 1998;6(4):53-62. Not a systematic review. [pmid: 10339045].
Lam JA, Rosenheck R. Street outreach for homeless persons with serious mental illness is it effective?. Medical Care. 1999;37(9):894-907. Not a systematic review. [pmid: 10493468].
Lamb GS, Stempel JE. Nurse case management from the client's view: growing as insider-expert. Nursing Outlook. 1994;42(1):7-13. Not a systematic review. [pmid: 8202398].
Langhorne P, Dey P, Woodman M, Kalra L, Wood-Dauphinee S, Patel N, et al. Is stroke unit care portable? A systematic review of the clinical trials. Age Ageing. Jul. 2005;34(4):324-30. Study conducted in an in-patient setting. [pmid: 15955755].
Larsen T, Olsen TS, Sorensen J. Early home-supported discharge of stroke patients: a health technology assessment. Int J Technol Assess Health Care. Summer. 2006;22(3):313-20. Duplicate publication. [pmid: 16984059].
Lau J, Balk E, Rothberg M, et al. Management of clinically inapparent adrenal mass. Evid Rep Technol Assess (Summ). 2002(56):1–5. Not care coordination
Lauriello J, Bustillo J, Keith SJ. A critical review of research on psychosocial treatment of schizophrenia. Biol Psychiatry. 1999;46(10):1409-17. Not a systematic review. [pmid: 10578455].
Lauver DR, Ward SE, Heidrich SM, et al. Patient-centered interventions. Research in Nursing & Health. 2002;25(4):246-55. Not a systematic review. [pmid: 12124719].
Leal S, Glover JJ, Herrier RN, Felix A. Improving quality of care in diabetes through a comprehensive pharmacist-based disease management program. Diabetes Care. 2004;27(12):2983-4. Not a systematic review. [pmid: 15562220].
Lefevre F, Piper M, Weiss K, Mark D, Clark N, Aronson N. Do written action plans improve patient outcomes in asthma? An evidence-based analysis. J Fam Pract. 2002;51(10):842-8. Not care coordination. [pmid: 12401152].
Legg L, Langhorne P. Rehabilitation therapy services for stroke patients living at home: systematic review of randomised trials. Lancet. 2004;363(9406):352-6. Not care coordination. [pmid: 15070563].
Leibowitz R, Day S, Dunt D. A systematic review of the effect of different models of after-hours primary medical care services on clinical outcome, medical workload, and patient and GP satisfaction. Fam Pract. 2003;20(3):311-7. Not care coordination. [pmid: 12738701].
Leonard B. Review: existing evidence does not support nurse led interventions in chronic obstructive pulmonary disease. Evidence-Based Nursing. Apr. 2006;9(2):56. Not care coordination. [pmid: 16622933].
Levy A, Alsop K, Hehir M, Lock V, Greenwood R, Tobin G. We'll meet again... is it true that emergency medical readmissions are a reflection of inadequate care or poor discharge planning?. Health Service Journal. 2000;110(5725):30-1. Not a systematic review.
Lewin SA, Skea ZC, Entwistle V, Zwarenstein M, Dick J. Interventions for providers to promote a patient-centred approach in clinical consultations. Cochrane Database Syst Rev. 2001(4):CD003267. Not care coordination
Louis AA, Turner T, Gretton M, Baksh A, Cleland JG. A systematic review of telemonitoring for the management of heart failure. Eur J Heart Fail. 2003;5(5):583-90. Not care coordination. [pmid: 14607195].
Loveman E, Royle P, Waugh N. Specialist nurses in diabetes mellitus. Cochrane Database Syst Rev. 2003(2):CD003286. Not care coordination
Low G. Developing the nurse's role in rehabilitation. Nurs Stand. 2003;17(45):33-8. Not a systematic review. [pmid: 12929344].
Lukas CV, Meterko M, Lowcock S, et al. Monitoring the progress of system integration. Quality Management in Health Care. 2002;10(2):1-11. Not a systematic review. [pmid: 11799825].
Lyndon A. Communication and teamwork in patient care: how much can we learn from aviation?. J Obstet Gynecol Neonatal Nurs. Jul–Aug. 2006;35(4):538-46. Study conducted in an in-patient setting.
Magnus M, Schmidt N, Kirkhart K, et al. Association between ancillary services and clinical and behavioral outcomes among HIV-infected women. AIDS Patient Care and STDs. 2001;15(3):137-45. Not a systematic review. [pmid: 11313026].
Mainous AG III, Koopman RJ, Gill JM, Baker R, Pearson WS. Relationship between continuity of care and diabetes control: evidence from the Third National Health and Nutrition Examination Survey. American Journal of Public Health. 2004;94(1):66-70. Not a systematic review. [pmid: 14713700]. [pmcid: 1449828].
Mannino FV, Shore MF. Consultation research in mental health and related fields; a critical review of the literature. Public Health Monogr. 1970;79:1-55. Not a systematic review. [pmid: 4935576].
Mark H, Mark T. Health service applications. Parental reasons for non-response following a referral in school vision screening. Journal of School Health. 1999;69(1):35-8. Not a systematic review. [pmid: 10098117].
Markey BT, Igou JF. Medication discharge planning for the elderly. Patient Education and Counseling. 1987;9(3):241-9. Not a systematic review. [pmid: 10282841].
Marsh MA. Discharge planning. Prairie Rose. 1992;61(2):9. Not a systematic review. [pmid: 1635903].
Marshall M, Fleming E, Gillibrand W, Carter B. Adaptation and negotiation as an approach to care in paediatric diabetes specialist nursing practice: a critical review. J Clin Nurs. 2002;11(4):421-9. Not care coordination. [pmid: 12100638].
Martire LM, Lustig AP, Schulz R, Miller GE, Helgeson VS. Title Is It Beneficial to Involve a Family Member? A Meta-Analysis of Psychosocial Interventions for Chronic Illness. Source Health Psychology. 2004;23(6):599-611. Not care coordination.
McAdam M, Wright N. A review of the literature considering the role of mental health nurses in assertive outreach. J Psychiatr Ment Health Nurs. Dec. 2005;12(6):648-60. Not care coordination. [pmid: 16336589].
McAlister FA, Lawson FM, Teo KK, Armstrong PW. A systematic review of randomized trials of disease management programs in heart failure. Am J Med. 2001;110(5):378-84. Duplicate publication. [pmid: 11286953].
McBride W, Ferrario C, Lyle PA. Hypertension and medical informatics. J Natl Med Assoc. 2003;95(11):1048-56. Not care coordination. [pmid: 14651371]. [pmcid: 2594689].
McCloskey JC. The nursing care plan: past, present, and uncertain future - a review of the literature. Nurs Forum. 1975;14(4):364-82. Not a systematic review. [pmid: 772631].
McCoy HV, Dodds S, Rivers JE, McCoy CB. Progress; Case management services for HIV seropositive IDU's. In R Ashery (Ed), Progress and issues in case management. Vol. 127. Rockville, MD: US Department of Health and Human Services, Alcohol, Drug Abuse, and Mental Health Administration; 1992. Not a systematic review
McKevitt C, Redfern J, Mold F, Wolfe C. Qualitative studies of stroke: a systematic review. Stroke. 2004;35(6):1499-505. Not care coordination. [pmid: 15105517].
McMahan EM, Hoffman K, McGee GW. Physician-nurse relationships in clinical settings: a review and critique of the literature, 1966-1992. Med Care Rev. 1994;51(1):83-112. Not a systematic review. [pmid: 10133007].
Melnick DM, Wahl WL, Dalton VK. Management of general surgical problems in the pregnant patient. Am J Surg. 2004;187(2):170-80. Not a systematic review. [pmid: 14769301].
Mezzich JE, Ruiz P, Munoz RA. Mental health care for Hispanic Americans: a current perspective. Cultur Divers Ethnic Minor Psychol. 1999;5(2):91-102. Not a systematic review. [pmid: 15605680].
Middleton J. The effect of case management on glycemic control in patients with type 2 diabetes. Case Manager. 2003;14(6):43-7. Not a systematic review. [pmid: 14618148].
Miller LA, Grunwald GK, Johnson SL, Krebs NF. Disease severity at time of referral for pediatric failure to thrive and obesity: time for a paradigm shift?. Journal of Pediatrics. 2002;141(1):121-4. Not a systematic review. [pmid: 12091862].
Millonig MK, Jackson TL, Ellis WM. Improving medication use through pharmacists' access to patient-specific health care information. J Am Pharm Assoc (Wash). 2002;42(4):638-45. No intervention evaluated. [pmid: 12150362].
Mills CS, Usher D. A kinship care case management approach. Child Welfare. 1996;75(5):600-18. Not a systematic review.
Minghella E, Ford R. Focal points. Health Service Journal. 1997;107(5583):26-7. Not a systematic review. [pmid: 10176078].
Mitchell E, Sullivan F. A descriptive feast but an evaluative famine: systematic review of published articles on primary care computing during 1980-97. BMJ. 2001;322(7281):279-82. Not care coordination. [pmid: 11157532]. [pmcid: 26582].
Molken MP, Van Doorslaer EK, Rutten FF. Economic appraisal of asthma and COPD care: a literature review 1980-1991. Soc Sci Med. 1992;35(2):161-75. Not care coordination. [pmid: 1509305].
Monninkhof E, van der Valk P, van der Palen J, van Herwaarden C, Partridge MR, Zielhuis G. Self-management education for patients with chronic obstructive pulmonary disease: a systematic review. Thorax. 2003;58(5):394-8. Not care coordination. [pmid: 12728158]. [pmcid: 1746688].
Monninkhof EM, van der Valk PD, van der Palen J, et al. Self-management education for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2003(1):CD002990. Not care coordination
Montori VM, Smith SA. Information systems in diabetes: in search of the holy grail in the era of evidence-based diabetes care. Exp Clin Endocrinol Diabetes. 2001;109(Suppl 2):S358-72. Not a systematic review. [pmid: 11460584].
Mulvihill BA, Cotton JN, Gyaben SL. Best practices for inclusive child and adolescent out-of-school care: a review of the literature. Fam Community Health. 2004;27(1):52-64. Not a systematic review. [pmid: 14724502].
Munderloh BJ. Managing COPD: using respiratory therapists as primary case managers. AARC Times. 1996;20(6):22-8. Not a systematic review.
Murray LP. The effectiveness of case managers in primary ambulatory care. Case Manager. 2003;14(4):66-8. Not a systematic review. [pmid: 12869954].
Naylor MD. Transitional care of older adults. Annual Review of Nursing Research. 2002;47(105 ref). No intervention evaluated
Newman M, Van den Bossche P, Gijbels D, et al. Responses to the pilot systematic review of problem-based learning. Med Educ. 2004;38(9):921-3. Not a systematic review. [pmid: 15327670].
Newton PJ, Davidson PM, Halcomb EJ, Denniss AR, Westgarth F. An introduction to the collaborative methodology and its potential use for the management of heart failure. J Cardiovasc Nurs. May–Jun. 2006;21(3):161-8. Not care coordination. [pmid: 16699354].
Norris SL, Engelgau MM, Narayan KM. Effectiveness of self-management training in type 2 diabetes: a systematic review of randomized controlled trials. Diabetes Care. 2001;24(3):561-87. Not care coordination. [pmid: 11289485].
Norris SL, Lau J, Smith SJ, Schmid CH, Engelgau MM. Self-management education for adults with type 2 diabetes: a meta-analysis of the effect on glycemic control. Diabetes Care. 2002;25(7):1159-71. Not care coordination. [pmid: 12087014].
Norris SL, Nichols PJ, Caspersen CJ, et al. Increasing diabetes self-management education in community settings. A systematic review. Am J Prev Med. 2002;22(4 Suppl):39-66. Not care coordination. [pmid: 11985934].
Odom SE, Herrick C, Holman C, Crowe E, Clements C. Case management for children with attention deficit hyperactivity disorder. Journal of School Nursing. 1994;10(3):17-21. Not a systematic review. [pmid: 7873901].
Ogrodniczuk JS, Joyce AS, Piper WE. Strategies for reducing patient-initiated premature termination of psychotherapy. Harv Rev Psychiatry. Mar–Apr. 2005;13(2):57-70. Not care coordination. [pmid: 16020021].
Okunade AA, Aronoff JB. Other voices. Determinants of specialty physician practice management integration. Managed Care Quarterly. 2000;8(1):61-71. Not a systematic review. [pmid: 11009736].
O'Malley AS, Gonzalez RM, Sheppard VB, Huerta E, Mandelblatt J. Primary care cancer control interventions including Latinos: a review. Am J Prev Med. 2003;25(3):264-71. Not care coordination. [pmid: 14507536].
Oroviogoicoechea C. The clinical nurse manager: a literature review. J Adv Nurs. 1996;24(6):1273-80. Not a systematic review. [pmid: 8953365].
Orzano AJ, Scott JG. Diagnosis and treatment of obesity in adults: an applied evidence-based review. J Am Board Fam Pract. 2004;17(5):359-69. Not care coordination. [pmid: 15355950].
Pacala JT, Boult C, Hepburn KW, et al. Case management of older adults in health maintenance organizations. Journal of the American Geriatrics Society. 1995;43(5):538-42. Not a systematic review. [pmid: 7730537].
Pachter S, Flics SS. Integrated care of patients with fractured hip by nursing and physical therapy. Patients and purse strings (Scherubel JC). National League for Nursing. 1988;2:441-3. (Pamphlet #20–2191) Not a systematic review.
Palmer E, Mayers SP Jr. Discharge planning effect on length of hospital stay. Archives of Physical Medicine and Rehabilitation. 1983;64(2):57-60. Not a systematic review. [pmid: 6824419].
Parker G, Bhakta P, Katbamna S, et al. Best place of care for older people after acute and during subacute illness: a systematic review. J Health Serv Res Policy. 2000;5(3):176-89. Not care coordination. [pmid: 11556369].
Parker M, Quinn J, Viehl M, et al. Issues in rural case management. Family & Community Health. 1992;14(4):40-60. Not a systematic review.
Parker M, Secord LJ. Private geriatric case management: an overview. Caring. 1987;6(12):20-3. Not a systematic review. [pmid: 10285200].
Peach H. Should Australia's hospitals be reviewing the use of research in patient care by nurses, managers and allied health professionals?—A systematic review of recent evidence. Aust Health Rev. 2003;26(2):49-62. Not care coordination. [pmid: 15368836].
Pelletier KR. A review and analysis of the clinical- and cost-effectiveness studies of comprehensive health promotion and disease management programs at the worksite: 1998-2000 update. American Journal of Health Promotion. 2001;16(2):107-16. Not care coordination. [pmid: 11727590].
Pelletier KR. Clinical and cost outcomes of multifactorial, cardiovascular risk management interventions in worksites: a comprehensive review and analysis. J Occup Environ Med. 1997;39(12):1154-69. Not care coordination. [pmid: 9429168].
Pengel HM, Maher CG, Refshauge KM. Systematic review of conservative interventions for subacute low back pain. Clin Rehabil. 2002;16(8):811-20. Not care coordination. [pmid: 12501942].
Persily CA. Lay home visiting may improve pregnancy outcomes. Holist Nurs Pract. 2003;17(5):231-8. Not care coordination. [pmid: 14596372].
Petticrew M, Sculpher M, Kelland J, Elliott R, Holdright D, Buxton M. Effective management of stable angina. Qual Health Care. 1998;7(2):109-16. Not care coordination. [pmid: 10180790]. [pmcid: 2483589].
Pirraglia PA, Rosen AB, Hermann RC, Olchanski NV, Neumann P. Cost-utility analysis studies of depression management: a systematic review. Am J Psychiatry. 2004;161(12):2155-62. No intervention evaluated. [pmid: 15569883].
Powell H, Gibson PG. Options for self-management education for adults with asthma. Cochrane Database Syst Rev. 2003(1):CD004107. Not care coordination
Proctor EK, Morrow-Howell N. Complications in discharge planning with Medicare patients. Health and Social Work. 1990;15(1):45-54. Not a systematic review. [pmid: 2156767].
Rat AC, Henegariu V, Boissier MC. Do primary care physicians have a place in the management of rheumatoid arthritis?. Joint Bone Spine. 2004;71(3):190-7. Not care coordination. [pmid: 15182789].
Reeves S, Meyer J, Glynn M, Bridges J. Coordination of interprofessional health care teams in a general and emergency medical directorate. Advancing Clinical Nursing. 1999;3(2):49-59. Not a systematic review.
Renders CM, Valk GD, Griffin SJ, Wagner EH, Eijk Van JT, Assendelft WJ. Interventions to improve the management of diabetes in primary care, outpatient, and community settings: a systematic review. Diabetes Care. 2001;24(10):1821-33. Duplicate publication. [pmid: 11574449].
Rich MW. Heart failure disease management: a critical review. J Card Fail. 1999;5(1):64-75. Not a systematic review. [pmid: 10194662].
Robinson L. Psychiatric liaison nursing 1962-1982: a review and update of the literature. Gen Hosp Psychiatry. 1982;4(2):139-45. Not a systematic review. [pmid: 7117829].
Roglieri JL. Partnering in CHF disease management. Comprehensive Therapy. Spring. 2001;27(1):28-38. Not a systematic review. [pmid: 11280853].
Roozen HG, Boulogne JJ, van Tulder MW, van den Brink W, De Jong CA, Kerkhof AJ. A systematic review of the effectiveness of the community reinforcement approach in alcohol, cocaine and opioid addiction. Drug Alcohol Depend. 2004;74(1):1-13. Not care coordination. [pmid: 15072802].
Rosen M, Lindqvist R, Stenbeck M. Revise the review process of the Cochrane collaboration. Scand J Public Health. 2002;30(3):238-9. Not a systematic review. [pmid: 12227981].
Rosen M. Behavioural techniques for the management of the child patient. A review of the literature. J Dent Assoc S Afr. 1980;35(10):689-93. Not a systematic review. [pmid: 7018025].
Ross H, Howlett J, Arnold JM, Liu P, O'Neill BJ, Brophy JM, et al. Treating the right patient at the right time: access to heart failure care. Can J Cardiol. Jul. 2006;22(9):749-54. Not a systematic review. [pmid: 16835668]. [pmcid: 2560514].
Roupe MY, Young SL. Interactive Home Telehealth: a complementary addition to disease management programs. Remington Report. 2003;11(4):14-6. Not a systematic review.
Rubenstein LZ, Stuck AE, Siu AL, Wieland D. Impacts of geriatric evaluation and management programs on defined outcomes: overview of the evidence. J Am Geriatr Soc. 1991;39(9 Pt 2):8S-16S. discussion 17S–18S. Not a systematic review. [pmid: 1832179].
Ruddy G, Rhee K. Transdisciplinary teams in primary care for the underserved: a literature review. J Health Care Poor Underserved. May. 2005;16(2):248-56. Not a systematic review. [pmid: 15937389].
Rushton J, Bruckman D, Kelleher K. Primary care referral of children with psychosocial problems. Archives of Pediatrics & Adolescent Medicine. 2002;156(6):592-8. Not a systematic review. [pmid: 12038893].
Ryan MJ Jr, Gibson J, Simmons P, Stanek E. Effectiveness of aggressive management of dyslipidemia in a collaborative-care practice model. American Journal of Cardiology. 2003;91(12):1427-31. Not a systematic review. [pmid: 12804728].
Salazar MK. Maximizing the effectiveness of case management service delivery. Case Manager. 2000;11(3):58-63. Not a systematic review. [pmid: 11935642].
Sarkisian CA, Brown AF, Norris KC, Wintz RL, Mangione CM. A systematic review of diabetes self-care interventions for older, African American, or Latino adults. Diabetes Educ. 2003;29(3):467-79. Not care coordination. [pmid: 12861963].
Saultz JW, Albedaiwi W. Interpersonal continuity of care and patient satisfaction: a critical review. Ann Fam Med. 2004;2(5):445-51. Not care coordination. [pmid: 15506579]. [pmcid: 1466724].
Saultz JW. Defining and measuring interpersonal continuity of care. Ann Fam Med. 2003;1(3):134-43. Not care coordination. [pmid: 15043374]. [pmcid: 1466595].
Schaefer AL, Anderson JA, Simms LM. Are they ready? Discharge planning for older surgical patients. Journal of Gerontological Nursing. Oct. 1990;16(10):16-9. Not a systematic review. [pmid: 2229954].
Schedlbauer A, Schroeder K, Peters TJ, Fahey T. Interventions to improve adherence to lipid lowering medication. Cochrane Database Syst Rev. 2004(4):CD004371. Not care coordination
Scheer SJ, Radack KL, O'Brien DR Jr. Randomized controlled trials in industrial low back pain relating to return to work. Part 1. Acute interventions. Arch Phys Med Rehabil. 1995;76(10):966-73. Not care coordination. [pmid: 7487440].
Schlemmer B. The status of discharge planning in intensive care units. Nursing Management;1989 Jul; 20(7):Crit Care Manage Ed: 88A–B. Not a systematic review
Schlenger WE, Kroutil LA, Roland EJ. Case management as a mechanism for linking drug abuse treatment and primary care: Preliminary evidence from the ADAMHA/HRSA linkage demonstration. In R Ashery (Ed), Progress and issues in case management. Vol. 127. Rockville, MD: US Department of Health and Human Services, Alcohol, Drug Abuse, and Mental Health Administration; 1992. Not a systematic review
Schlosser RJ, Bolger WE. Nasal cerebrospinal fluid leaks: critical review and surgical considerations. Laryngoscope. 2004;114(2):255-65. Not care coordination. [pmid: 14755200].
Schotland HM, Georeno AM, Pack AI. Obstructive sleep apnea: feasibility of a disease management strategy utilizing primary care case finding. Journal of Clinical Outcomes Management. 2000;7(7):34-8. Not a systematic review.
Schull DE, Tosch P, Wood M. Clinical nurse specialists as collaborative care managers. Nursing Management. 1992;23(3):30-3. Not a systematic review. [pmid: 1553138].
Scott JT, Harmsen M, Prictor MJ, Sowden AJ, Watt I. Interventions for improving communication with children and adolescents about their cancer. Cochrane Database Syst Rev. 2003(3):CD002969. Not care coordination
Sempowski IP, Brison RJ. Dealing with office emergencies. Stepwise approach for family physicians. Can Fam Physician. 2002;48:1464-72. Not care coordination. [pmid: 12371305]. [pmcid: 2214108].
Senlet P, Cagatay L, Ergin J, Mathis J. Bridging the gap: integrating family planning with abortion services in Turkey. International Family Planning Perspectives. 2001;27(2):90-5. Not a systematic review.
Seth CM, White R. Research to practice. No place like home. Children's Voice. 2004;13(2):35-6. Not a systematic review.
Shah MN, Schmit J, Croley WC, Meltzer D. Continuity of antibiotic therapy in patients admitted from the emergency department. Annals of Emergency Medicine. 2003;42(1):117-23. Not a systematic review. [pmid: 12827131].
Shepperd S, Parkes J, McClaren J, Phillips C. Discharge planning from hospital to home. Cochrane Database Syst Rev. 2004(1):CD000313. Not care coordination
Sherlock-Storey M, Milne D. What makes a good care manager? An analysis of care management skills in the mental health services. Health and Social Care in the Community. 1995;3(1):53-8. Not a systematic review.
Shiffman RN, Liaw Y, Brandt CA, Corb GJ. Computer-based guideline implementation systems: a systematic review of functionality and effectiveness. J Am Med Inform Assoc. 1999;6(2):104-14. Not care coordination. [pmid: 10094063]. [pmcid: 61349].
Shojania KG, Duncan BW, McDonald KM, Wachter RM, Markowitz AJ. Making health care safer: a critical analysis of patient safety practices. Evid Rep Technol Assess (Summ). 2001(43):i–x, 1–668. Study conducted in an in-patient setting only
Siebenhofer A, Berghold A, Sawicki PT. Systematic review of studies of self-management of oral anticoagulation. Thromb Haemost. 2004;91(2):225-32. Not care coordination. [pmid: 14961147].
Siehoff AM. Impact of unlicensed assistive personnel on patient satisfaction: an integrative review of the literature. J Nurs Care Qual. 1998;13(2):1-10. Not care coordination. [pmid: 9842170].
Silverman HJ, Vinicky JK, Gasner MR. Advance directives: implications for critical care. Crit Care Med. 1992;20(7):1027-31. Not a systematic review. [pmid: 1617972].
Sinnakaruppan I, Williams DM. Head injury and family carers: a critical appraisal of case management programmes in the community. International Journal of Rehabilitation Research. 2001;24(1):35-42. Not care coordination. [pmid: 11302462].
Skilbeck J, Payne S. Emotional support and the role of Clinical Nurse Specialists in palliative care. J Adv Nurs. 2003;43(5):521-30. Not care coordination. [pmid: 12919270].
Sloper P. Facilitators and barriers for co-ordinated multi-agency services. Child: Care, Health and Development. 2004;30(6):571-80. Not care coordination.
Smith GC. From consultation-liaison psychiatry to psychosocial advocacy: maintaining psychiatry's scope. Aust N Z J Psychiatry. 1998;32(6):753-61. discussion 762–6. Not a systematic review. [pmid: 10084339].
Sparbel KJH, Anderson MA. A continuity of care integrated literature review, part 2: methodological issues. Journal of Nursing Scholarship. 2000;32(2):131-5. Not care coordination. [pmid: 10887711].
Sparbel KJH, Anderson MA. Clinical scholarship. Integrated literature review of continuity of care: part 1, conceptual issues. Journal of Nursing Scholarship. 2000;32(1):17-24. Not care coordination. [pmid: 10819734].
Steiner A, Robinson R. Managed care: US research evidence and its lessons for the NHS. J Health Serv Res Policy. 1998;3(3):173-84. Not care coordination. [pmid: 10185377].
Stevens GD, Shi L. Racial and ethnic disparities in the primary care experiences of children: a review of the literature. Med Care Res Rev. 2003;60(1):3-30. Not care coordination. [pmid: 12674018].
Stewart S. Review: multidisciplinary interventions reduce hospital admission and all cause mortality in heart failure. Evidence-Based Nursing. Jan. 2006;9(1):23. Abstract. [pmid: 16437805].
Stewart SE, Manion IG, Davidson S. Emergency management of the adolescent suicide attempter: a review of the literature. J Adolesc Health. 2002;30(5):312-25. Not care coordination. [pmid: 11996780].
Stone EG, Morton SC, Hulscher ME, et al. Interventions that increase use of adult immunization and cancer screening services: a meta-analysis. Ann Intern Med. 2002;136(9):641-51. Not care coordination. [pmid: 11992299].
Stuck AE, Siu AL, Wieland GD, Adams J, Rubenstein LZ. Comprehensive geriatric assessment: a meta-analysis of controlled trials. Lancet. 1993;342(8878):1032-6. Not care coordination. [pmid: 8105269].
Sun AP. Program factors related to women's substance abuse treatment retention and other outcomes: a review and critique. J Subst Abuse Treat. Jan. 2006;30(1):1-20. Not care coordination. [pmid: 16377448].
Szilagyi PG, Bordley C, Vann JC, et al. Effect of patient reminder/recall interventions on immunization rates: A review. Jama. 2000;284(14):1820-7. Not care coordination. [pmid: 11025835].
Tait AR. Clinical governance in primary care: a literature review. J Clin Nurs. 2004;13(6):723-30. Not care coordination. [pmid: 15317512].
Taylor S, Bestall J, Cotter S, Falshaw M, Hood S, Parsons S, et al. Clinical service organisation for heart failure. Cochrane Database Syst Rev. 2005(2):CD002752. Not care coordination
Thomson O'Brien MA, Oxman AD, Davis DA, Haynes RB, Freemantle N, Harvey EL. Educational outreach visits: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2000(2):CD000409. Not care coordination
Thong BY, Hourihane JO. Monitoring of IgE-mediated food allergy in childhood. Acta Paediatr. 2004;93(6):759-64. Not a systematic review. [pmid: 15244223].
Toelle BG, Ram FS. Written individualised management plans for asthma in children and adults. Cochrane Database Syst Rev. 2004(2):CD002171. Not care coordination
Tomasi E, Facchini LA, Maia Mde F. Health information technology in primary health care in developing countries: a literature review. Bull World Health Organ. 2004;82(11):867-74. Not care coordination. [pmid: 15640923].
Tyrer P, Coid J, Simmonds S, Joseph P, Marriott S. Community mental health teams (CMHTs) for people with severe mental illnesses and disordered personality. Cochrane Database Syst Rev. 2000(2):CD000270. Duplicate publication
Tyrer P, Simmonds S. Treatment models for those with severe mental illness and comorbid personality disorder. Br J Psychiatry Suppl. 2003;44:S15-8. Not a systematic review. [pmid: 12509303].
van Dam HA, van der Horst F, van den Borne B, Ryckman R, Crebolder H. Provider-patient interaction in diabetes care: effects on patient self-care and outcomes. A systematic review. Patient Educ Couns. 2003;51(1):17-28. Not care coordination. [pmid: 12915276].
van der Feltz-Cornelis CM, Lyons JS, Huyse FJ, Campos R, Fink P, Slaets JP. Health services research on mental health in primary care. Int J Psychiatry Med. 1997;27(1):1-21. No intervention evaluated. [pmid: 9565710].
Van Manen L, Laschinger SJ, Stevenson T, Fothergill-Bourbonnais F. The nature of multidisciplinary HIV care in the ambulatory setting: a synthesis of the literature. J Assoc Nurses AIDS Care. Sep–Oct. 2005;16(5):49-57. Not a systematic review. [pmid: 16433109].
van Servellen G, Fongwa M, Mockus D'Errico E. Continuity of care and quality care outcomes for people experiencing chronic conditions: A literature review. Nurs Health Sci. Sep. 2006;8(3):185-95. Not an evaluation of an intervention. [pmid: 16911180].
Veeder NW. Care management as management. Care Management Journals: Journal of Case Management, The Journal of Long Term Home Health Care. 2001;3(2):68-76. Not a systematic review. [pmid: 12455217].
Vellozzi CJ, Romans M, Rothenberg RB. Delivering breast and cervical cancer screening services to underserved women: Part I. Literature review and telephone survey. Womens Health Issues. 1996;6(2):65-73. Not a systematic review. [pmid: 8932459].
Vukmir RB, Kremen R, Ellis GL, DeHart DA, Plewa MC, Menegazzi J. Compliance with emergency department referral: the effect of computerized discharge instructions. Annals of Emergency Medicine. 1993;22(5):819-23. Not a systematic review. [pmid: 8470839].
Waldenstrom U, Turnbull D. A systematic review comparing continuity of midwifery care with standard maternity services. Br J Obstet Gynaecol. 1998;105(11):1160-70. Not care coordination. [pmid: 9853764].
Warsi A, LaValley MP, Wang PS, Avorn J, Solomon DH. Arthritis self-management education programs: a meta-analysis of the effect on pain and disability. Arthritis Rheum. 2003;48(8):2207-13. Duplicate publication. [pmid: 12905474].
Warsi A, Wang PS, LaValley MP, Avorn J, Solomon DH. Self-management education programs in chronic disease: a systematic review and methodological critique of the literature. Arch Intern Med. 2004;164(15):1641-9. Not care coordination. [pmid: 15302634].
Waters E. Evidence-based paediatric practice and its relation to the Cochrane Collaboration. J Paediatr Child Health. 2003;39(2):137-8. Not a systematic review. [pmid: 12603804].
Watkins LO, Wagner EH. Nurse practitioner and physician adherence to standing orders criteria for consultation or referral. American Journal of Public Health. 1982;72:22-9. Not a systematic review. [pmid: 7053615]. [pmcid: 1649737].
Watson PM, Shortridge DL Jr, Jones DT, Rees RT, Stephens JT. Operational restructuring: a patient-focused approach. Nursing Administration Quarterly. 1991;16(1):45-52. Not a systematic review. [pmid: 1956573].
Weaver FM, Bryant FB. An analysis of decision making in discharge planning. Evaluation and the Health Professions. 1990;13(1):121-42. Not a systematic review.
Weigand JV, Gerson LW. Preventive care in the emergency department: should emergency departments institute a falls prevention program for elder patients? A systematic review. Acad Emerg Med. 2001;8(8):823-6. Not care coordination. [pmid: 11483459].
Weiner BJ, Savitz LA, Bernard S, Pucci LG. How do integrated delivery systems adopt and implement clinical information systems?. Health Care Management Review. 2004;29(1):51-66. Not a systematic review. [pmid: 14992484].
Weissert WG, Hirth RA, Chernew ME, Diwan S, Kim J. Case management: effects of improved risk and value information. Gerontologist. 2003;43(6):797-805. Not a systematic review. [pmid: 14704377].
Whellan DJ, Gaulden L, Gattis WA, et al. The benefit of implementing a heart failure disease management program. Archives of Internal Medicine. 2001;161(18):2223-8. Not a systematic review. [pmid: 11575979].
While A, Forbes A, Ullman R, Lewis S, Mathes L, Griffiths P. Good practices that address continuity during transition from child to adult care: synthesis of the evidence. Child: Care, Health and Development. 2004;30(5):439-52. No intervention evaluated.
Wilkinson D, Rutherford G. Population-based interventions for reducing sexually transmitted infections, including HIV infection. Cochrane Database Syst Rev. 2001(2):CD001220. Not care coordination
Williams A, Botti M. Issues concerning the on-going care of patients with comorbidities in acute care and post-discharge in Australia: a literature review. J Adv Nurs. 2002;40(2):131-40. Not care coordination. [pmid: 12366642].
Williams AJ, Baird SE. Literature review to establish nursing diagnosis cues for myelopathy patients. Orthop Nurs. 1984;3(5):9-15. Not care coordination. [pmid: 6567842].
Williams TL, May CR, Esmail A. Limitations of patient satisfaction studies in telehealthcare: A systematic review of the literature. Telemedicine Journal & e Health. 2001;7(4):293-316. Not care coordination. [pmid: 11886667].
Winkelman WJ, Leonard KJ. Overcoming structural constraints to patient utilization of electronic medical records: a critical review and proposal for an evaluation framework. J Am Med Inform Assoc. 2004;11(2):151-61. Not care coordination. [pmid: 14633932]. [pmcid: 353022].
Wisniowski J. Benchmarking the discharge planning process: reflections and findings. Continuum: An Interdisciplinary Journal on Continuity of Care. 1996;16(2):11-8. Not a systematic review.
Wolf FM, Guevara JP, Grum CM, Clark NM, Cates CJ. Educational interventions for asthma in children. Cochrane Database Syst Rev. 2003(1):CD000326. Not care coordination
Wolock I, Schlesinger E, Dinerman M, Seaton R. The posthospital needs and care of patients: implications for discharge planning. Social Work in Health Care. 1987;12(4):61-76. Not a systematic review. [pmid: 3433191].
Wood D, Schuster M, Donald-Sherbourne C, Duan N, Mazel R, Halfon N. Reducing missed opportunities to vaccinate during child health visits: how effective are parent education and case management?. Archives of Pediatrics & Adolescent Medicine. 1998;152(3):238-43. Not a systematic review. [pmid: 9529460].
Woodcock AJ, Kinmonth A, Campbell MJ, Griffin SJ, Spiegal NM. Diabetes care from diagnosis: effects of training in patient-centred care on beliefs, attitudes and behaviour of primary care professionals. Patient Education and Counseling. 1999;37(1):65-79. Not a systematic review. [pmid: 10640121].
Woods P, Richards D. Effectiveness of nursing interventions in people with personality disorders. J Adv Nurs. 2003;44(2):154-72. Not care coordination. [pmid: 14521682].
Wool MS, Guadagnoli E, Thomas M, Mor V. Negotiating concrete needs: short-term training for high-risk cancer patients. Health and Social Work. 1989;14(3):184-95. Not a systematic review. [pmid: 2673954].
Wright C, Catty J, Watt H, Burns T. A systematic review of home treatment services—classification and sustainability. Soc Psychiatry Psychiatr Epidemiol. 2004;39(10):789-96. Not care coordination. [pmid: 15669659].
Yeo M, Sawyer SM. Strategies to promote better outcomes in young people with chronic illnesses. Ann Acad Med Singapore. 2003;32(1):36-42. Not a systematic review. [pmid: 12625096].
Youde J, Ruse C, Parker S, Fotherby M. A high diagnostic rate in older patients attending an integrated syncope clinic. Journal of the American Geriatrics Society. 2000;48(7):783-7. Not a systematic review. [pmid: 10894317].
Young S. Case management and telehealth: outcomes and throughput. Lippincott's Case Management. 2004;9(6):300-2. Not a systematic review.