# Sample Data Abstraction Forms Level One (Screening Title and Abstract) Form

To see the Sample Data Abstraction Forms Level One (Screening Title and Abstract) Form, please select the link below. This link will take you to a PDF version of the forms.

Sample Data Abstraction Forms Level One (Screening Title and Abstract) Form