# Exact Search Strings

Medline^®^ Database Search

#1: Targets articles addressing care coordination

“Coordinated care” OR “care coordination” OR “collaborative care” OR “integrated care” OR “shared care” OR “transitional care” OR “comanagement” OR “case management” OR “synchronized care” OR “interdisciplinary care” OR “disease management” OR “Progressive Patient Care”[MeSH] OR “Continuity of Patient Care”[MeSH] OR “Patient-Centered Care”[MeSH] OR “Patient Care Planning”[MeSH] OR “Disease Management”[MeSH] OR “Delivery of Health Care, Integrated”[MeSH] OR (care AND (integrat* OR collaborat* OR coordinat* OR transition* OR interdisciplin* OR shared OR comanagement OR cooperat* OR aftercare OR interinstitution* OR synchron* OR harmon* OR manage*))

#2: Targets systematic reviews

((meta-analysis [pt] OR meta-analysis [tw] OR metanalysis [tw]) OR ((review [pt] OR guideline [pt] OR consensus [ti] OR guideline* [ti] OR literature [ti] OR overview [ti] OR review [ti] OR Decision Support Techniques [mh]) AND ((Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw])) OR (handsearch* [tw] OR search* [tw] OR searching [tw]) AND (hand [tw] OR manual [tw] OR electronic [tw] OR bibliographi* [tw] OR database* OR (Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw]))))) OR ((synthesis [ti] OR overview [ti] OR review [ti] OR survey [ti]) AND (systematic [ti] OR critical [ti] OR methodologic [ti] OR quantitative [ti] OR qualitative [ti] OR literature [ti] OR evidence [ti] OR evidence-based [ti]))) BUTNOT (case report [mh] OR case* [ti] OR report [ti] OR editorial [pt] OR comment [pt] OR letter [pt])

#3: Targets systematic reviews addressing care coordination

#1 and #2

#4: Limits articles found through search #3 to humans and English Language

#3 limited to English, Human

## Cumulative Index to Nursing and Allied Health (CINAHL^®^) Database Search

NOTE: Searching the CINAHL^®^ database required searching for different time frames as shown below. This search was updated to November 15, 2006.

#1: Targets disease management specific articles (1982 to May Week 2, 2005)

--------------------------------------------------------------------------------

1 “Continuity of Patient Care”/ or Case Management/ or care coordination.mp. (8222)
2 *“Continuity of Patient Care”/ (999)
3 exp *“Continuity of Patient Care”/ (1825)
4 3 (1825)
5 limit 4 to research (560)
6 exp research/ or study design/ (300305)
7 5 and 6 (526)
8 (“coordinated care” or “uncoordinated care”).mp. [mp=title, subject heading word, abstract, instrumentation] (120)
9 (“discontinuity of care” or “transfer of responsibility” or “documentation of follow-up” or “documentation of followup”).mp. [mp=title, subject heading word, abstract, instrumentation] (44)
10 (“handoff” or “consults” or referral or “information transfer” or “telephone care” or “care coordination” or “discharge planning”).mp. [mp=title, subject heading word, abstract, instrumentation] (11922)
11 (“collaborative care” or “integrated care” or “shared care” or “transitional care” or “comanagement” or “synchronized care”).mp. [mp=title, subject heading word, abstract, instrumentation] (1991)
12 (“interdisciplinary care” or “disease management” or “case management”).mp. [mp=title, subject heading word, abstract, instrumentation] (9912)
13 case management/ or progressive patient care/ (6366)
14 continuity of patient care/ (2086)
15 case management/ or patient centered care/ (8850)
16 Nursing Care Plans/ or patient care planning.mp. (2033)
17 Health Care Delivery, Integrated/ (952)
18 (care and (integrat$ or collaborat$ or coordinat$ or transition$ or interdisciplin$ or shared or comanagement or cooperat$ or aftercare or interinstitution$ or synchron$ or harmon$ or manage$)).mp. [mp=title, subject heading word, abstract, instrumentation] (60301)
19 1 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 (76912)
20 limit 19 to research (22658)
21 1 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 (28054)
22 limit 21 to research (8216)
23 (“care coordination” or “coordinated care” or “uncoordinated care” or “discontinuity of care” or “transfer of responsibility” or “documentation of followup” or “documentation of follow-up”).m_titl. (114)
24 (handoff or referral or consults or “information transfer” or “telephone care” or “collaborative care” or “integrated care” or “shared care” or “transitional care” or “synchronized care” or comanagement or “interdisciplinary care”).m_titl. (1203)
25 (“discharge planning” or “case management” or “disease management”).m_titl. (3528)
26 *“Continuity of Patient Care”/ or *“Health Care Delivery, Integrated”/ or *“Case Management”/ or *“Progressive Patient Care”/ or *“Patient Centered Care”/ (7733)
27 *“Nursing Care Plans”/ or *“Patient Care Planning”/ (560)
28 23 or 24 or 26 (8901)
29 limit 28 to research (1616)
30 25 or 27 (4081)
31 limit 30 to research (741)
32 31 not 29 (383)
33 from 32 keep 1–383 (383)

#2: Targets case management specific articles (1982 to May Week 2, 2005)

--------------------------------------------------------------------------------

1 “Continuity of Patient Care”/ or Case Management/ or care coordination.mp. (8222)
2 *“Continuity of Patient Care”/ (999)
3 exp *“Continuity of Patient Care”/ (1825)
4 3 (1825)
5 limit 4 to research (560)
6 exp research/ or study design/ (300305)
7 5 and 6 (526)
8 (“coordinated care” or “uncoordinated care”).mp. [mp=title, subject heading word, abstract, instrumentation] (120)
9 (“discontinuity of care” or “transfer of responsibility” or “documentation of follow-up” or “documentation of followup”).mp. [mp=title, subject heading word, abstract, instrumentation] (44)
10 (“handoff” or “consults” or referral or “information transfer” or “telephone care” or “care coordination” or “discharge planning”).mp. [mp=title, subject heading word, abstract, instrumentation] (11922)
11 (“collaborative care” or “integrated care” or “shared care” or “transitional care” or “comanagement” or “synchronized care”).mp. [mp=title, subject heading word, abstract, instrumentation] (1991)
12 (“interdisciplinary care” or “disease management” or “case management”).mp. [mp=title, subject heading word, abstract, instrumentation] (9912)
13 case management/ or progressive patient care/ (6366)
14 continuity of patient care/ (2086)
15 case management/ or patient centered care/ (8850)
16 Nursing Care Plans/ or patient care planning.mp. (2033)
17 Health Care Delivery, Integrated/ (952)
18 (care and (integrat$ or collaborat$ or coordinat$ or transition$ or interdisciplin$ or shared or comanagement or cooperat$ or aftercare or interinstitution$ or synchron$ or harmon$ or manage$)).mp. [mp=title, subject heading word, abstract, instrumentation] (60301)
19 1 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 (76912)
20 limit 19 to research (22658)
21 1 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 (28054)
22 limit 21 to research (8216)
23 (“care coordination” or “coordinated care” or “uncoordinated care” or “discontinuity of care” or “transfer of responsibility” or “documentation of followup” or “documentation of follow-up”).m_titl. (114)
24 (handoff or referral or consults or “information transfer” or “telephone care” or “collaborative care” or “integrated care” or “shared care” or “transitional care” or “synchronized care” or comanagement or “interdisciplinary care”).m_titl. (1203)
25 (“discharge planning” or “case management” or “disease management”).m_titl. (3528)
26 *“Continuity of Patient Care”/ or *“Health Care Delivery, Integrated”/ or *“Case Management”/ or *“Progressive Patient Care”/ or *“Patient Centered Care”/ (7733)
27 *“Nursing Care Plans”/ or *“Patient Care Planning”/ (560)
28 23 or 24 or 26 (8901)
29 limit 28 to research (1616)
30 25 or 27 (4081)
31 limit 30 to research (741)
32 31 not 29 (383)
33 from 32 keep 1–383 (383)
34 29 and 31 (358)
35 from 34 keep 1–358 (358)

#3: Targets articles that have the term “care coord” in title/abstract (2003 to 2005)

(NOTE: Searches 3, 4, 5 and 6 are the same except for the years searched)

--------------------------------------------------------------------------------

1 “Continuity of Patient Care”/ or Case Management/ or care coordination.mp. (8222)
2 *“Continuity of Patient Care”/ (999)
3 exp *“Continuity of Patient Care”/ (1825)
4 3 (1825)
5 limit 4 to research (560)
6 exp research/ or study design/ (300305)
7 5 and 6 (526)
8 (“coordinated care” or “uncoordinated care”).mp. [mp=title, subject heading word, abstract, instrumentation] (120)
9 (“discontinuity of care” or “transfer of responsibility” or “documentation of follow-up” or “documentation of followup”).mp. [mp=title, subject heading word, abstract, instrumentation] (44)
10 (“handoff” or “consults” or referral or “information transfer” or “telephone care” or “care coordination” or “discharge planning”).mp. [mp=title, subject heading word, abstract, instrumentation] (11922)
11 (“collaborative care” or “integrated care” or “shared care” or “transitional care” or “comanagement” or “synchronized care”).mp. [mp=title, subject heading word, abstract, instrumentation] (1991)
12 (“interdisciplinary care” or “disease management” or “case management”).mp. [mp=title, subject heading word, abstract, instrumentation] (9912)
13 case management/ or progressive patient care/ (6366)
14 continuity of patient care/ (2086)
15 case management/ or patient centered care/ (8850)
16 Nursing Care Plans/ or patient care planning.mp. (2033)
17 Health Care Delivery, Integrated/ (952)
18 (care and (integrat$ or collaborat$ or coordinat$ or transition$ or interdisciplin$ or shared or comanagement or cooperat$ or aftercare or interinstitution$ or synchron$ or harmon$ or manage$)).mp. [mp=title, subject heading word, abstract, instrumentation] (60301)
19 1 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 (76912)
20 limit 19 to research (22658)
21 1 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 (28054)
22 limit 21 to research (8216)
23 (“care coordination” or “coordinated care” or “uncoordinated care” or “discontinuity of care” or “transfer of responsibility” or “documentation of followup” or “documentation of follow-up”).m_titl. (114)
24 (handoff or referral or consults or “information transfer” or “telephone care” or “collaborative care” or “integrated care” or “shared care” or “transitional care” or “synchronized care” or comanagement or “interdisciplinary care”).m_titl. (1203)
25 (“discharge planning” or “case management” or “disease management”).m_titl. (3528)
26 *“Continuity of Patient Care”/ or *“Health Care Delivery, Integrated”/ or *“Case Management”/ or *“Progressive Patient Care”/ or *“Patient Centered Care”/ (7733)
27 *“Nursing Care Plans”/ or *“Patient Care Planning”/ (560)
28 23 or 24 or 26 (8901)
29 limit 28 to research (1616)
30 25 or 27 (4081)
31 limit 30 to research (741)
32 31 not 29 (383)
33 from 32 keep 1–383 (383)
34 29 and 31 (358)
35 from 34 keep 1–358 (358)
36 29 not (31 or 32 (1258)
37 from 36 keep 1–1258 (1258)
38 limit 37 to yr=2003 - 2005 (352)
39 from 38 keep 1–352 (352)

#4: Targets articles that have the term “care coord” in title/abstract (2000 to 2002)

Search strategy used is same as #3.

#5: Targets articles that have the term “care coord” in title/abstract (1995 to 1999)

Search strategy used is same as #3.

#6: Targets articles that have the term “care coord” in title/abstract (1966 to 1994)

Search strategy used is same as #3.

## Cochrane Database of Systematic Reviews, American College of Physicians Journal Club, Database of Abstracts of Reviews of Effects

(through November 15, 2006)

1 “Continuity of Patient Care”/ or Case Management/ or care coordination.mp. (294)
2 “Quality of Health Care”/ or Quality Improvement/ or improv$.mp. (63628)
3 1 and 2 (118)
4 from 3 keep 2,5–8,10 (6)
5 from 3 keep 3–4,11–12,14,19,22,25–26,28,46,50–51,53,70 (15)
6 care coordination.m_titl. (5)
7 [from 6 keep 2–4,6–15,17–20,22–24,26–27,29–30] (0)
8 5 or 7 (15)
9 [from 8 keep 1–39] (0)
10 from 8 keep 5,7–10,13–15 (8)

## PsychInfo Database Search

Search updated to November 15, 2006

1872 to May Week 5, 2005

--------------------------------------------------------------------------------

1 “Continuity of Patient Care”/ or Case Management/ or care coordination.mp. (1573)
2 (“coordinated care” or “uncoordinated care”).mp. [mp=title, abstract, subject headings, table of contents, key concepts] (47)
3 integrated care.mp. [mp=title, abstract, subject headings, table of contents, key concepts] (124)
4 “Quality of Health Care”/ or Quality Improvement/ or improv$.mp. (113208)
5 1 or 2 or 3 (1730)
6 4 and 5 (282)
7 from 6 keep 1–22 (22)
8 from 6 keep 23–209 (187)
9 exp meta analysis/ (2588)
10 6 and 9 (0)
11 5 and 9 (0)
12 exp “literature review”/ (22105)
13 5 and 9 (0)
14 5 and review.mp. [mp=title, abstract, subject headings, table of contents, key concepts] (170)
15 14 and systematic.mp. [mp=title, abstract, subject headings, table of contents, key concepts] (9)
16 from 15 keep 2 (1)
17 “systematic review”.m_titl. (536)
18 5 and 17 (1)
19 exp integrated services/ (1061)
20 case management/ or discharge planning/ (1622)
21 19 or 20 or 5 (2826)
22 21 and 17 (1)
23 21 and (metanalysis or “meta analysis” or “systematic review”).mp. [mp=title, abstract, subject headings, table of contents, key concepts] (7)
24 from 23 keep 1–7 (7)

## Sociological Abstracts Database and Social Services Abstracts Database Search

Through November 15, 2006

--------------------------------------------------------------------------------

Systematic review and (coordinated care or continuous care or uncoordinated care or care planning)