# Appendixes

Appendix A Exact Search Strings

Appendix B Sample Data Abstraction Forms Level One (Screening Title and Abstract) Form

Appendix C List of Excluded Reviews

Appendix D Technical Expert Panel and Peer Reviewers