# List of Acronyms/Abbreviations

Acronym/Abbreviation | Meaning
ARIMA | Autoregressive integrated moving-average
CAUTI | Catheter-associated urinary tract infection
CABG | Coronary artery bypass graft
CDC | Centers for Disease Control and Prevention
CLABSI | Catheter line-associated blood stream infection
CPOE | Computerized physician order entry
CVC | Central venous catheter
DVT | Deep vein thrombosis
EPOC | Cochrane Effective Practice and Organisation of Care
ICU | Intensive care unit
IHI | Institute for
ITS | Interrupted time series
HAI | Healthcare-associated infection
HICPAC | Healthcare Infection Control Practices Advisory Committee
JCAHO | Joint Commission for Accreditation of Healthcare Organizations
LCBI | Laboratory Confirmed Bloodstream Infection
MICU | Medical intensive care unit
NNIS | National Nosocomial Infection Surveillance System
NSIPP | National Surgical Infection Prevention Project
QI | Quality improvement
RCP | Respiratory care practitioners
SBT | Simple before-after
SCIP | Surgical Care Improvement Project
SENIC | Study of the Effectiveness of Nosocomial Infection Control
SICU | Surgical intensive care unit
SSI | Surgical site infection
VAP | Ventilator-associated pneumonia