# References and Included Studies

1 Weinstein RA. Nosocomial infection update. Emerg Infect Dis. Jul–Sep. 1998;4(3):416-20. [pmid: 9716961].
2 Harbarth S, Sax H, Gastmeier P. The preventable proportion of nosocomial infections: an overview of published reports. J Hosp Infect. Aug. 2003;54(4):258-66. quiz 321. [pmid: 12919755].
3 Haley RW, Culver DH, White JW, et al. The efficacy of infection surveillance and control programs in preventing nosocomial infections in US hospitals. Am J Epidemiol. Feb. 1985;121(2):182-205. [pmid: 4014115].
4 Weinstein RA, Siegel JD, Brennan PJ. Infection-control report cards—securing patient safety. N Engl J Med. Jul 21. 2005;353(3):225-7. [pmid: 16034007].
5 McKibben L, Horan TC, Tokars JI, et al. Guidance on public reporting of healthcare-associated infections: recommendations of the Healthcare Infection Control Practices Advisory Committee. Infect Control Hosp Epidemiol. Jun. 2005;26(6):580-7. [pmid: 16018435].
6 Joint Commission on Accreditation of Healthcare Organizations 2007 National Patient Safety Goals. Available online athttp://www.jointcommission.org/PatientSafety/NationalPatientSafetyGoals/07_hap_cah_npsgs.htm. Accessed July 1, 2006.
7 Institute for Healthcare Improvement “100,000 Lives” campaign. Available online athttp://www.ihi.org/IHI/Programs/Campaign/. Accessed July 1, 2006.
8 Institute of Medicine. Priority Areas for National Action: Transforming Health Care Quality. Adams K and Corrigan JM, eds. National Academy Press.
9 Thomas EJ, Studdert DM, Burstin HR, et al. Incidence and types of adverse events and negligent care in Utah and Colorado. Med Care. Mar. 2000;38(3):261-71. [pmid: 10718351].
10 Warren DK, Kollef MH. Prevention of hospital infection. Microbes Infect. Feb. 2005;7(2):268-74. [pmid: 15725388].
11 Saint S, Savel RH, Matthay MA. Enhancing the safety of critically ill patients by reducing urinary and central venous catheter-related infections. Am J Respir Crit Care Med. Jun 1. 2002;165(11):1475-9. [pmid: 12045119].
12 Jarvis WR. Benchmarking for prevention: the Centers for Disease Control and Prevention's National Nosocomial Infections Surveillance (NNIS) system experience. Infection. Dec. 2003;31(Suppl 2):44-8. [pmid: 15018472].
13 Mangram AJ, Horan TC, Pearson ML, et al. Guideline for Prevention of Surgical Site Infection, 1999. Centers for Disease Control and Prevention (CDC) Hospital Infection Control Practices Advisory Committee. Am J Infect Control. Apr. 1999;27(2):97-132. quiz 3–4; discussion 96. [pmid: 10196487].
14 National Nosocomial Infections Surveillance (NNIS) System Report, data summary from January 1992 through June 2004, issued October 2004. Am J Infect Control. 2004 Dec; 32(8): 470–85
15 Martone W, Jarvis W, Culver D, et al. In: Bennett JV, Brachman PS, eds. Hospital Infections. 3rd ed. Boston: Little, Brown and Co; 1992. p. 577–96.
16 Perencevich EN, Sands KE, Cosgrove SE, et al. Health and economic impact of surgical site infections diagnosed after hospital discharge. Emerg Infect Dis. Feb. 2003;9(2):196-203. [pmid: 12603990].
17 Bratzler DW, Houck PM. Antimicrobial prophylaxis for surgery: an advisory statement from the National Surgical Infection Prevention Project. Clin Infect Dis. Jun 15. 2004;38(12):1706-15. [pmid: 15227616].
18 Bratzler DW, Houck PM, Richards C, et al. Use of antimicrobial prophylaxis for major surgery: baseline results from the National Surgical Infection Prevention Project. Arch Surg. Feb. 2005;140(2):174-82. [pmid: 15724000].
19 Dellinger EP, Hausmann SM, Bratzler DW, et al. Hospitals collaborate to decrease surgical site infections. Am J Surg. Jul. 2005;190(1):9-15. [pmid: 15972163].
20 McGee DC, Gould MK. Preventing complications of central venous catheterization. N Engl J Med. Mar 20. 2003;348(12):1123-33. [pmid: 12646670].
21 Eggimann P, Sax H, Pittet D. Catheter-related infections. Microbes Infect. Sep. 2004;6(11):1033-42. [pmid: 15345236].
22 De Gaudio AR, Di Filippo A. Device-related infections in critically ill patients. Part I: Prevention of catheter-related bloodstream infections. J Chemother. Oct. 2003;15(5):419-27. [pmid: 14598934].
23 O'Grady NP. Applying the science to the prevention of catheter-related infections. J Crit Care. Jun. 2002;17(2):114-21. [pmid: 12096374].
24 O'Grady NP, Alexander M, Dellinger EP, et al. Guidelines for the prevention of intravascular catheter-related infections. Am J Infect Control. Dec. 2002;30(8):476-89. [pmid: 12461511].
25 Chaiyakunapruk N, Veenstra DL, Lipsky BA, et al. Chlorhexidine compared with povidone-iodine solution for vascular catheter-site care: a meta-analysis. Ann Intern Med. Jun 4. 2002;136(11):792-801. [pmid: 12044127].
26 Hu KK, Lipsky BA, Veenstra DL, et al. Using maximal sterile barriers to prevent central venous catheter-related infection: a systematic evidence-based review. Am J Infect Control. May. 2004;32(3):142-6. [pmid: 15153925].
27 Warren DK, Yokoe DS, Climo MW, et al. Preventing catheter-associated bloodstream infections: a survey of policies for insertion and care of central venous catheters from hospitals in the prevention epicenter program. Infect Control Hosp Epidemiol. Jan. 2006;27(1):8-13. [pmid: 16418980].
28 Collard HR, Saint S, Matthay MA. Prevention of ventilator-associated pneumonia: an evidence-based systematic review. Ann Intern Med. Mar 18. 2003;138(6):494-501. [pmid: 12639084].
29 Kollef MH. Prevention of hospital-associated pneumonia and ventilator-associated pneumonia. Crit Care Med. Jun. 2004;32(6):1396-405. [pmid: 15187525].
30 Safdar N, Dezfulian C, Collard HR, et al. Clinical and economic consequences of ventilator-associated pneumonia: a systematic review. Crit Care Med. Oct. 2005;33(10):2184-93. [pmid: 16215368].
31 Isakow W, Kollef MH. Preventing ventilator-associated pneumonia: an evidence-based approach of modifiable risk factors. Semin Respir Crit Care Med. Feb. 2006;27(1):5-17. [pmid: 16508876].
32 Tablan OC, Anderson LJ, Besser R, et al. Guidelines for preventing health-care—associated pneumonia, 2003: recommendations of CDC and the Healthcare Infection Control Practices Advisory Committee. MMWR Recomm Rep. Mar 26. 2004;53(RR-3):1-36. [pmid: 15048056].
33 Dodek P, Keenan S, Cook D, et al. Evidence-based clinical practice guideline for the prevention of ventilator-associated pneumonia. Ann Intern Med. Aug 17. 2004;141(4):305-13. [pmid: 15313747].
34 Saint S. Clinical and economic consequences of nosocomial catheter-related bacteriuria. Am J Infect Control. Feb. 2000;28(1):68-75. [pmid: 10679141].
35 Trautner BW, Darouiche RO. Catheter-associated infections: pathogenesis affects prevention. Arch Intern Med. Apr 26. 2004;164(8):842-50. [pmid: 15111369].
36 Tambyah PA. Catheter-associated urinary tract infections: diagnosis and prophylaxis. Int J Antimicrob Agents. Sep. 2004;24(Suppl 1):S44-8. [pmid: 15364306].
37 Tambyah PA, Maki DG. Catheter-associated urinary tract infection is rarely symptomatic: a prospective study of 1,497 catheterized patients. Arch Intern Med. Mar 13. 2000;160(5):678-82. [pmid: 10724054].
38 Saint S, Lipsky BA, Goold SD. Indwelling urinary catheters: a one-point restraint?. Ann Intern Med. Jul 16. 2002;137(2):125-7. [pmid: 12118969].
39 Saint S, Wiese J, Amory JK, et al. Are physicians aware of which of their patients have indwelling urinary catheters?. Am J Med. Oct 15. 2000;109(6):476-80. [pmid: 11042237].
40 Wong ES. Guideline for prevention of catheter-associated urinary tract infections. Am J Infect Control. Feb. 1983;11(1):28-36. [pmid: 6551151].
41 Bratzler DW, Houck PM. Antimicrobial prophylaxis for surgery: an advisory statement from the National Surgical Infection Prevention Project. Am J Surg. Apr. 2005;189(4):395-404. [pmid: 15820449].
42 Veenstra DL, Saint S, Saha S, et al. Efficacy of antiseptic-impregnated central venous catheters in preventing catheter-related bloodstream infection: a meta-analysis. Jama. Jan 20. 1999;281(3):261-7. [pmid: 9918482].
43 Johnson JR, Kuskowski MA, Wilt TJ. Systematic review: antimicrobial urinary catheters to prevent catheter-associated urinary tract infection in hospitalized patients. Ann Intern Med. Jan 17. 2006;144(2):116-26. [pmid: 16418411].
44 Nolan T, Berwick DM. All-or-none measurement raises the bar on performance. Jama. Mar 8. 2006;295(10):1168-70. [pmid: 16522838].
45 Making Health Care Safer: A Critical Analysis of Patient Safety Practices. Evidence Report/Technology Assessment: Number 43. AHRQ Publication No. 01-E058, July 2001. Agency for Healthcare Research and Quality, Rockville, MD.http://www.ahrq.gov/clinic/ptsafety/.
46 Naikoba S, Hayward A. The effectiveness of interventions aimed at increasing handwashing in healthcare workers - a systematic review. J Hosp Infect. Mar. 2001;47(3):173-80. [pmid: 11247676].
47 Shojania K, Ranji SR, Shaw LK, Charo LN, Lai JC, Rushakoff RJ, McDonald KM, Owens DK Diabetes Mellitus Care. Vol. 2 of: Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9 (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No 04-0051-2 Rockville, MD: Agency for Healthcare Research and Quality. 2004.
48 Ranji S, Steinman M, Shojania K, et al. Antibiotic Prescribing Behavior. Vol. 4 of: Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9 (Prepared by the Stanford University-UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No 04(06)-0051–4 Rockville, MD: Agency for Healthcare Research and Quality. 2006.
49 EPOC Register. Cochrane Effective Practice and Organisation of Care Group. November 4, 2002. Available at:http://www.epoc.uottawa.ca/register.htm. Accessed June 11, 2006.
50 National Nosocomial Infections Surveillance (NNIS) System Report, data summary from January 1992 through June 2003, issued August 2003. Am J Infect Control. 2003 Dec;31(8):481–98.
51 Bruce J, Russell EM, Mollison J, et al. The quality of measurement of surgical wound infection as the basis for monitoring: a systematic review. J Hosp Infect. Oct. 2001;49(2):99-108. [pmid: 11567554].
52 Wilson AP, Gibbons C, Reeves BC, et al. Surgical wound infection as a performance indicator: agreement of common definitions of wound infection in 4773 patients. Bmj. Sep 25. 2004;329(7468):720. [pmid: 15367425]. [pmcid: 518898].
53 Shojania KG, Grimshaw JM. Evidence-based quality improvement: the state of the science. Health Aff (Millwood). 2005 Jan-Feb;24(1):138–50.
54 Harris AD, Lautenbach E, Perencevich E. A systematic review of quasi-experimental study designs in the fields of infection control and antibiotic resistance. Clin Infect Dis. Jul 1. 2005;41(1):77-82. [pmid: 15937766].
55 Harris AD, Bradham DD, Baumgarten M, et al. The use and interpretation of quasi-experimental studies in infectious diseases. Clin Infect Dis. Jun 1. 2004;38(11):1586-91. [pmid: 15156447].
56 Emori TG, Edwards JR, Culver DH, et al. Accuracy of reporting nosocomial infections in intensive-care-unit patients to the National Nosocomial Infections Surveillance System: a pilot study. Infect Control Hosp Epidemiol. May. 1998;19(5):308-16. [pmid: 9613690].
57 Huenger F, Schmachtenberg A, Haefner H, et al. Evaluation of postdischarge surveillance of surgical site infections after total hip and knee arthroplasty. Am J Infect Control. Oct. 2005;33(8):455-62. [pmid: 16216659].
58 Mannien J, Wille JC, Snoeren RL, et al. Impact of postdischarge surveillance on surgical site infection rates for several surgical procedures: results from the nosocomial surveillance network in The Netherlands. Infect Control Hosp Epidemiol. Aug. 2006;27(8):809-16. [pmid: 16874640].
59 Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. Jama. Sep 15. 1999;282(11):1054-60. [pmid: 10493204].
60 Berg DE, Hershow RC, Ramirez CA, et al. Control of nosocomial infections in an intensive care unit in Guatemala City. Clin Infect Dis. Sep. 1995;21(3):588-93. [pmid: 8527548].
61 Greco D, Moro ML, Tozzi AE, et al. Effectiveness of an intervention program in reducing postoperative infections. Italian PRINOS Study Group. Am J Med. Sep 16. 1991;91(3B):164S-9S. [pmid: 1928159].
62 Lam B, Lee J, YL L. Hand hygiene practices in a neonatal intensive care unit: a multimodal intervention and impact on nosocomial infection. Pediatrics. 2004;114(5):e565-71. [pmid: 15492360].
63 Landgren FT, Harvey KJ, Mashford ML, et al. Changing antibiotic prescribing by educational marketing. Medical Journal of Australia. 1988;149(1112):595. [pmid: 3200183].
64 Ritchie S, Scanlon N, Lewis M, et al. Use of a preprinted sticker to improve the prescribing of prophylactic antibiotics for hip fracture surgery. Quality & Safety in Health Care. 2004;13(5):384. [pmid: 15465943]. [pmcid: 1743887].
65 Shapiro M, Sacks T, Simchen E, et al. Antibiotic use on the surgical services of two Jerusalem hospitals, as determined by surveillance and influenced by an intervention program. Rev Infect Dis. Jul–Aug. 1981;3(4):754-9. [pmid: 7339789].
66 Gastmeier P, Brauer H, Forster D, et al. A quality management project in 8 selected hospitals to reduce nosocomial infections: a prospective, controlled study. Infect Control Hosp Epidemiol. Feb. 2002;23(2):91-7. [pmid: 11893154].
67 Weinberg M, Fuentes JM, Ruiz AI, et al. Reducing infections among women undergoing cesarean section in Colombia by means of continuous quality improvement methods. Arch Intern Med. Oct 22. 2001;161(19):2357-65. [pmid: 11606152].
68 Cavalcante MD, Braga OB, Teofilo CH, et al. Cost improvements through the establishment of prudent infection control practices in a Brazilian general hospital, 1986–1989. Infect Control Hosp Epidemiol. Nov. 1991;12(11):649-53. [pmid: 1753079].
69 Haycock C, Laser C, Keuth J, et al. Implementing evidence-based practice findings to decrease postoperative sternal wound infections following open heart surgery. J Cardiovasc Nurs. Sep–Oct. 2005;20(5):299-305. [pmid: 16141774].
70 Lutarewych M, Morgan SP, Hall MM. Improving outcomes of coronary artery bypass graft infections with multiple interventions: putting science and data to the test. Infect Control Hosp Epidemiol. Jun. 2004;25(6):517-9. [pmid: 15242203].
71 Reilly JS, Baird D, Hill R. The importance of definitions and methods in surgical wound infection audit. J Hosp Infect. Jan. 2001;47(1):64-6. [pmid: 11161901].
72 Schelenz S, Tucker D, Georgeu C, et al. Significant reduction of endemic MRSA acquisition and infection in cardiothoracic patients by means of an enhanced targeted infection control programme. J Hosp Infect. Jun. 2005;60(2):104-10. [pmid: 15866007].
73 Talon D, Mourey F, Touratier S, et al. Evaluation of current practices in surgical antimicrobial prophylaxis before and after implementation of local guidelines. J Hosp Infect. Nov. 2001;49(3):193-8. [pmid: 11716636].
74 Borer A, Gilad J, Hyam E, et al. Prevention of infections associated with permanent cardiac antiarrhythmic devices by implementation of a comprehensive infection control program. Infect Control Hosp Epidemiol. Jun. 2004;25(6):492. [pmid: 15242198].
75 Brusaferro S, Rinaldi O, Pea F, et al. Protocol implementation in hospital infection control practice: an Italian experience of preoperative antibiotic prophylaxis. J Hosp Infect. Apr. 2001;47(4):288-93. [pmid: 11289772].
76 Larsen RA, Evans RS, Burke JP, et al. Improved perioperative antibiotic use and reduced surgical wound infections through use of computer decision analysis. Infect Control Hosp Epidemiol. Jul. 1989;10(7):316-20. [pmid: 2745959].
77 Smith KS, Quercia RA, Chow MS, et al. Multidisciplinary program for promoting single prophylactic doses of cefazolin in obstetrical and gynecological surgical procedures. Am J Hosp Pharm. Jun. 1988;45(6):1338-42. [pmid: 3414702].
78 St Jacques P, Sanders N, Patel N, et al. Improving timely surgical antibiotic prophylaxis redosing administration using computerized record prompts. Surg Infect (Larchmt). 2005;6(2):215-21. [pmid: 16128628].
79 Zanetti G, Flanagan HL Jr, Cohn LH, et al. Improvement of intraoperative antibiotic prophylaxis in prolonged cardiac surgery by automated alerts in the operating room. Infect Control Hosp Epidemiol. Jan. 2003;24(1):13-6. [pmid: 12558230].
80 Gyssens IC, Geerligs IE, Nannini-Bergman MG, et al. Optimizing the timing of antimicrobial prophylaxis in surgery: an intervention study. J Antimicrob Chemother. Aug. 1996;38(2):301-8. [pmid: 8877546].
81 Atukorala SD. Monitoring effectiveness of controlling hospital acquired infections by prevalence surveys. Ceylon Med J. Sep. 1998;43(3):134-7. [pmid: 9813930].
82 McConkey SJ, L'Ecuyer PB, Murphy DM, et al. Results of a comprehensive infection control program for reducing surgical-site infections in coronary artery bypass surgery. Infect Control Hosp Epidemiol. Aug. 1999;20(8):533-8. [pmid: 10466552].
83 Prado MA, Lima MP, Gomes Ida R, et al. The implementation of a surgical antibiotic prophylaxis program: the pivotal contribution of the hospital pharmacy. Am J Infect Control. Feb. 2002;30(1):49-56. [pmid: 11852418].
84 Gyssens IC, Geerligs IE, Dony JM, et al. Optimising antimicrobial drug use in surgery: an intervention study in a Dutch university hospital. J Antimicrob Chemother. Dec. 1996;38(6):1001-12. [pmid: 9023647].
85 Rao N, Schilling D, Rice J, et al. Prevention of postoperative mediastinitis: a clinical process improvement model. J Healthc Qual. Jan–Feb. 2004;26(1):22-7. quiz 8. [pmid: 14763317].
86 van Kasteren ME, Mannien J, Kullberg BJ, et al. Quality improvement of surgical prophylaxis in Dutch hospitals: evaluation of a multi-site intervention by time series analysis. J Antimicrob Chemother. Dec. 2005;56(6):1094-102. [pmid: 16234334].
87 Won S, Chou H, Hsieh W, et al. Handwashing program for the prevention of nosocomial infections in a neonatal intensive care unit. Infection Control and Hospital Epidemiology. 2004;25(9):742. [pmid: 15484798].
88 Coopersmith CM, Rebmann TL, Zack JE, et al. Effect of an education program on decreasing catheter-related bloodstream infections in the surgical intensive care unit. Critical Care Medicine. 2002;30(1):59. [pmid: 11902288].
89 Coopersmith CM, Zack JE, Ward MR, et al. The impact of bedside behavior on catheter-related bacteremia in the intensive care unit. Arch Surg. Feb. 2004;139(2):131-6. [pmid: 14769568].
90 Penne K. Using evidence in central catheter care. Seminars in Oncology Nursing. 2002;18(1):66. [pmid: 11878042].
91 Sherertz RJ, Ely EW, Westbrook DM, et al. Education of physicians-in-training can decrease the risk for vascular catheter infection. Ann Intern Med. Apr 18. 2000;132(8):641-8. [pmid: 10766683].
92 Warren DK, Zack JE, Cox MJ, et al. An educational intervention to prevent catheter-associated bloodstream infections in a nonteaching, community medical center. Crit Care Med. Jul. 2003;31(7):1959-63. [pmid: 12847389].
93 Warren DK, Zack JE, Mayfield JL, et al. The effect of an education program on the incidence of central venous catheter-associated bloodstream infection in a medical ICU. Chest. Nov. 2004;126(5):1612-8. [pmid: 15539735].
94 Berenholtz SM, Pronovost PJ, Lipsett PA, et al. Eliminating catheter-related bloodstream infections in the intensive care unit. Crit Care Med. Oct. 2004;32(10):2014-20. [pmid: 15483409].
95 Wall RJ, Ely EW, Elasy TA, et al. Using real time process measurements to reduce catheter related bloodstream infections in the intensive care unit. Qual Saf Health Care. Aug. 2005;14(4):295-302. [pmid: 16076796]. [pmcid: 1744064].
96 Pronovost P, et al. A Multi-Faceted Intervention to Reduce Catheter-Related Blood Stream Infections in Michigan Intensive Care Units. [Unpublished manuscript].
97 Frankel HL, Crede WB, Topal JE, et al. Use of corporate Six Sigma performance-improvement strategies to reduce incidence of catheter-related bloodstream infections in a surgical ICU. J Am Coll Surg. Sep. 2005;201(3):349-58. [pmid: 16125067].
98 Bijma R, Girbes AR, Kleijer DJ, et al. Preventing central venous catheter-related infection in a surgical intensive-care unit. Infect Control Hosp Epidemiol. Sep. 1999;20(9):618-20. [pmid: 10501261].
99 Eggimann P, Harbarth S, Constantin MN, et al. Impact of a prevention strategy targeted at vascular-access care on incidence of infections acquired in intensive care. Lancet. May 27. 2000;355(9218):1864-8. [pmid: 10866442].
100 Higuera F, Rosenthal VD, Duarte P, et al. The effect of process control on the incidence of central venous catheter-associated bloodstream infections and mortality in intensive care units in Mexico. Crit Care Med. Sep. 2005;33(9):2022-7. [pmid: 16148475].
101 Lobo RD, Levin AS, Gomes LM, et al. Impact of an educational program and policy changes on decreasing catheter-associated bloodstream infections in a medical intensive care unit in Brazil. Am J Infect Control. Mar. 2005;33(2):83-7. [pmid: 15761407].
102 Rosenthal VD, Guzman S, Pezzotto SM, et al. Effect of an infection control program using education and performance feedback on rates of intravascular device-associated bloodstream infections in intensive care units in Argentina. Am J Infect Control. Nov. 2003;31(7):405-9. [pmid: 14639436].
103 Yoo S, Ha M, Choi D, et al. Effectiveness of surveillance of central catheter-related bloodstream infection in an ICU in Korea. Infect Control Hosp Epidemiol. Jul. 2001;22(7):433-6. [pmid: 11583212].
104 Puntis JW, Holden CE, Smallman S, et al. Staff training: a key factor in reducing intravascular catheter sepsis. Arch Dis Child. Mar. 1991;66(3):335-7. [pmid: 1902650]. [pmcid: 1792884].
105 Earsing KA, Hobson DB, White KM. Best-practice protocols: preventing central line infection. Nurs Manage. Oct. 2005;36(10):18-24. [pmid: 16210947].
106 Eggimann P, Hugonnet S, Sax H, et al. Long-term reduction of vascular access-associated bloodstream infection. Ann Intern Med. May 17. 2005;142(10):875-6. [pmid: 15897546].
107 Babcock HM, Zack JE, Garrison T, et al. An educational intervention to reduce ventilator-associated pneumonia in an integrated health system: a comparison of effects. Chest. Jun. 2004;125(6):2224-31. [pmid: 15189945].
108 Joiner GA, Salisbury D, Bollin GE. Utilizing quality assurance as a tool for reducing the risk of nosocomial ventilator-associated pneumonia. Am J Med Qual. Summer. 1996;11(2):100-3. [pmid: 8704496].
109 Lai KK, Baker SP, Fontecchio SA. Impact of a program of intensive surveillance and interventions targeting ventilated patients in the reduction of ventilator-associated pneumonia and its cost-effectiveness. Infect Control Hosp Epidemiol. Nov. 2003;24(11):859-63. [pmid: 14649776].
110 Zack JE, Garrison T, Trovillion E, et al. Effect of an education program aimed at reducing the occurrence of ventilator-associated pneumonia. Crit Care Med. Nov. 2002;30(11):2407-12. [pmid: 12441746].
111 Kelleghan SI, Salemi C, Padilla S, et al. An effective continuous quality improvement approach to the prevention of ventilator-associated pneumonia. Am J Infect Control. Dec. 1993;21(6):322-30. [pmid: 8122805].
112 Nicotra D, Ulrich C. Process improvement plan for the reduction of nosocomial pneumonia in patients on ventilators. J Nurs Care Qual. Jul. 1996;10(4):18-23. [pmid: 8783541].
113 Resar R, Pronovost P, Haraden C, et al. Using a bundle approach to improve ventilator care processes and reduce ventilator-associated pneumonia. Jt Comm J Qual Patient Saf. May. 2005;31(5):243-8. [pmid: 15960014].
114 Helman DL Jr, Sherner JH, 3rd, Fitzpatrick TM, et al. Effect of standardized orders and provider education on head-of-bed positioning in mechanically ventilated patients. Crit Care Med. Sep. 2003;31(9):2285-90. [pmid: 14501958].
115 Salahuddin N, Zafar A, Sukhyani L, et al. Reducing ventilator-associated pneumonia rates through a staff education programme. J Hosp Infect. Jul. 2004;57(3):223-7. [pmid: 15236851].
116 Rosenthal VD, Guzman S, Crnich C. Impact of an infection control program on rates of ventilator-associated pneumonia in intensive care units in 2 Argentinean hospitals. Am J Infect Control. Mar. 2006;34(2):58-63. [pmid: 16490607].
117 Ching TY, Seto WH. Evaluating the efficacy of the infection control liaison nurse in the hospital. Journal of Advanced Nursing. 1990;15(10):1128. [pmid: 2258518].
118 Danchaivijitr S, Chokloikaew S, Tangtrakool T, et al. Does indication sheet reduce unnecessary urethral catheterization?. Journal of the Medical Association of Thailand. 1992;75(Suppl 2):1. [pmid: 1402492].
119 Huang W, Wann S, Lin S, et al. Catheter-associated urinary tract infections in intensive care units can be reduced by prompting physicians to remove unnecessary catheters. Infection Control and Hospital Epidemiology. 2004;25(11):974. [pmid: 15566033].
120 Rosenthal VD, Guzman S, Safdar N. Effect of education and performance feedback on rates of catheter-associated urinary tract infection in intensive care units in Argentina. Infect Control Hosp Epidemiol. Jan. 2004;25(1):47-50. [pmid: 14756219].
121 Dumigan DG, Kohan CA, Reed CR, et al. Utilizing national nosocomial infection surveillance system data to improve urinary tract infection rates in three intensive-care units. Clin Perform Qual Health Care. Oct–Dec. 1998;6(4):172-8. [pmid: 10351284].
122 Topal J, Conklin S, Camp K, et al. Prevention of nosocomial catheter-associated urinary tract infections through computerized feedback to physicians and a nurse-directed protocol. Am J Med Qual. May–Jun. 2005;20(3):121-6. [pmid: 15951517].
123 Cornia PB, Amory JK, Fraser S, et al. Computer-based order entry decreases duration of indwelling urinary catheterization in hospitalized patients. Am J Med. Apr 1. 2003;114(5):404-7. [pmid: 12714131].
124 Saint S, Kaufman SR, Thompson M, et al. A reminder reduces urinary catheterization in hospitalized patients. Jt Comm J Qual Patient Saf. Aug. 2005;31(8):455-62. [pmid: 16156193].
125 van Nieuwenhoven CA, Vandenbroucke-Grauls C, van Tiel FH, et al. Feasibility and effects of the semirecumbent position to prevent ventilator-associated pneumonia: a randomized study. Crit Care Med. Feb. 2006;34(2):396-402. [pmid: 16424720].
126 Grimshaw JM, Shirran L, Thomas R, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. Aug. 2001;39(8 Suppl 2):II2-45. [pmid: 11583120].
127 Scheckler WE, Brimhall D, Buck AS, et al. Requirements for infrastructure and essential activities of infection control and epidemiology in hospitals: A consensus panel report. Society for Healthcare Epidemiology of America. Am J Infect Control. Feb. 1998;26(1):47-60. [pmid: 9503113].
128 Edmond MB, White-Russell MB, Ober J, et al. A statewide survey of nosocomial infection surveillance in acute care hospitals. Am J Infect Control. Oct. 2005;33(8):480-2. [pmid: 16216664].
129 Klevens RM, Tokars JI, Edwards J, et al. Sampling for collection of central line-day denominators in surveillance of healthcare-associated bloodstream infections. Infect Control Hosp Epidemiol. Apr. 2006;27(4):338-42. [pmid: 16622809].
130 Ely EW, Meade MO, Haponik EF, et al. Mechanical ventilator weaning protocols driven by nonphysician health-care professionals: evidence-based clinical practice guidelines. Chest. Dec. 2001;120(6 Suppl):454S-63S. [pmid: 11742965].
131 Gastmeier P, Geffers C, Brandt C, et al. Effectiveness of a nationwide nosocomial infection surveillance system for reducing nosocomial infections. J Hosp Infect. Sep. 2006;64(1):16-22. [pmid: 16820247].