# Executive Summary

## Overview

Healthcare-associated infections (HAIs) are considered to be the greatest risk posed to hospitalized patients; up to two million patients experience a healthcare-associated infection every year in the U.S., leading to approximately 88,000 deaths per year. Active efforts to curb HAIs have increased in recent years, thanks to the growing emphasis on patient safety and quality; these efforts include public reporting of infection rates in some states, and widely publicized campaigns to promote adherence to HAI preventive interventions (such as the Institute for Healthcare Improvement's “100,000 Lives” campaign).

Within the hospital, surgical site infections (SSI) and three types of infections common in intensive care unit (ICU) patients are particularly prevalent—central-line associated bloodstream infections (CLABSI), ventilator-associated pneumonia (VAP), and catheter-associated urinary tract infections (CAUTI). Together, these infections account for more than 80 percent of all HAIs. In this report, we systematically review the evidence supporting quality improvement strategies to reduce the incidence of these key healthcare-associated infections. We intend to identify strategies that successfully increase adherence to effective preventive practices for each of these infections and reduce infection rates. Our specific research questions are:

1 Do quality improvement strategies increase adherence to evidence-based preventive interventions for healthcare-associated infections?
2 What are the critical components of effective QI strategies?
3 What are the limitations of current research in this field, and what areas require further study?

We defined a “preventive intervention” as a specific infection control practice that has been demonstrated to reduce the incidence of a HAI. To identify target preventive interventions, we reviewed the CDC guidelines for prevention of surgical site infection, prevention of intravascular catheter-related infections, prevention of healthcare-associated pneumonia, and prevention of catheter-associated urinary tract infection. Hand hygiene was identified as an important preventive intervention for all HAIs. The disease-specific target preventive interventions we identified are as follows:

- Surgical site infection: appropriate perioperative antibiotic prophylaxis (including appropriate antibiotic selection, timing, and duration), perioperative glucose control, and decreasing shaving of the operative site.
- Central line-associated bloodstream infection: adherence to maximal sterile barrier precautions, use of chlorhexidine for skin antisepsis, and avoidance of femoral catheterization.
- Ventilator-associated pneumonia: semirecumbent patient positioning and daily assessment of readiness for ventilator weaning.
- Catheter-associated urinary tract infection: reduction in unnecessary catheter use and adherence to aseptic catheter insertion and catheter care

As in previous reviews in this series, we performed a rigorous search of the published literature using the MEDLINE^®^ database, supplemented by targeted searches of the Cochrane Collaboration Effective Practice and Organisation of Care (EPOC) database. We included studies with contemporaneous control groups (randomized controlled trials and controlled before-after studies) and quasi-experimental studies without a contemporaneous control group (interrupted time series and simple before-after studies). We classified QI interventions according to a modification of a taxonomy used in previous volumes of this series. The QI strategies were classified as follows:

1 Clinician education
2 Patient education
3 Audit and feedback
4 Clinician reminder systems
5 Organizational change
6 Financial or regulatory incentives for patients or clinicians

We included studies that used one or more of the above QI strategies to implement or increase use of any of the target preventive interventions. Included studies were required to report data on the rate of adherence to recommended preventive interventions and/or the rate of healthcare-associated infection. Trials that reported related outcomes, such as costs, health services utilization (e.g., length of stay), patient or provider satisfaction with care, or adverse events associated with the intervention, were included only if they included data on infection rates or adherence measures.

We assessed study quality based on prespecified criteria for assessing study internal and external validity. These criteria were not used to determine study inclusion or exclusion. For simple before-after studies, we applied the following criteria:

1 Was the intervention performed independent of other QI efforts or other changes?
2 Did the study report data at more than one time point before and after the intervention?
3 If the study reported infection rates, were process measurements also reported?
4 If the study reported infection rates, did the study use CDC/NNIS methodology for measuring infections?
5 (For CLABSI, VAP, and CAUTI) If the study reported infection rates, were reported rates adjusted for device utilization?
6 (For SSI) If the study reported infection rates, was surveillance for infections performed after hospital discharge?

Studies reporting process measures (rate of adherence to target preventive interventions) were considered to have greater external validity, as these measures are universally applicable. For controlled studies, we also applied the following study quality criteria, as used in previous volumes of this series:

1 Were study subjects randomized, and if so, was the randomization process described?
2 For non-randomized studies, was the rationale for selection of the comparison group explained, and a baseline observation period included (to assess selection bias)?
3 Were the outcome assessors blinded to treatment group assignment?
4 Was a unit-of-analysis error present? If so, were appropriate statistical methods used for correction?

We did not perform quantitative analysis, instead using our study quality criteria as a framework to identify studies of relatively stronger internal and external validity.

## Result

Our search strategy identified a total of 4,847 citations, and one additional unpublished citation was identified from our peer review panel. Of these, 434 underwent full-text review, and 64 articles met all criteria for inclusion. In general, baseline rates of HAIs were higher than rates reported by the Centers for Disease Control and Prevention's National Nosocomial Infection Surveillance System (NNIS).

### Surgical Site Infections

Twenty-eight studies met all inclusion criteria and addressed prevention of surgical site infections. Most (19) of the studies were performed outside of the United States. Several QI strategies were used: 23 studies used clinician education, 15 used audit and feedback, 15 used organizational change strategies such as creation of multidisciplinary teams or adding additional staff, and five used clinician reminder systems. The methodological quality of studies was generally poor; 22 of 28 used a quasi-experimental simple before-after (SBA) design. Even within the limits of the study design, most SBA studies had poor internal and external validity, as most reported data on only one time point before and after the intervention, and most did not perform post-discharge surveillance. Ten studies used surgical site infection rate as the primary outcome, eight used process measures as primary outcomes, and eight both infection rates and process measures. The majority of studies (16 of 28) reported data on adherence to appropriate antibiotic prophylaxis protocols. Limited data indicate that educational interventions coupled with audit and feedback may be effective at improving adherence to appropriate antibiotic prophylaxis. Clinician reminders may also improve perioperative antibiotic prophylaxis, especially when incorporated into a CPOE system. No conclusion can be reached regarding the effectiveness of QI strategies at promoting perioperative glucose control, perioperative normothermia, or decreasing operative site shaving. We were unable to determine any strategies effective at reducing SSI rates. In studies that did not have important methodologic flaws, surgical site infection rates were not consistently reduced, even when process measurements were improved.

### Central Line-Associated Bloodstream Infections

Our literature search identified 19 studies that met our inclusion criteria that specifically addressed prevention of central line-associated blood stream infection (CLABSI). Ten were from centers within the United States. All but one of the studies was from a single center. All of the studies reported rates of CLABSI; nine of the studies also reported data on adherence measures. All studies but one targeted hand hygiene; five studies targeted hand hygiene alone, four targeted hand hygiene and maximal sterile barrier precautions, and seven studies targeted hand hygiene, maximal sterile barrier precautions, and at least one other preventive strategy. All but one of the studies employed educational strategies for health care providers as part of their intervention, targeting nurses and physicians. The majority of educational interventions were active in nature. Eight studies employed audit and feedback, five employed strategies that included organizational change, and four used clinician reminders. The majority of studies used a multifaceted approach, incorporating more than one QI strategy. The methodological quality of studies was also poor, as all but two used an SBA design, and the majority of these reported data at one time point before and after the intervention and failed to report both infection rates and adherence measures. Seven studies (including two controlled studies) used active educational interventions, including demonstrations and self-study tutorials to improve adherence to preventive practices during catheter insertion and reduce CLABSI rates. Two of these studies used an explicit checklist during central line insertion, with nurses empowered to stop the procedure if all preventive interventions were not used, and documented marked reductions in CLABSI rates. These educational interventions have been evaluated in teaching and non-teaching hospitals, and in U.S. and European institutions, increasing their generalizability. We were unable to judge the effectiveness of any other QI strategies at either improving adherence or reducing CLABSI rates.

### Ventilator-Associated Pneumonia

We identified 12 articles meeting our inclusion criteria that assessed prevention of ventilator-associated pneumonia. Studies were mostly performed in the United States, primarily in a single institution. All but one included studies explicitly promoted hand hygiene, and eight promoted semirecumbent patient positioning; two studies promoted daily assessment of readiness to wean from the ventilator. Many other preventive interventions were used in the studies, including aseptic drainage of ventilator circuit condensate, appropriate suctioning technique, and provision of oral care. All studies primarily used educational interventions targeted at providers (physicians, nurses, and respiratory therapists.) Most of these combined use of written materials and lectures, with six studies implementing an explicit clinical guideline for preventive care. Three studies used audit and feedback of infection rates, and two used a continuous quality improvement intervention. The methodologic quality of studies was generally poor, as all used a SBA design, and (similar to CLABSI studies) most reported data at one time point before the intervention and did not report both adherence measures and infection rates. Two studies used an active educational intervention with use of a self-study module for ICU staff, and documented significant reductions in VAP rates; this appears to be a promising strategy for reducing VAP. These studies implemented explicit clinical guidelines for preventing VAP. No conclusion can be reached on the effectiveness of audit and feedback of VAP rates, or on the effectiveness of any other QI strategies.

### Catheter-Associated Urinary Tract Infection

Our search identified ten articles that addressed prevention of catheter-associated urinary tract infections, six of which were performed outside the United States. Of the included studies, six addressed reduction in placement of catheters or removal of unnecessary catheters once already placed, four addressed aseptic insertion and catheter care, and two hand hygiene. Six studies used a printed or computer-based reminder to attempt to reduce unnecessary catheter use. Six studies used provider education, two used audit and feedback, and two used an organizational change strategy whereby nurses were authorized to remove urethral catheters without a physician order. Seven studies measured CAUTI rate (symptomatic CAUTI or asymptomatic bacteriuria). Four studies measured catheter usage, reported as the percentage of inpatients catheterized or the average duration of catheterization. We identified three controlled before-after studies and seven simple before-after studies. The CBA studies were generally of fair methodologic quality, and the SBA studies were generally of relatively poor quality, with similar problems with internal and external validity as for the other HAIs. Within these limitations, reminders to clinicians appear to be effective at reducing unnecessary catheter usage, primarily by reducing the duration of catheterization. Three of these studies incorporated an “automatic stop order” mandating removal of the catheter after 48 to 72 hours unless countermanded by the physician, and all documented a reduction in catheter use and CAUTI rate. We were unable to assess the effectiveness of any other QI strategies.

Across all four target HAIs, the quality of the included studies was generally poor, as 52 of 64 included studies used a SBA design. Even within the limitations of this study design, most studies had poor internal validity, chiefly due to reporting data at only one time point before and after the intervention. Generalizability was also poor, as the baseline level of HAI rates were well above the pooled NNIS mean for CLABSI, VAP, and CAUTI. The relatively high baseline rates raise the concern that the observed improvement could be due to regression to the mean (especially in SBA studies). Most studies also reported infection rates without reporting accompanying adherence measures. Publication bias is likely, as most (30 of 39) of the studies reporting adherence to preventive interventions reported a statistically significant improvement in adherence. Other methodologic problems in the included studies are similar to those identified in previous volumes in this series, such as inadequate reporting of intervention details and failure to report the reach of an intervention. No studies performed a formal cost-benefit analysis, and few studies reported on any potential adverse effects of the intervention. We were unable to perform any quantitative analyses.

## Conclusions

We are unable to make firm recommendations for organizations seeking to implement quality improvement interventions to reduce healthcare-associated infections. Based on the limited data available, we reach the following conclusions:

1 Preliminary data indicates that several strategies are worthy of future study, and possibly wider implementation.
  There is insufficient data to support universal implementation of these strategies, but they may be suitable for implementation if an appropriate plan is in place to monitor their effectiveness and potential adverse effects:
  - Printed or computer-based reminders with use of automatic stop orders to reduce unnecessary urethral catheterization (the only strategy supported by multiple controlled trials);
  - Printed or computer-based reminders for improving adherence to recommendations for timing and duration of surgical antibiotic prophylaxis;
  - Staff education, including use of interactive tutorials (including video and web-based) and checklists, to improve adherence to insertion practices for placement of central venous catheters;
  - Staff education, including use of interactive tutorials, to improve adherence to preventive interventions to prevent ventilator-associated pneumonia.
2 Higher quality studies of QI strategies to implement preventive interventions are urgently needed.
  Investigators should attempt to perform controlled trials of QI strategies when possible, and should report both adherence measures and infection rates. If performing a controlled trial is impractical, investigators should perform interrupted time series studies, involving reporting data for at least 3 time points before and after the intervention and formal time series statistical analysis. Given the burden of disease caused by healthcare-associated infections, prioritizing study of methods to implement effective preventive interventions should greatly benefit hospitalized patients.