# Acknowledgments

We thank Jessie McGowan and the Cochrane Effective Practice and Organisation of Care (EPOC) group for their help with the literature searches, Peter Pronovost, M.D., Ph.D. for providing a draft copy of an unpublished study, and Paul Cornia, MD for providing additional data from one study. We also acknowledge with much gratitude our expert advisors and peer reviewers who are listed in Appendix D *.

Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/hainfgaptp.htm