# Results

Our search strategy identified a total of 4,847 citations, and one additional unpublished citation was identified from our peer review panel (Figure 1). Of these, 434 underwent full-text review, and 64 articles met all criteria for inclusion. Of these, three reported data on more than one target HAI. ^60^ – ^62^ All included studies utilized a single intervention arm. The results are summarized according to each target HAI below. Appendix C * lists the excluded studies and the reason for exclusion.

Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/hainfgaptp.htm

Figure 1. Search results and article triage

## Surgical Site Infections

### Included Studies: Settings, Goals, and Target Populations

Our search strategy identified 28 articles that met our inclusion criteria and addressed prevention of surgical site infections (Tables 4a–4h). One of these ^60^ reported data on SSI, but its intervention primarily targeted VAP; thus, it will be discussed in the VAP section. Most (15) studies were conducted in single tertiary care hospitals, but seven were completed in multiple hospitals, ^19, ^ ^61, ^ ^63^ – ^67^ and one at a community hospital; ^68^ the hospital type was unclear in five studies. ^69^ – ^73^

Table 4a Articles addressing prevention of surgical site infections (studies addressing use of appropriate antibiotic prophylaxis): controlled studies

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Landgren 1988 ^63^ | Australia | 1985-1986 | 2 years | Appropriate use of perioperative antibiotics | QI strategies: Clinician education, audit and feedback, clinician reminder | Adherence to appropriate timing of perioperative antibiotics:
| Multiple hospitals of different types | | | | Counter-detailing program designed to counter efforts of pharmaceutical representatives and align behavior more closely with antibiotic guidelines booklet, widespread in Victoria, Australia | Net effect size (change in intervention - change in control) = 20%; p=0.04
| | | | | 1) All surgeons, anesthetists, and residents received pen, notepads similar to that of drug companies, each carrying rational prescribing message.; 2) 2 posters focused on proper antibiotic use, and 1 offering positive reinforcement.; 3) Audit of results; 4) lecture organized for surgical staff, discussing results of audit.; 5) 10 minute satirical videotape was produced specifically for staff, mocking drug reps, surgeons, RNs, microbiologists: aimed to stimulate discussion.; 6) Academic representative met with select number of surgeons, especially those unable to attend. | Adherence to administering perioperative antibiotics for the appropriate duration:
| | | | | | Net effect size (change in intervention - change in control) = 14%; p=NS
Ritchie 2004 ^64^ | United States | 9/1999 | 1 month | Appropriate use of perioperative antibiotics | QI strategies: Clinician education, clinician reminder | Adherence to appropriate timing of perioperative antibiotics:
| Multiple hospitals of different types | | | | Investigators used a retrospective audit to characterize use of antibiotics in pre-intervention period. | Net change in adherence (change in intervention group - change in control group): 15%
| | | | | After a consensus building session with orthopedic surgeons, anesthetists and investigators, all agreed that they would use preprinted sticker placed to remind anesthesiologist and surgeon to use cefazolin at induction, and for no more than 2 doses after surgery. | p value not supplied
| | | | | | Adherence to administering perioperative antibiotics for the appropriate duration:
| | | | | | Net change in adherence (change in intervention group - change in control group): 56%
| | | | | | p value not supplied
Zanetti 2003 ^79^ | United States | Not specified | 1 month | Appropriate use of perioperative antibiotics | QI strategies: Clinician reminder | Infection rates:
| Tertiary care or university hospital | | | | Computer-generated automatic alert for redosing prophylactic antibiotics in prolonged cardiac surgery. | Net change in infection rate (change in intervention group - change in control group) = 2.0%; p=NS
| | | | | | Appropriate redosing of antibiotics:
| | | | | | Net change in frequency of appropriate redosing (change in intervention group - change in control group) = 28%; p<0.01

Table 4h Articles addressing prevention of surgical site infections (studies not using appropriate antibiotic prophylaxis as an outcome): simple before-after studies of poor methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Atukorala 1998 ^81^ | Sri Lanka | 1 month | Not specified | Hand hygiene | QI Strategies: Clinician education, organizational change | Infection rate before intervention: 4.44% of patients
| Tertiary care or university hospital | | | | The strategy consisted of a broad-based increase in infection control measures. | Infection rate after intervention: 2.72% of patients
| | | | | The number of infection control nurses was increased and all health care workers underwent educational programs on infection control, which stressed hand washing as a priority. A liaison nurse was identified on each ward to assist the infection control nurse. A policy of replacing IV catheters every 3 to 4 days was instituted and guidelines for urinary catheter changes were instituted. Proper disposal of clinical waste was initiated. | p<0.01
Cavalcante 1991 ^68^ | Brazil | 1986-1989 | 4 years | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education | Infection rate prior to intervention: 24.4% of patients
| Community hospital with residents | | | | “The most important measures recommended by the infection control committee to decrease the infection rates were antibiotic policies, isolation precautions, education programs, a change to reusable instead of disposable material, no routine change of ventilators, no local and systemic antibiotic prophylaxis, and device procedure policy”. | Infection rate after intervention: 3.4% of patients
| | | | | Education involved 19 basic courses in infection control and informal in-services. | p value not reported
McConkey 1999 ^82^ | United States | 4/1991–12/1994 | 3 years | Appropriate use of perioperative antibiotics | QI Strategies: Audit and feedback, clinician reminder | Infection rate prior to intervention: 12.4% of cases
| Tertiary care or university hospital | | | Decreasing use of preoperative shaving of the operative site | Prospective effort to reduce SSI using comprehensive infection control program. | Infection rate after intervention: 8.2% of cases
| | | | Audit and feedback of infection rates to hospitals or individual clinicians | The following interventions were instituted: | p<0.01
| | | | | 1) prospective surveillance;; 2) quarterly reporting of surgeon and assistant specific SSI rates;; 3) chlorhexidine shower by pt preoperative;; 4) Hair removal by clipping on morning of surgery;; 5) antibiotic prophylaxis 1/2 to 2 hours prior to incision;; 6) elimination of open ice baths for cooling of cardioplegia solution;; 7) limitation of OR traffic;; 8) minimization of intraoperative flash sterilization;; 9) elimination of tap-water wound bathing within 96 hours post-op;; 10) sterile wound dressing for first 96 hours post-op;; 11) use of dedicated infection control practitioner.
Schelenz 2005 ^72^ | UK | 9/2000 – 12/2001 | 16 months | Hand hygiene | QI Strategies: Clinician education, audit and feedback, clinician reminder | Infection rate prior to intervention: 4.1% of cases
| Hospital type not specified | | | Appropriate use of perioperative antibiotics | Investigators implemented a bundle of different interventions aimed at decreasing MRSA wound infections, using education, audit and feedback, improvements in surgical skin preparation, improved antibiotic prophylaxis and several measures to limit the spread of MRSA. | Infection rate after intervention: 2.1% of cases
| | | | Decreasing use of preoperative shaving of the operative site | | p=NS
| | | | Audit and feedback of infection rates to hospitals or individual clinicians
Haycock 2005 ^69^ | United States | 4 months | 1 year | Hand hygiene | QI Strategies: Clinician education, audit and feedback, clinician reminder | Infection rate prior to intervention: 1.5% of cases
| Hospital type not specified | | | Appropriate use of perioperative antibiotics | Identified best practices for preventive practices and gaps in current practice. | Infection rate after intervention: 0.3%
| | | | Decreasing use of preoperative shaving of the operative site | Formed process teams and implemented pilot protocol. Then implemented change and modified strategy based on results. Intervention targeted antibiotic prophylaxis, skin preparation, hand hygiene, blood glucose control, and wound case management for cardiac surgery patients. | p<0.05
| | | | Perioperative normothermia | | Adherence to protocols for hand hygiene:
| | | | Audit and feedback of infection rates to hospitals or individual clinicians | | Percentage change in compliance rate (post % - pre %): 11%
| | | | | | Adherence to administering perioperative antibiotics for the appropriate timing:
| | | | | | before intervention: NR
| | | | | | after intervention: 87%
| | | | | | Adherence to appropriate selection of perioperative antibiotics:
| | | | | | before intervention: NR
| | | | | | after intervention: 98%
| | | | | | Adherence to protocols for perioperative shaving of the surgical site:
| | | | | | before intervention: NR
| | | | | | after intervention: 100%
Reilly 2001 ^71^ | UK | Not specified | 28 months | Audit and feedback of infection rates to hospitals or individual clinicians | QI Strategies: Audit and feedback, clinician reminder | Infection rate prior to intervention: 13.9% of cases
| Not specified | | | | Surveillance including individual risk assessment for wound infection, daily visits perioperatively, final assessment 4 weeks post-op. Results collected and reported to participating physicians. | Infection rate after intervention: 7.9% of cases
| | | | | | p<0.05
*Berg 1995 ^60^ | Guatemala | Not specified | 1 year | Hand hygiene | QI Strategies: Clinician education | Infection rate before intervention: 4% of patients
| Tertiary care or university hospital | | | | A multifaceted intervention was used to target nosocomial infections in the ICU, with both general measures and measures targeting VAP and CAUTI. | Infection rate after intervention: 5% of patients
| | | | | Nurses and physicians received 15 educational sessions on aseptic technique, stressing proper hand washing. The educational sessions used lectures and demonstrations, and individual clinicians also received positive and negative feedback and reminder signs at the bedside. The VAP intervention targeted proper use of sterile rinse water and improvement in aseptic technique for suctioning. Providers received more than 15 interactive conferences on the detection, management, and prevention of nosocomial pneumonia; these included lectures, demonstrations, individual instruction and feedback, and contests. The CAUTI intervention consisted of changing open urinary drainage systems to closed systems (aseptic catheter care), with an educational session on the new catheter. The intervention did not specifically target CLABSI, but those outcomes are reported. | p=Non-significant (NS)
| | | | | | (Note: denominator for above is all patients in ICU; number of surgical cases was not provided.)

* This study addresses prevention of surgical site infections, central line-associated bloodstream infections, ventilator-associated pneumonia and catheter-associated urinary tract infections.

Many studies took place in a defined location in the hospital, with nine occurring the operating room, ^64, ^ ^73^ – ^80^ six in the intensive care unit, ^60, ^ ^61, ^ ^66, ^ ^72, ^ ^81, ^ ^82^ and two on the general inpatient ward. ^83, ^ ^84^ The remainder took place in multiple areas of the hospital. Ten of the studies took place in the past decade ^19, ^ ^64, ^ ^67, ^ ^71^ – ^74, ^ ^83, ^ ^85, ^ ^86^ but the remainder took place before then or did not have a stated time period. Among those reporting follow-up periods, the range was one month to four years, with a median of one year.

### Baseline Infection Rates in U.S. and Non-U.S. Studies

Most of the studies were performed outside of the United States, with 11 in Europe, Australia, and New Zealand, ^61, ^ ^63, ^ ^64, ^ ^66, ^ ^71^ – ^73, ^ ^75, ^ ^80, ^ ^84, ^ ^86^ nine in the United States, ^19, ^ ^69, ^ ^70, ^ ^76^ – ^79, ^ ^82, ^ ^85^ and eight in other countries. ^60, ^ ^65, ^ ^67, ^ ^68, ^ ^74, ^ ^81, ^ ^83, ^ ^87^ The NNIS 2004 report published mean surgical site infections rates for surgeries performed in the United States that ranged from 0.44 per 100 cases for low-risk cholecystectomy, 3.45/100 for all coronary artery bypass surgery patients, and 11.53/100 for high-risk colorectal surgery. ^14^ By comparison, among our included studies, the sixteen studies that used surgical site infection rates as an outcome reported a median of 5.4 per 100 cases and a range of 1.1–24.4 per 100 cases. This range represents the wide range of geographic areas, time periods, and types of surgeries among included studies.

Baseline surgical site infection rates in the United States-based studies were 4–12.4 percent in four studies involving QI in cardiac surgery patients ^70, ^ ^79, ^ ^82, ^ ^85^ and 2.3 percent in a large multicenter trial. ^19^ In studies from Europe, New Zealand and Australia, the baseline infection rates ranged from 5.4 to 13.9 percent in studies with multiple types of surgeries ^61, ^ ^71, ^ ^86^ and 4.1 percent in one study of cardiac surgery patients. ^72^ A German study reported a surgical site infection rate of 48/1,000 patient-days that cannot be directly compared to the NNIS report. ^66^ Studies conducted in other countries (including Israel, Brazil, and Guatemala) reported baseline surgical site infection rates of 13.5 percent, ^81^ 24.4 percent, ^68^ 5 percent, ^60^ 4.2 percent, ^74^ and 0.33/1,000 patient days. ^87^ Overall, studies conducted in Europe, Australia, and New Zealand had similar infection rates as those of United States studies, although these rates were higher than those reported in the NNIS 2004 report. Studies conducted in all other countries showed much higher infection rates than in comparable United States studies, which decreased their translatability to United States QI efforts.

### Preventive Interventions and Outcomes Measured

We identified several preventive interventions for review: appropriate provision of perioperative antibiotics (including appropriate timing, selection and duration of antibiotics), hand hygiene, perioperative glycemic control, and avoidance of preoperative shaving. Eleven studies targeted more than one process measure, including at least one of the above. ^19, ^ ^61, ^ ^63, ^ ^66, ^ ^68, ^ ^69, ^ ^72^ – ^75, ^ ^82^ Promotion of the appropriate use of perioperative antibiotics was used in 23 of the 28 studies; ^19, ^ ^61, ^ ^63^ – ^69, ^ ^72^ – ^80, ^ ^82^ – ^86^ in ten of these, other preventive interventions were advocated as well. ^19, ^ ^61, ^ ^63, ^ ^66, ^ ^68, ^ ^69, ^ ^72^ – ^75^ Sixteen of the 23 studies targeting perioperative antibiotics reported data on appropriate antibiotic use before and after the intervention; the other seven studies reported only SSI rates. Hand hygiene promotion was used in seven of the studies, ^60, ^ ^66, ^ ^69, ^ ^72, ^ ^74, ^ ^81, ^ ^87^ often as part a comprehensive infection control program. ^66, ^ ^69, ^ ^72, ^ ^74^ Four studies targeted improved perioperative glycemic control ^19, ^ ^66, ^ ^74, ^ ^85^ and eight studies promoted avoidance of shaving at the operative site ^19, ^ ^61, ^ ^66, ^ ^69, ^ ^72, ^ ^74, ^ ^82, ^ ^85^ as part of a comprehensive infection control program, but no studies used either intervention alone. Overall, both U.S. and non-U.S. studies used similar preventive interventions.

Ten studies used surgical site infection rate as the primary outcome, ^61, ^ ^66, ^ ^68, ^ ^70^ – ^72, ^ ^74, ^ ^79, ^ ^81, ^ ^82^ eight used process measures as primary outcomes, ^63^ – ^65, ^ ^73, ^ ^77, ^ ^78, ^ ^80, ^ ^84^ and eight used surgical site infection rate and at least one included process measure as a primary or secondary outcome. ^19, ^ ^60, ^ ^67, ^ ^69, ^ ^76, ^ ^85^ – ^87^ We did not attempt quantitative synthesis of the results because of the heterogeneity of outcomes, preventive methods, and baseline surgical site infection rates.

### Quality Improvement Strategies

Included studies directed audit and feedback methods, educational interventions or clinical reminders at providers (Tables 4a–4h). Physicians were specifically targeted in ten studies, ^63^ – ^65, ^ ^71, ^ ^73, ^ ^75^ – ^78, ^ ^80^ nurses in one, ^69^ and both physicians and nurses in seven studies; ^60, ^ ^61, ^ ^66, ^ ^68, ^ ^79, ^ ^84, ^ ^86^ the remainder targeted all clinical staff. ^67, ^ ^70, ^ ^72, ^ ^74, ^ ^81^ – ^83, ^ ^85, ^ ^87^ Clinical reminder systems were explicitly used in five studies targeting appropriate antibiotic use; two used a computerized physician order entry (CPOE) system, ^78, ^ ^79^ and three others used a preprinted reminder sticker or forms. ^64, ^ ^76, ^ ^83^ Every study that did not use a clinical reminder system used some type of educational program. Seven studies employed consensus-building sessions, ^19, ^ ^60, ^ ^64, ^ ^65, ^ ^70, ^ ^75, ^ ^83^ and the remaining studies distributed information using lectures or written materials. One study used academic counterdetailing. ^63^ Fourteen studies explicitly used audit and feedback ^19, ^ ^61, ^ ^66, ^ ^69^ – ^73, ^ ^75, ^ ^82^ – ^84, ^ ^86, ^ ^87^ as a means of directly decreasing infection rates or of promoting specific interventions (see above). Fifteen used organizational change strategies such as creation of multidisciplinary teams or adding additional staff to existing teams to monitor and promote changes in infection control practices, along with either audit and feedback or consensus building sessions. ^19, ^ ^61, ^ ^63, ^ ^67, ^ ^69, ^ ^71, ^ ^72, ^ ^77, ^ ^80^ – ^86^

### Methodological Quality of Included Studies

The methodological quality of studies was generally poor because 22 of 28 used a quasi-experimental simple before-after design (Tables 4a–4h). We identified two interrupted time series, ^67, ^ ^86^ three controlled before-after studies, ^63, ^ ^64, ^ ^66^ and one randomized control trial (RCT) (Tables 4a, 4b, 4f). ^79^ Most of the simple before-after studies had limited internal validity (Table 5). Five simple before-after studies reported data on more than one time point before and after the intervention; ^60, ^ ^61, ^ ^69, ^ ^74, ^ ^85^ most (14/23) reported at least one process measurement. ^19, ^ ^60, ^ ^65, ^ ^69, ^ ^73, ^ ^75^ – ^78, ^ ^80, ^ ^83^ – ^85, ^ ^87^ No study clearly stated that the intervention was conducted independent of any other quality improvement effort. Three simple before-after studies met two criteria for internal validity. ^60, ^ ^69, ^ ^85^ Despite difficulties with internal validity, some studies exhibited good external validity as they used standard NNIS/CDC methods to track infections and performed post-discharge surveillance. ^74, ^ ^75, ^ ^82^ Among those studies reporting surgical site infection rates, most reported an overall infection rate, but two studies separately reported superficial incisional, deep incisional, and organ/space infection rates. ^61, ^ ^82^

Table 4b Articles addressing prevention of surgical site infections (studies addressing use of appropriate antibiotic prophylaxis): interrupted time series

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Weinberg, 2001 ^67^ | Colombia | 1996-1998 | Hospital A: 12 months | Appropriate use of perioperative antibiotics | QI strategies: Audit and feedback, organizational change | Infection rate prior to intervention: Hospital A, 10.5%; Hospital B, 6.1%
| Two academic maternity hospitals | | Hospital B: 21 months | Decreasing use of preoperative shaving of the operative site | A CQI intervention was performed targeting surgical site infections in women undergoing cesarean section at 2 hospitals in Bogota, Colombia. At both hospitals, multidisciplinary teams were formed consisting of an obstetrician, resident, nurse, pharmacist, and administrator. | Infection rate after intervention: Hospital A, 0%; Hospital B, 4.4%; p<0.001 for hospital A, p=0.042 for hospital B
| | | | | The teams reviewed the literature to identify risk factors for SSI. The teams underwent training in CQI methods by outside facilitators, then used PDSA methods to identify the problem and formulate an approach. SSI rates were fed back to administrators and (at one hospital) to individual physicians. | Compliance with appropriate timing of antibiotic prophylaxis:
| | | | | | Compliance before intervention: hospital A, 24%; hospital B, 70%
| | | | | | Compliance after intervention: hospital A, 96%; hospital B, 96%; p<0.001 for both
Van Kasteren 2005 ^86^ | Netherlands | 7/2001 – 10/2002 | 16 months | Appropriate use of perioperative antibiotics | QI strategies: Clinician education, audit and feedback, clinician reminder | Infection rate prior to intervention: 5.4%
| Tertiary care or university hospital | | | | Implementation of a national guideline for surgical antimicrobial prophylaxis at 13 Dutch hospitals. The guideline recommends single-dose prophylaxis with a cephalosporin (plus metronidazole if indicated) to be administered within 30 minutes before incision. Each hospital received feedback on their baseline compliance rate to the guideline. The study group formulated recommendations for improving adherence at each hospital, and discussed them with physicians and nurses. Additional educational meetings were held. | Infection rate after intervention: 4.5%; p=NS
| | | | | | Adherence to administering perioperative antibiotics for the appropriate duration:
| | | | | | before intervention: 44.2%
| | | | | | after intervention: 31.4%; p<0.01
| | | | | | Adherence to appropriate selection of antibiotics:
| | | | | | before intervention: 3.9%
| | | | | | after intervention: 63.5%; p<0.01
| | | | | | Adherence to appropriate timing of perioperative antibiotics:
| | | | | | before intervention: 49.5%
| | | | | | after intervention: 61.6%; p<0.01

Table 4f Articles addressing prevention of surgical site infections (studies not using appropriate antibiotic prophylaxis as an outcome): controlled studies

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Gastmeier 2002 ^66^ | Germany | 10 months | 2 years | Hand hygiene | QI strategies: Clinician education, audit and feedback | Infection rate prior to intervention:
| Multiple hospitals of different types | | | Appropriate use of perioperative antibiotics | Intervention hospitals introduced quality circles and surveillance activities. The quality circles consisted of at least 1 physician and 1 nurse from the surgical unit and ICU, and infection control personnel. | 2.6% of cases
| | | | Decreasing use of preoperative shaving of the operative site | The quality circles were structured groups that used continuous quality improvement (CQI) methodology to decide on a problem focus, reach a consensus on solving a given problem, and execute the solution. | Infection rate after intervention:
| | | | Improving perioperative glucose control | Each QC focused on hand hygiene, but otherwise each intervention hospital individualized their focus. Thus, each hospital focused on different aspects of SSI, CAUTI or CLABSI prevention; the specific preventive interventions targeted appear to vary between hospitals, but generally belonged to CDC category I. After a 10-month period in which the quality circles were set up, outcomes were measured, and subsequently ongoing surveillance was performed by infection control nurses according to NNIS protocols. Outcomes were measured again after another 10 months. | 2.0 % of cases
| | | | | | p=NS

Table 5 Quality criteria for simple before-after studies addressing surgical site infections

| Internal Validity | | | External Validity
Author | Did the study report data on more than one time point before and after the intervention? | If the study reported infection rates, did it also report process measurements? | Was the intervention performed independent of other QI efforts or other changes? | Did the study use NNIS/CDC methods for measuring infections? | Did the study perform surveillance for infections after hospital discharge?
Atukorala 1998 ^81^ | o | o | ▴ | ▴ | ▴
Berg 1995 ^60^ | • | • | ▴ | • | ▴
Borer 2004 ^74^ | • | o | ▴ | • | •
Brusaferro 1991 ^75^ | o | • | ▴ | • | •
Cavalcante 1991 ^68^ | o | o | o | o | ▴
Dellinger 2005 ^19^ | o | • | ▴ | ▴ | •
Greco 1991 ^61^ | • | o | o | ▴ | ▴
Gyssens 1996 ^84^ | o | Not applicable | ▴ | Not applicable | Not applicable
Gyssens 1996 ^80^ | o | • | ▴ | Not applicable | Not applicable
Haycock 2005 ^69^ | • | • | ▴ | o | ▴
Larsen 1989 ^76^ | o | • | o | ▴ | •
Lutarewych 2004 ^70^ | o | o | o | • | •
McConkey 1999 ^82^ | o | o | ▴ | • | •
Prado 2002 ^83^ | o | • | o | o | ▴
Rao 2004 ^85^ | • | • | ▴ | o | •
Reilly 2001 ^71^ | o | o | ▴ | o | •
Schelenz 2005 ^72^ | o | o | o | o | ▴
Shapiro 1981 ^65^ | o | Not applicable | o | Not applicable | Not applicable
Smith 1988 ^77^ | o | Not applicable | o | Not applicable | Not applicable
St Jacques 2005 ^78^ | o | Not applicable | ▴ | Not applicable | Not applicable
Talon 2001 ^73^ | o | Not applicable | ▴ | Not applicable | Not applicable
Won 2004 ^87^ | o | • | ▴ | • | Not specified

• Yes o No ▴ Unclear

Given the generally poor methodological quality of the results and the heterogeneity of the methods used, we will summarize the results according to their study design, internal and external validity, and give less detail on lower quality studies. We further divided the studies into the 16 studies that reported compliance with appropriate antibiotic prophylaxis as an outcome measure, ^19, ^ ^61, ^ ^63^ – ^65, ^ ^67, ^ ^73, ^ ^75^ – ^80, ^ ^83, ^ ^84, ^ ^86^ and those that reported other outcome measures, including the surgical site infection rate.

### Studies Addressing Use of Appropriate Antibiotic Prophylaxis

Controlled Trials. One controlled study was conducted in six pairs of matched hospitals (four teaching, two suburban, and six rural hospitals), and focused on improving appropriateness of perioperative antibiotic timing and duration (Table 4a). ^63^ The educational effort centered on academic counterdetailing, a process in which pharmaceutical marketing techniques are used to promote academic goals (suggest moving this definition up to where the term is first used). Investigators used promotional gifts, posters, lectures, videos, and targeted letters to inform the physician staff about appropriate perioperative antibiotic use. The study showed improvement in appropriate duration (absolute improvement of 20.0 percent, p=0.04) and in appropriate timing (absolute improvement of 13.0 percent, p=0.12). The study employed a crossover design, and similar results were seen in the second (crossover) phase of the study. This improvement reverted to baseline after the QI effort was stopped during the final phase of the study. The study's generalizability to current U.S. hospital practices is moderate despite the multicenter design because the study took place in Australia 20 years ago.

A second controlled study was also directed at providers: a preprinted sticker was placed to remind providers to limit the duration of prophylactic antibiotics (cefazolin) to three doses total (Table 4a). ^64^ The policy in the control group was usual care. In the intervention hospital, appropriate cefazolin use rose from 29 percent to 74 percent (p<0.001). However, the study's internal validity is moderate. The authors failed to explain how the control hospital was chosen; in addition, the improvement in cefazolin use occurred in all intervention hospital patients regardless of whether the sticker was used. This suggests a possible Hawthorne effect (i.e., physicians changed their behavior due to awareness that a study was ongoing) or spillover of the educational effect of the sticker to other clinical situations.

A randomized controlled trial took place in a major teaching hospital that had a preexisting integrated computerized physician order entry system (Table 4a). ^79^ Patients were randomized to receive a computerized reminder if prophylactic antibiotics needed redosing during a long operation. The study reported significantly more frequent intraoperative redosing in the intervention group (68 percent vs. 40 percent, p<0.001) though no statistically significant differences in the secondary outcome (surgical site infection rate was four percent in the treatment group vs. six percent in the control group, p=0.42). The study was likely underpowered to detect difference in infection rates. The study was a well-designed RCT, but has only moderate applicability because the study hospital's provider characteristics (which include familiarity with CPOE) are uncommon.

Interrupted Time Series Studies. One study ^86^ was conducted in a diverse group of 13 Dutch hospitals (both teaching and non-teaching) that were already participating in a national surveillance network (Table 4b). A supervising committee received surveillance data from the individual hospitals, and supplied feedback to the hospital based on process and outcome measures. They also organized educational meetings for both nurses and physicians, emphasizing guideline adherence and appropriate use of prophylactic antibiotics. The precise content of both the feedback and the educational content were not discussed. The study exhibited good internal and external validity. It was a prospectively designed study where the pre-intervention baseline was established in multiple hospitals over one year. In addition, the committee collected data on several process measurements as well as on surgical site infections. Given that these hospitals were part of a surveillance network, it seems likely that other QI interventions were ongoing but it is unclear whether these would have affected surgical site infections. The distribution of surgeries remained stable between hospitals, but the proportion of orthopedic and gynecological surgery increased after the intervention; the authors adjusted for this change in their comparison. The study's results are translatable to other settings because the investigators followed CDC recommendations for surgical site infection post-discharge surveillance and standard prophylactic antibiotic protocols. Results revealed statistically significant increases in appropriate duration (55.8 percent to 68.6 percent), selection (4.9 percent to 62.5 percent) and timing of antibiotic administration (49.5 percent to 60.6 percent). The study showed a non-significant trend toward reduced surgical site infections: 5.4 percent pre-intervention and 4.6 percent post-intervention.

Another study ^67^ used continuous quality improvement (CQI) methodology to target postoperative infections among women undergoing cesarean section at two maternity hospitals in Colombia (Table 4b). At each hospital, multidisciplinary teams were formed that underwent training in CQI methods by outside facilitators; these teams then researched the problem of SSI and formulated a structured approach using multiple cycles of interventions and measurement. The intervention focused on streamlining the process of ordering and administering perioperative antibiotics, along with feedback of infection rates to hospital administrators. The study's internal and external validity were excellent, as the investigators collected at multiple time points, performed appropriate ITS statistical analysis, measured both process measures (use of perioperative antibiotic prophylaxis and appropriate timing of prophylactic antibiotics) and infection rates, and used CDC/NNIS measurement standards. The intervention achieved statistically significant improvements in administration of antibiotics (i.e., whether or not antibiotics were given at all) and appropriate timing of antibiotics at both hospitals; SSI rates were significantly reduced as well.

Before-After Studies With Good Internal and External Validity. A large study was conducted in Italy between 1987 and 1989 in which a group of 12 hospitals convened a series of meetings with surgeons and nurses in each of the participating wards to discuss nosocomial infection rates and promote best practices (Table 4c). ^61^ Targeted practices included avoiding preoperative shaving, using appropriate, short-term antibiotic prophylaxis, limiting invasive procedures and drains, implementing respiratory exercises, and using optimal disinfection procedures. Several time points were measured, and multiple hospitals were used, strengthening both internal and external validity. The authors reported small but statistically significant improvements for all process measures, including a drop in prolonged antibiotic prophylaxis (36.9 percent to 27.2 percent, p<0.001). The surgical site infection rate was unchanged (7.8/100 to 6.7/100 cases, p>0.05); in addition, the authors reported non-significant changes in both the superficial infection rate (6.7/100 to 5.7/100 cases) and the deep infection rate (1.9/100 to 1.05/100 cases) but they did not state which definitions were used for these outcomes.

Table 4c Articles addressing prevention of surgical site infections (studies addressing use of appropriate antibiotic prophylaxis): before-after studies with good methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
*Greco 1991 ^61^ | Italy | 12/1988 – 6/1989 | 19 months | Appropriate use of perioperative antibiotics | QI strategies: Clinician education, audit and feedback, clinician reminder | Infection rate prior to intervention: 7.8% of patients
| Multiple hospitals of different types | | | Decreasing use of preoperative shaving of the operative site | Series of meetings with surgeons and nurses from each of participating wards. Data on infection incidence and practices were discussed and best practices reviewed including: appropriate use of perioperative antibiotics (pre-operative, limited duration, appropriate selection), avoidance of preoperative shaving, closed drainage of urinary catheters and surgical drains, implementation of respiratory exercises, use of hygienic measures for urinary catheters. | Infection rate after intervention: 6.2% of patients
| | | | Audit and feedback of infection rates to hospitals or individual clinicians | | p=NS

* This study addresses prevention of surgical site infections and catheter-associated urinary tract infections.

Before-After Studies With Moderate Internal and External Validity. A large multi-hospital study was conducted to examine implementation of several process measures, including appropriate use of prophylactic antibiotics, prevention of hyperglycemia, normothermia, avoidance of shaving, and optimization of oxygen tension (Table 4d). ^19^ Fifty-six hospitals participated in the effort, where teams of clinical leaders from each hospital attended learning sessions. They shared strategies and implemented them at their respective hospitals, but details regarding local implementation strategies were not available. Outcomes were analyzed by hospital, as patient level data was unavailable. Internal validity was strengthened by the reporting of outcomes for process measures and for surgical site infection. The surgical site infection rate showed a non-significant improvement from 2.3 per 100 cases to 1.7 per 100 cases. The improved adherence to all preventive interventions was statistically significant, including timing of antibiotics within one hour (72 percent to 92 percent), appropriate selection of antibiotics (90 percent to 95 percent), and discontinuation of antibiotics within 24 hours (67 percent to 85 percent). However, the authors could not adjust for differences in patient or provider characteristics as they only had access to hospital level data, and they did not report data on multiple time points prior to the implementation. Mitigating these concerns, the broad range of participating hospitals gave the data good external validity and reduces the possibility that the improvement represented regression to the mean.

Table 4d Articles addressing prevention of surgical site infections (studies addressing use of appropriate antibiotic prophylaxis): before-after studies with moderate methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Dellinger 2005 ^19^ | United States | 4/2002–2/2003 | 11 months | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education, audit and feedback, clinician reminder | Infection rate prior to intervention: 2.28% of cases
| Multiple hospitals of different types | | | Decreasing use of preoperative shaving of the operative site | Collaboration among 56 hospitals to study implementation of 1 or more quality initiatives. Each facility created team of “clinical champion” - surgeon or anesthesiologist - along with day-to-day coordinators. | Infection rate after intervention: 1.65% of cases; p=NS
| | | | Improving perioperative glucose control | Learning sessions performed every 4 months. | Adherence to administering perioperative antibiotics for the appropriate duration:
| | | | | Subsequently, information was brought back to individual facilities. Exact means of diffusion of information for specific measures were not stated. | before intervention: 72%
| | | | | | after intervention: 92%; p<0.01
| | | | | | Adherence to appropriate selection of perioperative antibiotics:
| | | | | | prior to intervention: 90%
| | | | | | after intervention: 95%; p<0.01
| | | | | | Adherence to protocols for perioperative shaving of the surgical site:
| | | | | | prior to intervention: 59%
| | | | | | after intervention: 95%; p<0.01
| | | | | | Adherence to protocols for perioperative normothermia:
| | | | | | prior to intervention: 57%
| | | | | | after intervention: 74%; p<0.01
| | | | | | Adherence to protocols for perioperative glucose control:
| | | | | | prior to intervention: 46%
| | | | | | after intervention: 54%; p<0.01
Larsen 1989 ^76^ | United States | 6/1986 – 11/1986 | 6 months | Appropriate use of perioperative antibiotics | QI Strategies: Audit and feedback, clinician reminder | Infection rate prior to intervention: 1.1% of cases
| Tertiary care or university hospital | | | | Authors used pre-existing information system (Health Evaluation through Logical Processing -HELP) to monitor patients. Subsequently, computer decision analysis tool implemented to prepare reminder stickers to be placed in chart. Reminder stickers focused on provision of appropriate antibiotic prophylaxis. | Infection rate after intervention: 0.7% of cases p value not supplied
| | | | | | Adherence to appropriate timing of perioperative antibiotics:
| | | | | | before intervention: 40%
| | | | | | after intervention: 58% p<0.01

One study implemented a computerized reminder using a preexisting computer decision analysis system to improve antibiotic prophylaxis (Table 4d). ^76^ The study was conducted prospectively, with baseline prescribing habits established during the first year and the intervention implemented during the second year. Computer generated reminders were placed in the chart during the intervention period. Antibiotics were given within two hours of incision in 40 percent of the sample prior to the intervention, and 58 percent of the sample after the intervention (p<0.001 for the difference). The infection rate declined from 1.8 percent to 0.9 percent, but the external validity of this outcome is diminished because the authors did not use CDC criteria to diagnose infections and did not conduct post-discharge surveillance.

Before-After Studies With Poor Internal and External Validity. Eight studies in this category met our inclusion criteria but had methodological flaws that seriously limited their internal external validity (Table 4e). ^65, ^ ^73, ^ ^75, ^ ^77, ^ ^78, ^ ^80, ^ ^83, ^ ^84^ An Italian study examined the impact of a preoperative antibiotic prophylaxis protocol, but included one time point before and after the intervention and gave few details as to the nature of the QI intervention. ^75^ In a 1988 study, a multidisciplinary program was used to promote use of single dose cefazolin in obstetrical and gynecological surgical procedures. ^77^ However, other QI interventions were ongoing, making the results less reliable; the authors also reported several results where the numbers were inconsistent. A study using a CPOE system to remind providers to redose prophylactic antibiotics during long surgeries showed a great improvement after institution of the protocol (20 percent to 58 percent) ^78^ but only reported data immediately before and after the intervention. A French study examined the effect of local guideline development on antibiotic usage but reported data in terms of a composite outcome (using indication, selection, dosage, timing, dosing interval, and duration), which limits our ability to discern the effect of the QI strategy. ^73^ In addition, only two time points were analyzed, which limits internal validity. A Brazilian hospital program used preprinted order forms to promote appropriate use of surgical antibiotic prophylaxis and demonstrated a statistically significant improvement in this process measurement; however, only two time points were analyzed. ^83^

Table 4e Articles addressing prevention of surgical site infections (studies addressing use of appropriate antibiotic prophylaxis): before-after studies with poor methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Brusaferro 2001 ^75^ | Italy | 12/1998 | 6 months | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education, audit and feedback | Compliance to guideline for perioperative antibiotic prescribing:
| Tertiary care or university hospital | | | | A protocol for perioperative antibiotic prophylaxis was developed by a group consisting of a microbiologist, chemist, anesthetist, clinical pharmacologist and three surgeons. Compliance with the protocol was measured before and after the intervention. Follow-up focus groups were conducted with the group and the surgical units after the data were collected. | before intervention: 4.3%
| | | | | | after intervention: 17.4%
| | | | | | p<0.01
Smith 1988 ^77^ | United States | 5/1988 – 11/1988 | 16 months | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education, clinician reminder | Compliance with using single dose cefazolin as preoperative antibiotic prophylaxis, percent compliance before intervention: 0%
| Tertiary care or university hospital | | | | 1) Direct education programs (in-service) were presented to anesthesia and OR staff.; 2) Change in OR drug stocks to change provider use; 3) In-service education by director of obstetrics and gynecology directed at specific attendings; 4) Eventually hospital required that formal Infectious Diseases consultation and approval for all disfavored antibiotics. | after intervention: 42.8%
| | | | | | p value not supplied
St. Jacques 2005 ^78^ | United States | Not specified | 1 month | Appropriate use of perioperative antibiotics | QI Strategies: Clinician reminder | Adherence to appropriate timing of perioperative antibiotics:
| Tertiary care or university hospital | | | | Used computer reminder system to assist in intraoperative redosing of prophylactic antibiotics. | before intervention: 20%
| | | | | | after intervention: 57%
| | | | | | p<0.01
Talon 2001 ^73^ | France | 6/1998–7/1998 | 2 months | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education, audit and feedback | Adherence to appropriate timing of perioperative antibiotics:
| Hospital type not specified | | | Audit and feedback of infection rates to hospitals or individual clinicians | A survey of antibiotic prescribing practices was performed and used to develop local guidelines for antimicrobial prophylaxis by a multidisciplinary team. | before intervention: 89%
| | | | | Diffusion of guidelines to all surgeons and anesthetists, as well as display of guidelines. | after intervention: 98%
| | | | | | Adherence to administering perioperative antibiotics for the appropriate duration:
| | | | | | before intervention: 76%
| | | | | | after intervention: 94%
| | | | | | Adherence to appropriate selection of perioperative antibiotics:
| | | | | | before intervention: 74%
| | | | | | after intervention: 96%
| | | | | | Overall percentage of inappropriate prescriptions (timing, duration, and selection):
| | | | | | Before intervention: 69%
| | | | | | After intervention: 18%; p=0.01
Prado 2002 ^83^ | Brazil | 10/1999 | 1 month | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education, clinician reminder | Infection rate prior to intervention: 4.1%
| Tertiary care or university hospital | | | | Multiple interventions were instituted: | Infection rate after intervention: 4.2%; p=NS
| | | | | 1) Created a multidisciplinary leadership team with representatives from surgical, infection control, pharmacy, and hospital epidemiology and quality-improvement departments.; 2) Creation of a preprinted perioperative antibiotic prophylaxis form indicating only type of surgery.; 3) Review of form by all parties involved (RNS, MDs); 4) initiation of perioperative antibiotic prophylaxis protocol. | Adherence to administering perioperative antibiotics for the appropriate duration:
| | | | | | before intervention: 21.4%
| | | | | | after intervention: 95.8%; p<0.01
| | | | | | Adherence to appropriate selection of perioperative antibiotics:
| | | | | | before intervention: 74.5%
| | | | | | after intervention: 97.2%; p<0.01
Gyssens 1996 ^80^ | Netherlands | 1990 -1992 | 14 months | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education, clinician reminder | Adherence to administering perioperative antibiotics for the appropriate duration:
| Tertiary care or university hospital | | | | A guideline for standard surgical antimicrobial prophylaxis was introduced, which called for standard single-dose prophylaxis with a cephalosporin to be delivered within 1 hour prior to surgical incision. | before intervention: 21%
| | | | | The guideline was introduced after a preintervention period in which the rates of appropriate antimicrobial prophylaxis were measured and reported to the department chairpersons. The protocol was developed in concert with the surgeons. The guideline was presented to the surgical department and junior pharmacists introduced it to the nursing staff (no other details on the implementation process are provided.) | after intervention: 85%
| | | | | | p<0.01
| | | | | | Adherence to appropriate timing of perioperative antibiotics:
| | | | | | before intervention: 42%
| | | | | | after intervention: 73%
| | | | | | p<0.01
Gyssens 1996 ^84^ | Netherlands | 1 month | Not specified | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education, audit and feedback, clinician reminder | Adherence to administering perioperative antibiotics for the appropriate duration:
| Tertiary care or university hospital | | | | The principal goal was to universally have a single-dose of cephazolin at incision. | before intervention: 79%
| | | | | Recommendations were adapted into new protocols and presentations were held on these new protocols. Junior pharmacists organized briefings for nurses and prophylaxis guidelines were displayed in the wards and operating rooms. Pharmacy techs discussed protocol violations with prescribers and nurses on their twice weekly visits to wards. | after intervention: 92%
| | | | | | p<0.01
Shapiro 1981 ^65^ | Israel | Not specified | Not specified | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education | Adherence to administering perioperative antibiotics for the appropriate duration:
| Multiple hospitals of different types | | | | Introduction of a protocol involving changing the perioperative antibiotics used previously, initiating prophylaxis shortly before the operation, and encouraged the curtailment of prophylactic administration of antimicrobial drugs in the early postoperative period. | before intervention: 39%
| | | | | | after intervention: 97% p value not supplied
| | | | | | p value not supplied

Two studies (conducted at the same hospitals in the Netherlands) measured compliance with guidelines regarding the selection and duration of antibiotics ^84^ or timing of prophylactic antibiotics ^80^ before and after an intervention (Table 4e). However, the intervention and pre-intervention measurement periods were two years apart and the intervention took place over one year in between measurements, making it difficult to infer causality in either study. Another study measured the effect of having control of antimicrobial drugs by an infectious disease specialist. ^65^ The average prophylactic drug course in the study was four days (range 1–34 days), limiting applicability to current practice.

### Studies Not Using Appropriate Antibiotic Prophylaxis as an Outcome

Controlled Trials. One controlled before-after study was conducted in multiple hospitals (including several teaching hospitals) and evaluated if a quality management project could reduce all types of nosocomial infections (Table 4f). ^66^ The investigators used ‘quality circles’ which consisted of a committee with at least one physician and one nurse representative from each study hospital. These committees actively reviewed infection control practices and surveillance data from each institution and guided modification of infection control practices. Surgical site infections declined from 2.2/100 cases to 1.6/100 cases (not statistically significant) and overall nosocomial infections declined from 7.5/100 cases to 5.3 cases/100 cases (a significant decrease). Several factors undermine the internal validity of the study. The control group was not randomly assigned, but instead consisted of those hospitals that declined to participate in the quality management project. In addition, the surgical site infection rate (but not the overall nosocomial infection rate) reverted back to baseline by the end of the study. The QI strategy (‘quality circles’) did not have a clear mechanism for improvement so it is difficult to infer causality between the intervention and the primary outcome, especially considering that all of the hospitals were interested in quality improvement and may have had concurrent QI projects.

Before-After Studies With Moderate Internal and External Validity. A study conducted in Israel measured infection rates for permanent cardiac antiarrhythmic devices before and after the implementation of comprehensive infection control program (Table 4g). ^74^ The investigators combined education on antiseptic techniques, avoidance of preoperative shaving, preoperative antiseptic showers, optimization of perioperative hyperglycemia, improvement in ventilation, and promotion of perioperative prophylaxis. The authors noted a decrease in the rate of infections from 4.2 percent in the immediate pre-intervention period to 0 percent. However, the rate of SSI had been 0.5 percent for three years prior to the increase to 4.2 percent, so the decrease could simply represent regression to the mean.

Table 4g Articles addressing prevention of surgical site infections (studies not using appropriate antibiotic prophylaxis as an outcome): simple before-after studies of moderate methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Borer 2004 ^74^ | Israel | 1997 - 9/2001 | 24 months | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention:
| Tertiary care or university hospital | | | Appropriate use of perioperative antibiotics | A check list of infection control items was devised. These consisted of hand hygiene, appropriate use of perioperative antibiotics, glycemic control, and decreasing use of shaving of the operative site. In addition to these interventions, there was strict aseptic techniques used to scrub the surgical site; staff couldn't wear fake nails or jewelry; staff received education and active surveillance was performed. | 4.2% of cases
| | | | Decreasing use of preoperative shaving of the operative site | | Infection rate after intervention: 0% of cases
| | | | Improving perioperative glucose control | | p<0.01
Lutarewych 2004 ^70^ | United States | 1/2002 – 2/2002 | 1 year | Improving perioperative glucose control | QI Strategies: Clinician education, audit and feedback, patient education | Infection rate prior to intervention:
| Not specified | | | | Multiple interventions were implemented: | 7.58% of cases
| | | | | 1) perioperative glucose control; 2) maintenance of strict sterility of the graft and sternal wound sites.; 3) use of intranasal mupirocin during the perioperative period; 4) use of a sports bra for women with a cup size of C or larger to reduce pulling on the incision site; 5) reduction of traffic in and out of the operative suite; 6) administration of the preoperative antibiotic l<1 hour before incision; 7) a consistent preoperative shower with chlorhexidine | Infection rate after intervention:
| | | | | Improvement in compliance was directed to staff to reinforce education about other measures. | 3.47% of cases
| | | | | | p value not reported
Rao 2004 ^85^ | United States | 1/1999 – 4/1999 | 20 months | Appropriate use of perioperative antibiotics | QI Strategies: Clinician education, clinician reminder | Infection rate prior to intervention: 2.1% Infection rate after intervention: 1.5%
| Tertiary care or university hospital | | | Decreasing use of preoperative shaving of the operative site | ICP was assigned to the open-heart surgery program. ICP followed patient from admission to discharge and implemented the following program: prospective surveillance of superficial and deep chest and leg infections; post discharge follow up of patients readmitted within 30 days; chlorhexidine showers by pts the night before/morning of surgery; hair removal by clippers only; administration of antibiotics 2 hours before surgical incision; segregation of surgical instruments; improved glycemic control. | p=NS
| | | | Improving perioperative glucose control | | Adherence to protocols for perioperative antibiotic prophylaxis:
| | | | | | before intervention: 70%
| | | | | | after intervention: 92%
| | | | | | p value not reported
Won 2004 ^87^ | Taiwan | 9/1998 – 8/2000 | 22 months | Hand hygiene | QI Strategies: Clinician education, audit and feedback | Infection rate prior to intervention: 0.33% per 1,000 patient days
| Tertiary care or university hospital | | | | A multifaceted campaign to encourage hand hygiene was implemented. All health care workers received lectures on appropriate use of hand cleansing agents, correct hand washing techniques, and importance of hand washing. This information was incorporated into regular resident orientation sessions. | Infection rate after intervention: 0.84 per 1,000 patient days
| | | | | Cartoon reminders were posted above each sinks along with printed reminders in easily visible sites. Observations of hand washing were made by other NICU nurses, and results posted in the NICU each month. One-on-one feedback was privately given to individual healthcare workers who did not perform hygiene appropriately, and positive reinforcement was given at NICU staff meetings. Financial incentives were given to nurses as an extra monthly bonus, individualized by the number of correct observed hand washing opportunities. The formal lectures were discontinued after 2 years, but the other measures continued for an additional 16 months. | p=NS
| | | | | | Adherence to protocols for hand hygiene:
| | | | | | before intervention: 43%
| | | | | | after intervention: 81%
| | | | | | p<0.01

Two studies in this category investigated quality improvement in cardiac surgery (Table 4g). ^70, ^ ^85^ One study developed a protocol based on local committee literature search and consensus-building session after investigators realized that their hospital's infection rate was far above the NNIS mean at 7.58 percent. ^70^ The protocol consisted of encouraging all of the following: (1) perioperative glucose control; (2) maintenance of strict sterility of the graft and sternal wound sites; (3) use of intranasal mupirocin during the perioperative period; (4) post-operative use of a sports bra for women with a cup size of C or larger to reduce pull on the incision site; (5) reduction of traffic in and out of the operative suite; (6) administration of the prophylactic antibiotic within one hour of incision; (7) a preoperative shower with chlorhexidine. Specific educational programs emphasized each one of the above to the nursing staff. The authors reported a decrease in the surgical site infection rate to 3.47 percent (from 7.58 percent), but did not report results for process measures. The study findings are generalizable to other interested hospitals because the hospital used standard CDC diagnostic criteria for surgical site infections. However, some of the interventions are atypical, and the effectiveness of any one of the measures is indeterminate. The other study ^85^ employed a ‘Plan-Do-Check-Act’ continuous quality improvement model, and a dedicated infection control practitioner was responsible for ensuring compliance. They emphasized several interventions: (1) perioperative glucose control; (2) segregation of instruments for graft and sternal wound sites; (3) reduction of traffic in and out of the operative suite; (4) administration of the perioperative antibiotic in the holding area; (5) a preoperative shower with chlorhexidine. The authors did not report results for these process measures. They did note pre-intervention infection rates, and also reported that the mediastinitis rate declined from 2.1 percent to 1.5 percent (non-significant trend) and the leg wound infection rate declined from 1.93 percent to 0.47 percent (a significant improvement). However, mediastinitis rates had risen from 0.8 percent four years prior to the study to 2.1 percent during the pre-implementation period without explanation; the subsequent decrease could represent regression to mean. The external validity of the study was diminished to some extent because the authors did not report the diagnostic criteria for surgical site infections.

The last study in this group examined whether a handwashing promotion program decreased nosocomial infection rates in a neonatal intensive care unit (Table 4g). ^87^ After a prospective observational period established baseline infection rates, a special educational program which explained the merits of hand washing began for all clinical staff in the neonatal intensive care unit, and compliance was subsequently monitored by observers. Hand hygiene compliance improved from 43 percent to 80 percent during the promotional period, but surgical site infection rates did not show a statistically significant change. External validity was improved because the study used CDC criteria for the diagnosis of infection. However, the stated surgical site infection rate of 0.33/1,000 patient-days is difficult to interpret, as the number of surgical cases was not reported.

Before-After Studies With Poor Internal and External Validity. Several studies met our inclusion criteria but had methodological flaws that seriously limited their internal validity or applicability (Table 4h). ^68, ^ ^69, ^ ^71, ^ ^72, ^ ^81, ^ ^82^ One study attempted to reduce the nosocomial infection rates using educational programs directed at handwashing but did not use CDC or NNIS criteria for measuring surgical site infections and did not conduct post-discharge surveillance. ^81^ Another study measured the effect of a comprehensive program of infection control practices but only reported one time point before and after the intervention and also did not report the effect on process measures. ^68^ In addition, the study's results translate poorly to current practices because the surgical site infection rate was 24.4 percent prior to the intervention and standard CDC definitions for wound infections were not used. Two studies involving surgical site infections in cardiothoracic surgery patients reported data only immediately before and after the intervention, and did not include outcomes for the various prevention interventions. ^72, ^ ^82^ One of these studies did not report using standard NNIS or CDC criteria to diagnose wound infections; ^72^ the other study did not comment on the higher infection rates seen in the middle years of study. ^82^ Another study in this category investigated quality improvement in cardiac surgery patients but did not clearly define pre-intervention period, and defined outcomes in terms of observed/expected infection rates but did not state how these were created.69 In addition, pre-intervention compliance was not discussed for most interventions in the study.

A United Kingdom (UK) study examined if using audit and feedback methods could reduce surgical site infection rate in the UK. ^71^ The authors extended post-discharge surveillance to 30 days, and then reported the results to participating surgeons. The overall surgical site infection rate significantly declined over 29 months from 13.9 percent to 7.9 percent. However, the authors did not report how the surgeons used the information or if concomitant QI efforts were underway. In addition, there was significant variation in the monthly infection rate, which was not reflected in the before-after statistical analysis. External validity is also limited by the relatively high pre-intervention surgical site infection rate.

Finally, a study conducted in an intensive care unit in a tertiary care center in Guatemala examined the effect of an educational program on hand hygiene, aseptic technique and multiple nosocomial infections. ^60^ The study included surgical site infection as an outcome, but focused on ventilator-acquired pneumonia primarily, and will be discussed in more detail in the VAP section.

## Central Line-Associated Bloodstream Infections

### Included Studies: Settings, Goals, and Target Populations

Our literature search identified 19 studies that met our inclusion criteria that specifically addressed prevention of central line-associated blood stream infection (CLABSI) (Tables 6a–6e). One of the studies ^60^ reported data on CLABSI rates, but primarily addressed VAP prevention. This study will be discussed in detail in the section on VAP but will not be included in the analysis of CLABSI. This left 18 studies for analysis. Ten of the 18 studies were from centers within the United States ^88^ – ^97^ and eight were from outside the United States. ^62, ^ ^98^ – ^104^ Seventeen of the studies specifically targeted reduction of CLABSI, while one ^62^ targeted CLABSI and VAP. All but one of the studies was from a single center. One study ^96^ reported data from multiple hospitals that varied from tertiary teaching centers to community non-teaching hospitals. Of the remaining studies, 14 were from tertiary care medical centers and three from community hospitals. One of these community hospitals had residents, ^100^ while the other two were non-teaching centers. ^92, ^ ^102^ One study ^104^ did not report the type of hospital. Most studies took place in ICUs. One study was from a bone marrow transplant unit ^90^ and two did not state the type of unit that was studied. ^91, ^ ^104^ One study was located in a neonatal ICU ^62^ and the remaining studies were from adult medical or surgical ICUs.

Table 6a Articles addressing prevention of central line-associated bloodstream infections (CLABSI): controlled studies

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Berenholtz 2004 ^94^ | United States | 2/1999–12/2001 | 2 years | Hand hygiene | QI Strategies: Clinician education, audit and feedback | Intervention group:
| Tertiary care or university hospital | | | Maximal sterile barrier precautions | Multiple interventions to reduce CLABSI were introduced in a staggered fashion.; 1) Beginning 2/1999, all physicians or physician extenders who inserted CVCs were required to complete a Web-based training module and 10-question posttest. The training module emphasized hand hygiene, maximal sterile barrier precautions, chlorhexidine skin sterilization, and subclavian site as the preferred insertion site. It also addressed the care of central lines after insertion. In 2002, completion of the module was required for physicians. Infection control staff also provided 16 lectures for nurses and five for physicians to reinforce the guidelines. Monthly CLABSI rates were posted in the SICU.; 2) A central catheter insertion cart containing all the materials needed to insert a CVC was introduced in 6/1999.; 3) Beginning 6/2001, the ICU team began asking whether catheters could be removed every day during rounds, and added it to the daily goals form for each patient.; 4) A standardized checklist for CVC insertion, completed by nurses, was introduced in 11/2001.; 5) Beginning 12/2001, nurses were empowered to stop insertion of a CVC if the checklist was not followed (except in an emergency.) | Before intervention: 11.3 CLABSI per 1,000 catheter-days
| | | | Appropriate insertion site selection | | After intervention: 0 CLABSI per 1,000 catheter-days
| | | | Chlorhexidine skin disinfection | | Control group:
| | | | Prompt removal of unnecessary catheters | | Before intervention: 5.7 CLABSI per 1,000 catheter-days
| | | | | | After intervention: 1.6 CLABSI per 1,000 catheter-days
| | | | | | p value for comparison of change in intervention group versus change in control group = NS
Eggimann 2000 ^99^ | Switzerland | 3/1997 – 4/1997 | 8 months | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention: 3.1 microbiologically documented CLABSI per 1,000 catheter-days
| Tertiary care or university hospital | | | Maximal sterile barrier precautions | A multiple-approach intervention strategy targeted at the reduction of vascular-access infections was implemented in March 1997. An educational campaign consisting of 30-min slide-shows and practical demonstrations was developed for all medical ICU staff (21 fellows or residents, 82 nurses, and 15 nursing assistants), and was completed by individual in-service training. The guidelines covered the following: preparation of the material to avoid any interruption during insertion; skin preparation (hair-cutting instead of shaving) and disinfection (alcohol-based solution of chlorhexidine gluconate 0.5%, with 2 min drying time); maximum barrier precautions (sterile gloves and gown, cap, mask, and a large sheet) used for all but peripheral lines; subclavian or wrist vein as standard insertion sites; and dressings (dry gauze covered by a non-occlusive adhesive band). Administration sets, devices, and dressings were replaced every 72 h, except for lines receiving lipid or blood products, and for the first dressing after catheter insertion 24 h. | Infection rate after intervention: 1.2 CLABSI per 1,000 catheter-days
| | | | Chlorhexidine skin disinfection | Hand disinfection was strongly emphasized before and after the insertion, replacement, or manipulation of any vascular device. Central lines were not routinely replaced, but were changed over a guidewire in cases of clinical sepsis without documented source of infection. | p<0=0.04
| | | | Prompt removal of unnecessary catheters | Prompt removal of any device not intended for use was strongly recommended.

Table 6b Articles addressing prevention of central line-associated bloodstream infections: interrupted time series

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Pronovost (unpublished) ^96^ | United States | 3/2004 – 2/2005 | 3 months | Hand hygiene | QI Strategies: Clinician education, audit and feedback, clinician reminder, organizational change | Median infection rate prior to intervention: 2.8 CLABSI per 1,000 catheter-days
| Multiple hospitals of different types | | | Maximal sterile barrier precautions | Using a multiple time series design, Keystone ICU involved individual ICUs implementing several different patient safety interventions and monitoring the impact of these interventions on specific safety measures. In addition to the multi-faceted intervention to reduce CLABSI, ICUs implemented a “Daily Goals Sheet” to improve communication between clinicians in the ICU, a multi-faceted intervention to reduce ventilator-associated pneumonia, and a comprehensive unit-based safety program (CUSP) to improve safety culture. | Median infection rate after intervention: 0 per 1,000 catheter-days
| | | | Appropriate insertion site selection Chlorhexidine skin disinfection | The implementation period for each intervention was estimated to take three months. Hospitals were asked to start with CUSP and then choose the implementation order for the remaining three patient safety interventions during the 12-month period. | p<0.01
| | | | Prompt removal of unnecessary catheters | Before implementing any patient safety intervention, each ICU designated at least one physician and nurse as team leaders. These team leaders were given detailed training and then were responsible for disseminating the interventions to their colleagues. Team leaders participated in biweekly conference calls and attended two state-wide meetings during the year. For each intervention, teams were provided a manual of operations that included details regarding the efficacy of the intervention, evidence supporting the intervention, suggestions for implementing the intervention, and methods of data collection.
| | | | | Interventions were: washing hands prior to the procedure, using full barrier precautions, cleaning the skin around the insertion site with chlorhexadine, avoiding the femoral site if possible, and removing unnecessary catheters.
| | | | | The strategy to increase the use of these evidence-based interventions had six components, as described in detail elsewhere. First, ICU clinicians were educated to increase their awareness of evidence-based infection control practices and to review the harm caused by CLABSI. Second, a cart with all supplies and equipment necessary for central line insertion was created to reduce the number of steps necessary in preparing for safe and sterile line insertion. Third, a central line insertion checklist was used by the ICU bedside nurse to help ensure a safe and sterile procedure. Fourth, nurses were empowered to stop a central line insertion (in non-emergency situations) if providers did not comply with evidence-based infection control practices. Fifth, ICU staff discussed whether central lines could be removed during daily physician rounds.
| | | | | Finally, monthly feedback was provided to teams regarding the number of CLABSIs and quarterly feedback regarding rates of CLABSI in their ICU.

Table 6e Articles addressing prevention of central line-associated bloodstream infections: simple before-after studies of poor methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Bijma 1999 ^98^ | The Netherlands | Not specified | 6 months | Hand hygiene | QI Strategies: Clinician education; organizational change | Infection rate prior to intervention: 15.0 CLABSI per 1,000 catheter-days
| Tertiary care or university hospital | | | | The following fivefold intervention was consecutively implemented during a 12-month period:; 1 A propanol/isopropanol solution containing a quaternary ammonium compound and an emollient to prevent excessive drying of the skin was introduced as a hand disinfecting agent.; 2 An adhesive, non-woven, island-type gauze was introduced as CVC dressing.; 3 A “one bag” TPN system was introduced.; 4 A small needleless closed IV connection device was incorporated in every SICU patient's IV system.; 5 Implementation of the aforementioned measures was carried out by and under continuous surveillance of the SICU's infection control practitioner (ICP).; Checking protocol compliance required the ICP's daily presence on the SICU. | Infection rate after intervention: 8.0 CLABSI per 1,000 catheter-days
| | | | | | P=NS
*Lam 2004 ^62^ | Hong Kong | Not specified | 10 months | Hand hygiene | QI Strategies: Clinician reminder; organizational change | Infection rate prior to intervention: 6.8 CLABSI per 1,000 catheter-days
| Tertiary care or university hospital | | | | Nurses and physicians received an educational program targeting hand hygiene. A hand hygiene protocol was implemented as part of the orientation for new staff. Face-to-face educational seminars were conducted for nurses and physicians where solutions to overcome obstacles to hand washing were provided; 2 sessions were provided for physicians and 10 for nurses. A task-oriented analysis was performed to identify strategies for hand washing during complex procedures. Demonstrations were conducted at regular intervals, and reminder pictures were posted at each hand washing basin. | Infection rate after intervention: 1.2 CLABSI per 1,000 catheter-days
| | | | | | p=NS
| | | | | | Compliance with hand hygiene:
| | | | | | Before intervention: 40%
| | | | | | After intervention: 53%
| | | | | | p<0.01
Lobo 2005 ^101^ | Brazil | 1/01 through 12/02 | 20 months | Hand hygiene | QI Strategies: Clinician education; audit and feedback, clinician reminder | Infection rate prior to intervention: 20 CLABSI per 1,000 catheter-days
| Tertiary care or university hospital | | | Maximal sterile barrier precautions | An education program was developed by a multidisciplinary task force focusing on CVC insertion, manipulation, and care. 3 infection control nurses, a physician, and the entire unit staff were on the task force. | Infection rate after intervention: 11 CLABSI per 1,000 catheter-days
| | | | | | p value not reported
| | | | | | Adherence to appropriate use of maximal sterile barrier precautions:
| | | | | | Before intervention: 91%
| | | | | | after intervention: 100%
| | | | | | p=NS
Penne 2002 ^90^ | United States | January 1997-July 1998, | Not specified | Hand hygiene | QI Strategies: Clinician education; audit and feedback; clinician reminder; organizational change | Number of CLABSI before intervention: 39
| Tertiary care or university hospital | August 1998-March 2000 | | Maximal sterile barrier precautions | A nurse educator performed individual education sessions with each staff member and demonstrated dressing change to ensure sterile technique and proper application of dressing to prevent risk of infection | Number of CLABSI after intervention: 24
| | | | | | Note: number of catheter-days not supplied
Puntis 1991 ^104^ | UK | Not specified | Not specified | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention: 45% of catheters infected
| Not specified | | | | The nutritional care team at a children's hospital instituted an education program for care of catheters used for parenteral nutrition. Hand hygiene was emphasized, and new guidelines for catheter care were drawn up emphasizing use of aseptic technique and proper technique for changing feeding bags. Demonstrations of line care and bag changing were organized for nursing staff at which attendance was compulsory. A video of proper technique was also shown. | Infection rate after intervention: 8% of catheters infected
| | | | | This educational intervention was delivered to junior medical staff and nurses.
Rosenthal 2003 ^102^ | Argentina | Bernal Medical center: 4/1999–5/1999; | 22 months | Hand hygiene | QI Strategies: Clinician education; audit and feedback | Infection rate prior to intervention: 45.94 CLABSI per 1,000 catheter-days
| Non-teaching community hospital | Colegiales Medical Center, 9/2000–12/2000 | | Maximal sterile barrier precautions | A surveillance and educational intervention was implemented at 2 ICUs in Argentina. Health care workers in the study ICUs underwent training for central venous catheter care based on CDC guidelines (at the time, these included hand hygiene, maximal sterile barrier precautions, appropriate insertion site selection and prompt removal of unnecessary catheters; however, chlorhexidine skin sterilization was not part of the guidelines.) Subsequently, performance feedback on catheter site care was provided to the ICU staff on a monthly basis. Compliance rates with catheter care were also provided to ICU administrators. This intervention was referred to as phase 2 (phase 1 being the pre-intervention period.) A separate intervention to encourage hand washing was implemented simultaneously; all health care workers received a comprehensive infection control manual. Hand washing compliance was observed covertly in the ICU by an infection control practitioner and monthly meetings were held at which hand washing rates were displayed and fed back to providers. Hand washing rates were also posted monthly in the ICUs and reported to the ICU manager and administrator. | Infection rate after intervention: 9.90 CLABSI per 1,000 catheter-days
| | | | Appropriate insertion site selection | The hand washing guideline was also posted in the ICU. Educational classes were given in 1-hour group sessions for each shift daily for 1 week (attendance was voluntary). | p<0.01
| | | | Prompt removal of unnecessary catheters | Participants underwent a posttest to evaluate retention of the educational material. In addition, infection control review classes were held to answer questions and share surveillance data. | Adherence to protocols for hand hygiene before intervention: 23.1%
| | | | | | after intervention: 64.5%
| | | | | | p<0.01
Wall 2005 ^95^ | United States | began 11/2002 | 2 years | Hand hygiene | QI Strategies: Clinician education; audit and feedback | Infection rate prior to intervention: 7.0 CLABSI per 1,000 catheter-days
| Tertiary care or university hospital | | | Maximal sterile barrier precautions | A continuous quality improvement intervention was conducted in a medical intensive care unit. An interdisciplinary team consisting of the MICU director and nurse manager, MICU nurses and physicians, epidemiologist, infection control practitioner and QI experts was assembled and decided to focus on central line insertion practices (after reviewing relevant prevention literature). The intervention primarily targeted house staff physicians. A nurse observed central line insertions to determine the baseline quality gap. A checklist for central line insertion was developed that mandated: hand hygiene, maximal sterile barrier precautions, chlorhexidine skin preparation, and proper supervision of trainees. (These steps could be skipped if the insertion was considered an emergency.) | Infection rate after intervention: 3.8 CLABSI per 1,000 catheter-days
| | | | Chlorhexidine skin sterilization | Providers were educated on the checklist and supporting evidence through a web-based tutorial with self-assessment exam; house staff was required to complete the tutorial. Infection rates and rates of compliance with process measures were fed back to the front line staff.
**Berg 1995 ^60^ | Guatemala | 3 months | 1 year | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention: 14% of patients
| Tertiary care or university hospital | | | | A multifaceted intervention was used to target nosocomial infections in the ICU, with both general measures and measures targeting VAP and CA-UTI. | Infection rate after intervention: 13% of patients
| | | | | Nurses and physicians received 15 educational sessions on aseptic technique, stressing proper hand washing. The educational sessions used lectures and demonstrations, and individual clinicians also received positive and negative feedback and reminder signs at the bedside. The VAP intervention targeted proper use of sterile rinse water and improvement in aseptic technique for suctioning. Providers received more than 15 interactive conferences on the detection, management, and prevention of nosocomial pneumonia; these included lectures, demonstrations, individual instruction and feedback, and contests. The CA-UTI intervention consisted of changing open urinary drainage systems to closed systems (aseptic catheter care), with an educational session on the new catheter. The intervention did not specifically target surgical site infections, but those outcomes are reported. | p=NS
| | | | | | Adherence to protocols for hand hygiene:
| | | | | | before intervention: 5%
| | | | | | after intervention: 63%
| | | | | | p<0.01

* This study addresses prevention of central line-associated bloodstream infections and ventilator-associated pneumonia.

** This study addresses prevention of surgical site infections, central line-associated bloodstream infections, ventilator-associated pneumonia and catheter-associated urinary tract infections.

All of the studies reported rates of CLABSI; nine of the studies also reported data on process measurements. ^89^ – ^93, ^ ^96, ^ ^100, ^ ^101, ^ ^103^ The study populations were highly variable, with baseline CLABSI ranging from 2.7 episodes of CLABSI/1,000 catheter-days ^96^ to 45.9 CLABSI/1,000 catheter-days. ^102^ The range of study duration was 4–39 months, with the median being 23 months. Four studies ^62, ^ ^96, ^ ^98, ^ ^104^ did not report duration.

### Preventive Interventions and Outcomes Measured

We identified hand hygiene, use of maximal sterile barrier precautions, appropriate insertion site selection, chlorhexidine skin disinfection, and prompt removal of unnecessary catheters as target preventive interventions for this review (Tables 6a–6e). All studies but two ^92, ^ ^97^ targeted hand hygiene; the next most common targeted strategy was maximal sterile barrier precautions. Five studies targeted hand hygiene alone, ^62, ^ ^88, ^ ^98, ^ ^100, ^ ^104^ four targeted hand hygiene and maximal sterile barrier precautions, ^90, ^ ^91, ^ ^101, ^ ^103^ and seven studies targeted hand hygiene, maximal sterile barrier precautions, and at least one other preventive strategy ^89, ^ ^93^ – ^96, ^ ^99, ^ ^102^ (Tables 6a–6e). A number of included studies also attempted to reduce CLABSI by improving nursing care of catheters already in situ. ^88, ^ ^89, ^ ^99^ We did not consider in situ catheter care as a target preventive intervention as there is a stronger evidence base supporting proper insertion practices as effective means of preventing CLABSI, but these interventions may have contributed to the observed effects in these studies.

### Quality Improvement Strategies Used

Tables 6a–6e list the QI strategies employed in each study and provide details on the QI intervention. All but one of the studies employed educational strategies for health care providers as part of their intervention (Lam ^62^ did not include provider education). Most of the educational programs were for nurses and physicians; ^88, ^ ^89, ^ ^91^ – ^94, ^ ^96, ^ ^97, ^ ^99^ – ^104^ one study only provided education for nurses ^90^ and another only for physicians. ^95^ One study ^98^ did not specify who was given education. Most educational interventions involved distributed educational material ^88, ^ ^89, ^ ^92, ^ ^94^ – ^96, ^ ^99, ^ ^102^ – ^104^ or lecture format. ^89, ^ ^91^ – ^94, ^ ^96, ^ ^97, ^ ^100^ – ^102, ^ ^104^ Three particularly intensive educational programs combined distributed material, lectures, and interactive workshops. ^92, ^ ^93, ^ ^102^ Other modes of provider education used in the studies were consensus-building sessions, ^88^ distribution of “promotional materials”, ^89^ and academic detailing. ^90, ^ ^101^ The majority of studies that used education used more than one modality for delivery of educational content.

In addition to provider education, the strategies of audit and feedback, clinical reminders, and organizational change were employed to encourage behavioral change. Eleven studies employed audit and feedback, ^88, ^ ^90, ^ ^92^ – ^97, ^ ^100^ – ^102^ five employed strategies that included organizational change, ^62, ^ ^90, ^ ^96^ – ^98, ^ ^100^ and four used clinical reminders. ^62, ^ ^90, ^ ^96, ^ ^101^ Seven studies used two different strategies, ^62, ^ ^88, ^ ^92, ^ ^93, ^ ^95, ^ ^98, ^ ^102^ five used only provider education, ^89, ^ ^91, ^ ^99, ^ ^103, ^ ^104^ three studies employed three of the strategies, ^97, ^ ^100, ^ ^101^ and two studies used all four strategies to encourage behavioral change. ^90, ^ ^96^

### Study Methodologic Quality

The methodological quality of studies was limited, as all but two used a quasi-experimental, before-after design (Tables 6a–6e). In addition, there was extensive variability in the duration of studies and whether the intervention ran in series or coincident with the period measuring the intervention's effect. To help facilitate comparison between studies and qualitative analysis, we developed criteria to characterize internal and external validity for simple before-after studies (Table 7). One study met all three criteria for internal validity. ^100^ Eight studies met two out of three, ^88, ^ ^89, ^ ^91^ – ^93, ^ ^96, ^ ^101, ^ ^103^ three studies met one out of three, ^90, ^ ^95, ^ ^97^ and five studies met none. ^62, ^ ^98, ^ ^99, ^ ^102, ^ ^104^ Most studies met criteria for external validity. Only three studies did not measure CLABSI by NNIS/CDC definitions, ^90, ^ ^95, ^ ^98^ and three studies did not report infection rates in terms of days of device utilization. ^90, ^ ^102, ^ ^104^

Table 7 Quality criteria for simple before-after studies addressing central line-associated bloodstream infections

| Internal Validity | | | External Validity
Author | Did the study report data on more than one time point before and after the intervention? | If the study reported infection rates, did it also report process measurements? | Was the intervention performed independent of other QI efforts or other changes? | Did the study use NNIS/CDC methods for measuring infections? | Did the study report infection rates in terms of device utilization?
Berg 1995 ^60^ | o | • | ▴ | • | •
Bijma 1999 ^98^ | o | o | ▴ | o | •
Coopersmith 2002 ^88^ | • | o | • | • | •
Coopersmith 2004 ^89^ | • | • | ▴ | • | •
Frankel, 2005 ^97^ | • | o | o | • | •
Higuera 2005 ^100^ | • | • | • | • | •
Lobo 2005 ^101^ | o | • | • | • | •
Lam 2004 ^62^ | o | o | ▴ | • | •
Penne 2002 ^90^ | o | • | ▴ | o | o
Puntis 1991 ^104^ | o | o | ▴ | • | o
Rosenthal 2003 ^102^ | o | o | o | • | o
Sheretz 2000 ^91^ | • | • | ▴ | • | •
Wall 2005 ^95^ | • | o | ▴ | o | •
Warren 2003 ^92^ | o | • | • | • | •
Warren 2004 ^93^ | • | • | ▴ | • | •
Yoo 2001 ^103^ | o | • | • | • | •

•: Yes o: No ▴: Unclear

Given the heterogeneous study groups, the variety of specific interventions, and the significant methodological limitations of all the included studies, we were not able to perform quantitative analysis of the data. We will summarize the studies that we considered to have generally stronger internal and external validity.

Controlled Before-After Studies. One study ^94^ measured the effect of their intervention in an ICU that cares for patients undergoing general, orthopedic, transplant, trauma, and vascular surgery, and compared the results to a concurrent control ICU that cares for patients undergoing cardiac surgery (Table 6a). An interdisciplinary team of physicians, nurses, and infection control practitioners implemented five interventions over a period of nearly two years: (1) education of staff to increase provider awareness of evidence-based infection control practices (a hospital-wide intervention which also targeted providers in the control ICU). All physicians or physician extenders who inserted CVCs were required to complete a Web-based training module and 10-question posttest. Completion of the module was required for physicians. Infection control staff also provided 16 lectures for nurses and five for physicians to reinforce the guidelines. Monthly CLABSI rates were posted in the SICU; (2) a central catheter insertion cart containing all the materials needed to properly insert a CVC was introduced on the study unit; (3) the ICU team began asking whether catheters could be removed every day during rounds, and added this prompt to the daily goals form for each patient; (4) a standardized checklist for CVC insertion, completed by nurses, was implemented; (5) nurses were empowered to stop procedures if guidelines contained in the checklist were not followed. The cumulative intervention targeted hand hygiene, maximal sterile barrier precautions, chlorhexidine skin disinfection, and subclavian vein as the preferred insertion site. It also addressed the care of central lines after insertion. Cases were defined by NNIS criteria, and the data were normalized to days of device usage. CLABSI rates in the study unit decreased from 11.3/1,000 catheter-days in the quarter before the beginning of the intervention to 0/1,000 catheter-days in the quarter when nurses were empowered to stop the procedure if guidelines were not followed. The control unit also saw a decrease in rates of CLABSI, from 5.7/1,000 catheter-days to 1.6/1,000 catheter-days over the same time period. Study data were analyzed by using a Poisson regression model to model the change in infection rates over time and by comparing the slopes and intercepts of the regression lines for the intervention and control groups. There was no significant difference between the regression lines for either slope or intercept. This raises the possibility that the educational intervention (which was delivered to both groups) may have entirely accounted for the intervention effect. No process measures were reported. A subsequent report documented sustained reductions in CLABSI over an additional 18 months of followup. ^105^

An educational campaign aimed at reducing CLABSI was the main intervention in another controlled study out of the medical ICU of a large tertiary medical center in Geneva, Switzerland (Table 6a). ^99^ The program consisted of 30-minute slide shows and practical demonstrations and was given to all medical intensive care unit (MICU) staff (fellows, residents, nurses, nursing assistants). Among our targeted interventions, proper hand hygiene, use of chlorhexidine for skin preparation, maximal sterile barrier precautions, and use of the subclavian vein as the preferred site were specifically addressed. Rates of CLABSI before and after the educational campaign were compared to rates in the surgical ICU (SICU) of the same hospital; the authors do not comment how isolated the units are, and it is possible that there was crossover among unit personnel. The study did not report data at multiple time points and did not report process measures. Data for arterial and central venous lines were reported in aggregate. Rates of CLABSI decreased from 11.3/1,000 catheter-days to 3.8/1,000 catheter-days in the MICU (study unit), while they were unchanged during the same period in the control SICU (10.3/1,000 catheter-days before and 11.6/1,000 catheter-days after the educational campaign). A subsequent report documented a sustained reduction in CLABSI over six years of follow-up. ^106^

Interrupted Time Series Studies. A yet to be published study employed a complex multiple time series design. ^96^ This project took place in 107 separate ICUs in the state of Michigan over a one-year period. Study ICUs were diverse, ranging from small non-teaching community hospitals to large tertiary academic centers; both surgical and medical ICUs were included. In addition to an intervention to reduce CLABSI, participating ICUs sequentially introduced a “Daily Goals Sheet” to improve communication among healthcare personnel, a multi-faceted intervention to reduce ventilator-associated pneumonia, and a comprehensive unit-based safety program to improve safety culture.

The implementation period for each of the four interventions was estimated to take three months. Hospitals were asked to start with the comprehensive unit-based safety program, and then choose the implementation order for the remaining three patient safety interventions during the 12-month period. The included manuscript comments only on the intervention to reduce CLABSI; it does not give details of the nature or outcomes of the other patient safety programs.

Before implementing any patient safety intervention, each ICU designated at least one physician and nurse as team leaders. For CLABSI, interventions were washing hands prior to the procedure, using full barrier precautions, cleaning the skin around the insertion site with chlorhexadine, avoiding the femoral site if possible, and removing unnecessary catheters. A bundle of six strategies was used to increase adherence to these targeted interventions, similar to those used in a prior study: ^94^ (1) ICU clinicians were educated to increase their awareness of evidence-based infection control practices and to review the harm caused by CLABSI; (2) A central catheter insertion cart containing all the materials needed to properly insert a CVC was introduced on the study unit; (3) the ICU team began asking whether catheters could be removed every day during rounds, and added it to the daily goals form for each patient; (4) A standardized checklist for CVC insertion, completed by nurses, was implemented; (5) Nurses were empowered to stop procedures if guidelines contained in the checklist were not followed; and (6) teams were provided with monthly feedback regarding the number of CLABSI and quarterly feedback regarding rates of CLABSI in their ICU.

Data was acquired at baseline and at three-month intervals. The sequential nature of the implementation and time frame of the study meant that no single center had a complete data set; data from all of the study centers was analyzed in aggregate. As a result, the population of centers included in the baseline data set and subsequent post-intervention data sets had significant overlap, but were not identical. Cases of CLABSI were defined by NNIS criteria and reported normalized to days of device utilization. Data reported as median CLABSI/1,000 catheter-days for each time period among the ICUs included at each time point. The median pre-intervention rate of CLABSI was 2.8/1,000 catheter-days. This decreased to 1.7 during the three-month peri-intervention period, and then to zero during each of the subsequent periods post-intervention. Thus, more than half of the study ICUs reported no cases of CLABSI up to nine months following implementation of their quality improvement strategy. The difference between the pre- and post- intervention rates of CLABSI was statistically significant (p=0.002); multi-level Poisson regression model (time series analysis) demonstrated a significant decrease in CLABSI rates during all observation periods (versus pre-intervention baseline).

Though the reported results are impressive, aspects of the study design and data collection limit the interpretability of its results. Most significantly, the current study focuses on an intervention to prevent CLABSI, but in reality the intervention involved a variety of interventions targeting patient safety and HAIs, which could have contributed to the observed effect in addition to the CLABSI-specific intervention. There were also problems with internal validity. Of the 1,176 ICU-months of data, 25 percent were not available. While a sensitivity analysis was performed and statistical significance was maintained, this is a large amount of data unaccounted for; it might be expected that those centers not reporting data have a higher rate of CLABSI. In addition, as described above, the population of ICUs included in the baseline data is not the same as that studied after implementation of the intervention, introducing the potential for sampling error.

Before-After Studies With Good Internal and External Validity. Only one study met all of our criteria for internal and external validity (Table 6c). ^100^ This study, out of Mexico City, used a combination of education, audit and feedback, and organizational change to encourage behavioral change in a medical-surgical ICU and a neurologic-ICU. The education component consisted of one-hour classes given by an infection control nurse to unit nurses and residents. The investigators performed active surveillance of hand hygiene and catheter care practices; performance feedback consisted of charts posted in the units with unit level data on hand hygiene and invasive device care. Cases of CLABSI were defined by NNIS criteria. The intervention led to a reduction of CLABSI from 46.3 events/1,000 catheter days to 19.5. The authors also demonstrated an improvement in process measures, with optimal hand hygiene improving from 62 percent to 85 percent of observed cases. A major limitation to the study was the high baseline rate of CLABSI, which likely was related to resource availability at the study center. Part of the hand hygiene component of the study involved a hospital-wide switch from non-antiseptic soap to alcohol hand rub or povidone-iodine soap.

Table 6c Articles addressing prevention of central line-associated bloodstream infections: simple before-after studies of good methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Higuera 2005 ^100^ | Mexico | phase 1 6/ 2002 – 8/ 2002; | 9 months | Hand hygiene | QI Strategies: Clinician education, audit and feedback, organizational change | Infection rate prior to intervention: 46.3 CLABSI per 1,000 catheter-days
| Community hospital with residents | phase 2 9/ 2002 – 5/2003 | | | The overall strategy was referred to process control. Targeted processes were hand hygiene and catheter care. | Infection rate after intervention: 19.5 CLABSI per 1,000 catheter-days
| | | | | The study was in Mexico, where routine maintenance catheter was very substandard compared to US practice. | p<0.01
| | | | | The investigators reported using education, process control, performance feedback, and direct observation. The education process was led by an infection control nurse who presented one hour classes to nurses and residents. Performance feedback consisted of charts posted in the units with unit level data on hand hygiene and invasive device care. | Adherence to protocols for hand hygiene:
| | | | | | before intervention: 62%
| | | | | | after intervention: 84.9%
| | | | | | p<0.01
Coopersmith 2002 ^88^ | United States | 7/1999–12/2000 | 18 months | Hand hygiene | QI Strategies: Clinician education, audit and feedback | Infection rate prior to intervention: 10.8 CLABSI per 1,000 catheter-days
| Tertiary care or university hospital | | | | This was an educational intervention targeted primarily at nurses, but also at physicians. The main intervention was a 10-page self study module that every nurse was supposed to complete, along with a pre- and post-test. Specific risk reduction strategies addressed included: handwashing & aseptic technique, methods for detection potential clinical signs & symptoms of local infection, technique for sending catheter-tip culture, routine catheter site care, replacing administration sets & fluids, cleaning & changing injection ports & luer lock caps, how to handle parenteral fluids & multidose vials & procedure for drawing blood cultures. The program also involved verbal inservice raining at staff meetings. Each participant took a pretest before the study module and an identical test upon completion. Fact sheets & posters reinforcing this information were posted throughout the ICU. | Infection rate after intervention: 3.7 CLABSI per 1,000 catheter-days
| | | | | | p<0.01
Coopersmith 2004 ^89^ | United States | 11/2000 – 2/2002 | | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention: 3.4 CLABSI per 1,000 catheter-days
| Tertiary care or university hospital | | | Maximal sterile barrier precautions | Used a literature-based determination of risk factors involved in catheter infections to develop an audit tool to determine whether randomly checked CVCs were properly maintained or whether new insertions were performed under sterile conditions. | Infection rate after intervention: 2.8 CLABSI per 1,000 catheter-days
| | | | Appropriate insertion site selection | After these bedside audits, a behavioral intervention was designed. The intervention was multifactorial. Pictures demonstrating each step of CVC maintenance (aimed at nursing staff) and insertion (aimed at physicians) were placed at every patient's bed, throughout the ICU, and in the manual each resident receives when they rotate through the ICU. Lectures and hands-on demonstrations were given to nurses as part of their annual skills sessions by two of us (C.S.S. and M.E.S.). Lectures were given to the entire resident staff in the departments of surgery and emergency medicine by one of us (C.M.C.), and monthly lectures were given to all residents rotating through the ICU. To assess the success of the behavioral intervention, a second set of bedside audits was performed from November 2001 through February 2002. | p=NS
| | | | | | Adherence to protocols for hand hygiene:
| | | | | | before intervention: 17%
| | | | | | after intervention: 30%
| | | | | | Adherence to appropriate use of maximal sterile barrier precautions:
| | | | | | before intervention: 50%
| | | | | | after intervention: 80%
| | | | | | Adherence to appropriate catheter site selection:
| | | | | | before intervention: 53%
| | | | | | after intervention: 60%
| | | | | | p=NS for all process measures
Warren 2003 ^92^ | United States | 7/1999 – 9/1999 | 2 years | Maximal sterile barrier precautions | QI Strategies: Clinician education, audit and feedback | Infection rate prior to intervention: 4.9 CLABSI per 1,000 catheter-days
| Non-teaching community hospital | | | Appropriate insertion site selection | An educational intervention targeting CLABSI was administered to the clinical staff in a community hospital ICU. | Infection rate after intervention: 2.1 CLABSI per 1,000 catheter-days
| | | | | Nursing and medical staff received a 45 minute lecture on CLABSI, and grand rounds on prevention of CLABSI were presented to the medical staff. Posters and fact sheets were placed in the ICU (the content of these was not specified.) CLABSI rates were reported to all ICU staff. All ICU nurses and physicians had to complete a 10-page self-study module on the prevention of CLABSIs, based on the 1996 HICPAC guidelines. | P<0.01
| | | | | These emphasized maximal sterile barrier precautions, preference for subclavian vein insertion, and guidelines for changing intravenous tubing and administration sets as well as proper technique for blood cultures. | Adherence to appropriate catheter site selection:
| | | | | A pretest and posttest was administered to ICU nurses; the pretest was optional but the posttest was mandatory. All physicians completed the posttest as well. | before intervention: 25%
| | | | | | after intervention: 41%
| | | | | | p<0.01
Warren 2004 ^93^ | United States | 1/ 2002–12/2003 | 2 years | Hand hygiene | QI Strategies: Clinician education, audit and feedback | Infection rate prior to intervention: 9.4 CLABSI per 1,000 catheter-days
| Tertiary care or university hospital | | | Maximal sterile barrier precautions | An educational intervention targeting CLABSI was administered to the clinical staff in a medical ICU at a teaching hospital. The ICU infection control team developed policies and procedures for catheter insertion and site maintenance and developed a strategy for education and implementation. The intervention consisted of the following: Nursing and medical staff received a 45 minute lecture on CLABSI. Posters and fact sheets were placed in the ICU at computer terminals (the content of these was not specified.) All ICU nurses and physicians had to complete a 10-page self-study module on the prevention of CLABSIs, based on the HICPAC guidelines. These emphasized the following: hand hygiene, maximal sterile barrier precautions, avoidance of femoral catheterization, hair removal with clippers, avoidance of antimicrobial ointment at the insertion site, avoidance of changing catheters over guidewires, and guidelines for changing intravenous tubing and administration sets. A pretest and posttest was administered to nurses and physicians. CLABSI rates were reported to all ICU staff. A promotional campaign was also launched with distribution of lapel buttons, fact sheets, posters, and photographic guidelines demonstrating proper insertion and catheter care techniques in prominent locations in the ICU. | Infection rate after intervention: 5.5 CLABSI per 1,000 catheter-days
| | | | Appropriate insertion site selection | | Adherence to appropriate catheter site selection:
| | | | | | before intervention: 26.3%
| | | | | | after intervention: 20.4%
| | | | | | p=NS
Sherertz 2000 ^91^ | United States | 06/1996 and 06/1997 | 6 months | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention: 4.51 CLABSI per 1,000 patient-days
| Tertiary care or university hospital | | | Maximal sterile barrier precautions | PGY-1 residents and medical students underwent a 1/2-day educational session on infection control practices for procedures. Infection control practitioners and an epidemiologist gave a 1-hour lecture on basic infection control principles, including hand washing. The subjects then rotated through a series of 1-hour stations at which they received didactic and hands-on instruction on the following procedures: insertion of central venous and arterial catheters, blood draws through vascular lines, arterial puncture, urinary catheter insertion, lumbar puncture, peripheral venous catheter insertion, and phlebotomy. The hands-on stations used mannequins. | Infection rate after intervention: 2.92 CLABSI per 1,000 patient-days
| | | | | | p<0.01
| | | | | | Adherence to appropriate use of maximal sterile barrier precautions:
| | | | | | before intervention: 44%
| | | | | | after intervention: 65%
| | | | | | p<0.01

A pair of studies carried out in a surgical ICU in a single teaching hospital reported consecutive interventions to reduce CLABSI (Table 6c). The first study ^88^ was an educational program targeted primarily at nurses. The main intervention was a 10-page self-study module that every nurse was expected to complete, along with a pre- and post-test. Unit-level monthly feedback of rates of CLABSI was posted, along with fact sheets and posters. Of note, housestaff did not receive the educational program but were responsible for placing all central lines under supervision of faculty and/or fellows. The educational module covered background information about CLABSI and methods to decrease risk. Of our targeted interventions, optimal hand hygiene and preferred insertion site (subclavian vein optimal, femoral vein only in emergency situations) were specifically addressed. Other techniques to reduce the risk of CLABSI focused on catheter maintenance. This study was not a time series analysis but did report data at multiple time points before and after the intervention. Process measures were not reported. CLABSI rates decreased from 10.8 cases/1,000 catheter-days before the intervention to 3.7 cases/1,000 catheter-days afterward. Subsequent to this study, the same group attempted another intervention to improve adherence to optimal risk reduction behaviors. ^89^ Using a series of bedside audits to define current practice patterns, a multifactorial behavioral intervention was designed. Pictures demonstrating each step of CVC maintenance and insertion were placed at every patient's bed, throughout the ICU, and in the manual each resident receives when they rotate through the ICU. Nurses received lectures and hands-on demonstrations were given to nurses as part of their annual skills sessions. Lectures were given to the entire resident staff, and monthly lectures were given to all residents rotating through the ICU. A second set of bedside audits was performed to assess the success of the behavioral intervention, and CLABSI rates were monitored concurrently with the study. Data was reported at multiple time points before and after the intervention, but a formal time series analysis was not performed. Only ten central line insertions were actually audited after the intervention, limiting the findings regarding behavioral change improvement. The intervention was associated with improved adherence to appropriate hand hygiene (17 percent to 30 percent), maximal sterile barrier precautions (50 percent to 80 percent) and appropriate catheter site selection (53 percent to 60 percent). No other process measures were reported. The rate of CLABSI was 3.4/1,000 catheter-days before the intervention and 2.8/1,000 catheter-days afterward.

Two other studies out of the same integrated healthcare system as the previous two reports used a similar educational intervention to reduce CLABSI (Table 6c). ^92, ^ ^93^ One of these ^92^ was distinguished by the fact that it was in non-teaching, community hospital and included a medical and surgical ICU. For this intervention, all ICU nurses and physicians had to complete a 10-page self-study module on the prevention of CLABSIs; the module was similar to the one described above. ^88^ Nursing and medical staff received a 45 minute lecture on CLABSI, and grand rounds on prevention of CLABSI were presented to the medical staff. Among our targeted interventions, maximal sterile barrier precautions and appropriate catheter site selection were covered in the educational program. Posters and fact sheets were placed in the ICU. A pretest and posttest was administered to ICU nurses; the pretest was optional but the posttest was mandatory. All physicians completed the posttest as well. Rates of CLABSI were 4.9/1,000 catheter-days before the intervention, and 2.1/1,000 catheter-days afterward. Rates of adherence to appropriate catheter site selection improved from 25 percent to 41 percent. All catheters used in this study were impregnated with chlorhexidine and silver-sulfadiazine. The same investigators also reported the results of an intervention in the MICU of a large tertiary academic medical center. ^93^ A multidisciplinary committee made local modifications to the educational module already described; ^88^ the program was administered to all nurses and physicians working on the unit. In addition, a promotional campaign was carried out that included distribution of lapel buttons, fact sheets, posters; photographic guidelines demonstrating proper insertion and catheter care techniques were placed in prominent locations in the ICU. Feedback was provided in the form of monthly reports of CLABSI rates, which were posted in multiple locations throughout the unit. Data were reported from multiple time points before and after the intervention, but a formal time-series analysis was not performed. CLABSI rate improved from 9.4 cases/1,000 catheter-days before the intervention to 5.5 cases/1,000 catheter-days after the procedure. The education did not change provider behaviors regarding catheter site selection; 26 percent of insertion sites were deemed appropriate before the intervention compared to 20 percent afterward. Notably, there was a QI program targeting Ventilator-Associated Pneumonia running concurrently with this study. There could have been significant crossover in effect between the interventions, making the results less reliable.

This study, like the three others from this healthcare system, ^88, ^ ^89, ^ ^93^ is subject to a certain amount of bias due to the fact that there was intense system-wide effort to reduce overall health-care associated infections, a fact which by itself might influence the findings.

Another study using an educational intervention targeted medical students and interns (Table 6c). ^91^ As part of a half-day course on performing a variety of medical procedures, interns and students received a one-hour lecture on basic infection control principles, including hand washing and appropriate use of barrier garments. Attendees then went through a series of one-hour workstations, one of which was dedicated to proper insertion of arterial and central venous catheters. This module specifically addressed hand hygiene and maximal sterile barrier precautions. Data on the effectiveness of the intervention was collected in six medical-surgical ICUs and their associated step-down units and was reported at multiple time points. Cases were defined by CDC criteria. Use of full-sized drapes was assessed by measuring the surrogate marker of purchasing records and improved from 44 percent to 65 percent after the intervention. Rate of CLABSI decreased from 4.51 to 2.92 cases/1,000 patient-days. Rates of infection normalized to catheter days were estimated, but not actually measured.

Before-After Studies With Moderate Iinternal and External Validity. A study from Korea used a combination of education and intensive surveillance and active feedback to reduce the rate of CLABSI (Table 6d). ^103^ The infection control committee held “Infection Control Week”, during which new guidelines for central line care, aseptic technique, and hand washing were distributed. Details of the educational program were not provided. Infection control staff conducted daily surveillance of all central lines to monitor for appropriate catheter care, including hand washing, occlusive dressing, and aseptic application of povidone iodine, and gave direct feedback if protocols were violated. Rates of CLABSI decreased from 4.2/1,000 catheter-days before the intervention to 1.3/1,000 catheter-days afterward, but these results are non-significant due to the very small size of the study. The data reflect only six actual cases of CLABSI.

Table 6d Articles addressing prevention of central line-associated bloodstream infections: simple before-after studies of moderate methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Yoo 2001 ^103^ | Korea | 10/1998 – 1/1999 | 3.5 months | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention: 4.2 CLABSI per 1,000 catheter-days
| Tertiary care or university hospital | | | Maximal sterile barrier precautions | An intensive surveillance and catheter care education program was instituted at an ICU in Korea. The infection control committee held “Infection Control Week”, during which new guidelines for central line care, aseptic technique, and hand washing were distributed. Infection control staff conducted daily surveillance of all central lines to monitor for appropriate catheter care, including hand washing, occlusive dressing, and aseptic application of povidone iodine. Infection control staff gave direct feedback if protocols were violated, and recommended catheter removal and blood cultures if the patient has symptoms of CLABSI. | Infection rate after intervention: 1.3 CLABSI per 1,000 catheter-days
| | | | | | p=NS
Frankel, 2005 ^97^ | United States | 5/2001 – 5/2002 | 2 years | Maximal sterile barrier precautions | QI Strategies: Clinician education, audit and feedback, organizational change | CLABSI rate:
| Tertiary care or university hospital | | | | The study used Six Sigma methods to reduce CLABSI in a surgical ICU. Trained facilitators met with clinical stakeholders to instruct them in Six Sigma methodology, which focus on minimizing variability and improving efficiency. The stakeholder groups (SICU staff and hospital epidemiologists) determined risk factors for CLABSI and formulated a stepwise intervention. This consisted of a standardized video tutorial for residents on insertion site practices, development of new policies for changing catheters over wires, development of a standardized kit with insertion materials, new policies for catheter care, and inserting antibiotic-coated catheters in patients expected to be ventilated for >4 days. Also, all central lines were inserted under direct supervision of an attending physician except in an emergency. Feedback on infection rates was posted in the ICU. | Infection rate before intervention: 10.5/1,000 catheter-days
| | | | | | After intervention: 1.7/1,000 catheter-days
| | | | | | p<0.001

A study conducted in a surgical intensive care unit of a tertiary care hospital used corporate “Six Sigma” methodology, which focuses on minimizing variability and improving efficiency, to target CLABSI (Table 6d). ^97^ A multidisciplinary team consisting of SICU staff and hospital epidemiologists developed an educational module for residents and guidelines for catheter care and changing catheters over guidewires. Additionally, attending staff were required to supervise non-emergent catheter insertion, and infection rates were fed back to SICU staff. The study had good external validity and reported data at more than one time point before and after the intervention, but did not measure adherence. CLABSI were significantly reduced, however, the results of the QI intervention were likely significantly confounded by the simultaneous introduction of antibiotic-coated catheters ^42^ for patients requiring long-term (greater than four days) mechanical ventilation; these had not been used in the baseline phase of the study.

Before-After Studies With Poor Internal and External Validity. We identified seven simple before-after studies with poor internal and external validity which are listed in Table 6e. One of these ^60^ will be discussed under the section addressing prevention of VAP.

## Ventilator-Associated Pneumonia

### Included Studies: Settings, Goals, and Target Populations

Our search strategy identified a total of 12 articles meeting our inclusion criteria that assessed prevention of ventilator-associated pneumonia (Tables 8a–8c). Of these, ten specifically targeted VAP, and two ^60, ^ ^62^ addressed prevention of multiple types of HAIs including VAP. Studies were mostly performed in the United States. ^107^ – ^114^ Ten studies took place in a single institution and two ^107, ^ ^113^ in multiple hospitals. Studies primarily evaluated prevention of VAP in adult medical-surgical ICUs; ^60, ^ ^107^ – ^111, ^ ^114^ – ^116^ results were reported separately for medical and surgical patients in two studies. ^109, ^ ^110^ One study ^62^ was conducted in a neonatal ICU and one study ^107^ evaluated an intervention conducted in both adult and pediatric ICUs. Six ^107, ^ ^109, ^ ^110, ^ ^113, ^ ^115, ^ ^116^ of the nine studies reporting the study period were conducted within the last decade. The follow-up periods ranged from six months to 2.5 years, with a median of one year. The median baseline rate of VAP was 19.5 per 1,000 ventilator-days, but varied widely across the studies (range 5.5 – 113 episodes/1,000 ventilator-days.) By comparison, the median rate of VAP in medical-surgical ICUs at NNIS hospitals in 2003 was 4.6 per 1,000 ventilator days (interquartile range, 2.6 – 7.2) for major teaching hospitals and 5.6 per 1,000 ventilator-days at all other hospitals (IQR 2.9 – 6.7). ^14^

Table 8a Articles addressing prevention of ventilator-associated pneumonia: simple before-after studies of good methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Babcock 2004 ^107^ | United States | 1/2000–1/2001 | 18 months | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention: 8.75 VAP per 1,000 ventilator-days
| Multiple hospitals of different types (1 adult tertiary care, 1 pediatric tertiary care, 2 community hospitals) | | | Head of bed elevation above 30 degrees | All nurses and respiratory care practitioners working in the ICU at 4 hospitals received a self-study module on preventing VAP, accompanied by pre- and post-test examinations. The self-study module contained information on the epidemiology, risk factors, clinical and economic consequences, etiology, definitions, diagnostic procedures, and risk reduction methods for VAP. All participants had to complete the module and score >80% on the post-test. The module was mandated for nurses at 3 of the 4 hospitals. The key messages were also used in posters and fact sheets in the ICU. Nursing and respiratory care staff also underwent in-service training (at scheduled training times and staff meetings). At the adult teaching hospital, respiratory care practitioners received 2 1-hr lectures on VAP. | Infection rate after intervention: 4.74 VAP per 1,000 ventilator-days
| | | | Daily interruption of sedation | | p<0.01
Zack 2002 ^110^ | United States | 10/2000 – 9/2001 | 1 year | Head of bed elevation above 30 degrees | QI Strategies: Clinician education | Infection rate prior to intervention: 12.6 VAP per 1,000 ventilator days
| Tertiary care or university hospital | | | | ICU nurses and respiratory therapists received an educational intervention targeting VAP prevention. Participants completed a 10-page self-study module with information on the epidemiology, risk factors, etiology, diagnosis, consequences, and prevention of VAP. The specific preventive interventions included: head of bed elevation >30 degrees, encouraging orotracheal intubation and orogastric tubes, early extubation and use of NIV when needed, provision of adequate sedation, avoidance of gastric over distention, provision of oral hygiene, avoiding overuse of antibiotics, and appropriate disposal of ventilator circuit condensates. Participants were required to complete a 20 question pretest and posttest before and after completing the educational module. | Infection rate after intervention: 5.7 VAP per 1,000 ventilator days
| | | | | Infection control practitioners also conducted in-services at scheduled meeting times, and respiratory therapists also received two 1-hour lectures on VAP. The RCPs completed the posttest again 6 months after completing the self-study module. The module was mandatory for all RCPs, but was not mandatory for nurses. Individuals who scored <80% on the posttest were required to repeat the module. Additionally, fact sheets and posters were posted in the ICU. | p<0.01
Helman 2003 ^114^ | United States | Not reported | 6 months | Head of bed elevation above 30 degrees | QI Strategies: Clinician education, clinician reminder | Compliance to head of bed elevation > 30 degrees:
| Tertiary care or university hospital | | | | An intervention to improve compliance with elevation of the head of the bed above 30 degrees was carried out at a teaching hospital. The first intervention consisted of adding an order to the standardized admission order set to keep the HOB elevated. The second intervention (which took place 2 months after the first) was an educational intervention targeting all physicians and nurses. The educational session was a group discussion based on a prepared poster on HOB elevation. The session was mandatory for all physicians. | Compliance before intervention: 26%
| | | | | | After intervention: 88%
| | | | | | p<0.01

Table 8c Articles addressing prevention of ventilator-associated pneumonia: simple before-after studies of poor methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
*Berg 1995 ^60^ | Guatemala | Not specified | 1 year | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention: 113 VAP per 1,000 ventilator-days
| Tertiary care or university hospital | | | | A multifaceted intervention was used to target nosocomial infections in the ICU, with both general measures and measures targeting VAP and CAUTI. Nurses and physicians received 15 educational sessions on aseptic technique, stressing proper hand washing. The educational sessions used lectures and demonstrations, and individual clinicians also received positive and negative feedback and reminder signs at the bedside. The VAP intervention targeted proper use of sterile rinse water and improvement in aseptic technique for suctioning. Providers received more than 15 interactive conferences on the detection, management, and prevention of nosocomial pneumonia; these included lectures, demonstrations, individual instruction and feedback, and contests. The CAUTI intervention consisted of changing open urinary drainage systems to closed systems (aseptic catheter care), with an educational session on the new catheter. The intervention did not specifically target surgical site infections, but those outcomes are reported. | Infection rate after intervention: 40 VAP per 1,000 ventilator-days
| | | | | | p<0.01
| | | | | | Adherence to protocols for hand hygiene:
| | | | | | Before intervention: 5%
| | | | | | After intervention: 63%
| | | | | | p<0.01
Joiner 1996 ^108^ | United States | 5/1992–9/1992 | 2.5 years | Hand hygiene | QI Strategies: Clinician education, organizational change | Infection rate prior to intervention: 26 VAP per 1,000 ventilator-days
| Tertiary care or university hospital | | | Head of bed elevation above 30 degrees | A QI team (including physicians, respiratory therapists, ICU nurses, infection control practitioners, and quality managers) brainstormed to develop practice guidelines for preventing VAP. These guidelines were developed into a standardized protocol and presented to staff in a presentation and at staff meetings. VAP rates were reviewed monthly and shared with departments. A continuous quality improvement method was used to review data and revise the intervention as needed. | Infection rate after intervention: 16 VAP per 1,000 ventilator-days
| | | | | | p value not reported
Resar 2005 ^113^ | United States | 2002-2004 | 6 months | Head of bed elevation above 30 degrees | QI Strategies: Clinician education, organizational change | For medical-surgical ICUs
| Multiple hospitals of different types | | | Daily interruption of sedation | Report of 61 hospitals who participated in the IHI IMPACT network. Teams of critical care physicians from each organization attended collaborative meetings, beginning with a half-day introductory course on change concepts. | Infection rate prior to intervention: 5.5 VAP per 1,000 ventilator days
| | | | | The “ventilator bundle”, consisting of PUD prophylaxis, DVT prophylaxis, HOB elevation, and sedation vacation, were the key concepts targeted for implementation, and the collaborative meetings sere devoted to implementation methods. | Infection rate after intervention: 2.7 VAP per 1,000 ventilator days
| | | | | ICU's implemented multidisciplinary rounds and daily patient goals at a minimum. | p value not reported
Nicotra 1996 ^112^ | United States | 12/1991–5/1994 | 18 months | Hand hygiene | QI Strategies: Clinician education, organizational change | Infection rate prior to intervention: 22 VAP per 1,000 ventilator days
| Single hospital, type not specified | | | | A continuous quality improvement style intervention was implemented to reduce VAP. A multidisciplinary task force developed a process improvement plan consisting of implementation of a closed suction device, and changes in cleaning and maintenance of ventilator units. A survey was performed which revealed a lack of knowledge among nurses about preventive interventions for VAP. Thus, an educational program on VAP was conducted for nurses, consisting of information about hand washing, suctioning, other preventive measures (such as patient mobilization, respiratory care, maintaining hydration, assessing nutritional status, and review of drugs for stress ulceration), as well as general infection control measures. | Infection rate after intervention: 8.3 VAP per 1,000 ventilator days
| | | | | | p values not reported
**Lam 2004 ^62^ | Hong Kong | Not specified | 10 months | Hand hygiene | QI Strategies: Clinician reminder; organizational change | Infection rate prior to intervention: 16.9 VAP per 1,000 ventilator days
| Tertiary care or university hospital | | | | Nurses and physicians received an educational program targeting hand hygiene. A hand hygiene protocol was implemented as part of the orientation for new staff. Face-to-face educational seminars were conducted for nurses and physicians where solutions to overcome obstacles to hand washing were provided; 2 sessions were provided for physicians and 10 for nurses. A task-oriented analysis was performed to identify strategies for hand washing during complex procedures. Demonstrations were conducted at regular intervals, and reminder pictures were posted at each hand washing basin. | Infection rate after intervention: 6.4 VAP per 1,000 ventilator days
| | | | | | p=NS
| | | | | | Adherence to protocols for hand hygiene:
| | | | | | before intervention: 40%
| | | | | | after intervention: 53%
| | | | | | p<0.01

* This study addresses prevention of surgical site infections, central line-associated bloodstream infections, ventilator-associated pneumonia and catheter-associated urinary tract infections.

** This study addresses prevention of central line-associated bloodstream infections and ventilator-associated pneumonia.

### Preventive Interventions and Outcomes Measured

We identified hand hygiene, semirecumbent patient positioning, and daily interruption of sedation and assessment of readiness to wean as target preventive interventions for this review. All included studies explicitly promoted hand hygiene, and eight ^107^ – ^111, ^ ^113^ – ^115^ promoted semirecumbent patient positioning; two studies ^107, ^ ^113^ promoted daily assessment of readiness to wean from the ventilator. Overall, many other preventive interventions were used in the studies (Table 9).

Table 9 Other preventive interventions used in studies addressing ventilator-associated pneumonia

Author | Continuous aspiration of subglottic secretions | Avoidance of scheduled ventilator circuit changes | Use of heat and moisture exchangers | Universal peptic ulcer disease prophylaxis | Aseptic suctioning technique | Aseptic drainage of ventilator circuit condensate | Oral care | Other interventions
Babcock 2004 ^107^ | o | • | •* | o | • | • | • | Avoid gastric overdistension; provide immunizations for influenza and pneumococcus
Berg 1995 ^60^ | o | o | o | o | • | • | o
Joiner 1996 ^108^ | o | o | o | o | • | • | •
Lai 2003 ^109^ | o | o | o | o | o | o | o | Replacement of stopcocks with enteral valves for nasogastric feeding tubes; changing of in-line suction catheters as needed instead of every 24 hours
Lam 2004 ^62^ | o | o | o | o | o | o | o
Salahuddin 2004 ^115^ | o | o | • | o | o | o | • | Monitor gastric residual volume; use noninvasive positive pressure ventilation (NIPPV) to avoid intubation and facilitate extubation; use orogastric tubes
Zack 2002 ^110^ | o | o | o | o | o | • | • | Use orogastric tubes; avoid gastric overdistension; use NIPPV when possible; provide immunizations for influenza and pneumococcus
Kelleghan 1993 ^111^ | o | o | • | o | • | • | • | Avoid gastric overdistension
Nicotra 1996 ^112^ | o | o | o | o | ▴* | ▴* | o
Resar 2005 ^113^ | o | o | o | • | o | o | o | Multidisciplinary rounds in ICU; daily patient goals; DVT prophylaxis
Rosenthal 2006 ^116^ | o | o | o | o | • | • | o | Percussion and postural drainage to stimulate coughing

•: Yes o: No ▴: Unclear

* - Babcock 2004 ^107^ : heat and moisture exchangers contraindicated in patients with “excessive secretions”, but otherwise recommended

* - Nicotra 1996 ^112^ : nurses “received information” on suctioning and handling of ventilator tubing, but does not specifically state that aseptic technique was discussed

Aseptic drainage of ventilator circuit condensate, appropriate suctioning technique, and provision of oral care (including chlorhexidine mouthwash) were frequently incorporated into preventive strategies. Some studies made use of interventions that remain controversial, such as universal peptic ulcer disease prophylaxis ^113^ or use of heat and moisture exchangers. ^107, ^ ^111, ^ ^115^

All studies focused specifically on prevention of VAP and instituted preventive interventions targeting it, with the exception of one study ^62^ which implemented an intervention targeting hand hygiene and measured its effects on multiple HAIs in an ICU.

### Quality Improvement Strategies

All studies primarily used educational interventions targeted at providers (Tables 8a–8c). Nurses and physicians were specifically targeted in all 12 studies, and respiratory therapists in six; ^107, ^ ^108, ^ ^110, ^ ^111, ^ ^115, ^ ^116^ three studies ^60, ^ ^113, ^ ^116^ targeted all clinical staff in the ICU. Most studies combined use of written materials and lectures, with six studies ^60, ^ ^107, ^ ^108, ^ ^111, ^ ^113, ^ ^115^ using an explicit clinical guideline for preventive care. Three studies ^109, ^ ^111, ^ ^116^ used audit and feedback of infection rates to ICU staff or ICU managers, and two ^108, ^ ^112^ used a continuous quality improvement intervention. One ^113^ incorporated other organizational change strategies (establishment of multidisciplinary team rounds daily and daily assessment of patient goals on rounds). No other QI strategies were used in any included study.

### Methodologic Quality of Included Studies

The methodologic quality of studies was generally poor, as all used a quasi-experimental, before-after design (Tables 8a–8c). With this limitation, the external validity of studies was generally good, as all but one ^110^ used CDC/NNIS definitions to diagnose VAP and all reported infection rates adjusted for device utilization (Table 10). However, the studies exhibited limitations with internal validity. Only five studies ^107, ^ ^108, ^ ^110, ^ ^111, ^ ^115^ reported infection rates at more than one time point before and after the intervention, and only two studies ^107, ^ ^109^ specifically stated that no other QI interventions took place contemporaneously. Three studies ^60, ^ ^62, ^ ^111^ reported both infection rates and process measures (in each case, compliance with hand hygiene protocols), and one study ^114^ measured only process measures (adherence to semirecumbent patient positioning). Because of the lack of controlled studies, variety of preventive interventions used, and the wide differences in baseline rates of VAP, we did not attempt quantitative synthesis of the results. Given the generally poor methodologic quality of the results and the homogeneity of QI strategies used, we will summarize the studies that we considered to have generally stronger internal and external validity.

Table 10 Quality criteria for simple before-after studies addressing ventilator-associated pneumonia

| Internal Validity | | | External Validity
Author | Did the study report data on more than one time point before and after the intervention? | If the study reported infection rates, did it also report process measurements? | Was the intervention performed independent of other QI efforts or other changes? | Did the study use NNIS/CDC methods for measuring infections? | Did the study report infection rates in terms of device utilization?
Babcock 2004 ^107^ | • | o | • | • | •
Berg 1995 ^60^ | o | • | ▴ | • | •
Helman, 2003 ^114^ | o | Not applicable | • | Not applicable | Not applicable
Joiner 1996 ^108^ | • | o | ▴ | • | •
Lai 2003 ^109^ | o | o | • | • | •
Lam 2004 ^62^ | o | • | ▴ | • | •
Salahuddin 2004 ^115^ | • | o | ▴ | • | •
Zack 2002 ^110^ | • | o | ▴ | o* | •
Kelleghan 1993 ^111^ | • | • | ▴ | • | •
Nicotra 1996 ^112^ | o | o | ▴ | • | •
Resar 2005 ^113^ | o | o | ▴ | ▴ ^†^ | •
Rosenthal 2006 ^116^ | o | o | ▴ | • | •

•: Yes

o: No

▴: Unclear

* - The study used the American College of Chest Physicians criteria for diagnosis of VAP.

† - 84% of participating hospitals used CDC/NNIS definitions for measuring VAP rates. The methods used by the remaining hospitals were not specified.

Before-After Studies With Good Internal and External Validity. Two studies ^107, ^ ^110^ conducted within the same integrated health system used an educational intervention centered around a self-study module for physicians, nurses and respiratory therapists (Table 8a). The paper-based module consisted of a comprehensive tutorial on the epidemiology, risk factors, diagnosis, and prevention of VAP, accompanied by a 20-question pretest and posttest. The preventive interventions discussed included semirecumbent patient positioning and hand hygiene. Completion of the module and passing the post-test was required for all respiratory care practitioners (RCPs) in one study ^110^ and was strongly encouraged for nurses in both studies. Of note, both of these studies documented the reach of the intervention by documenting the percentage of nurses and RCPs completing the module. These studies were both of similar methodologic quality, with good external validity; both studies also reported data at more than three time points before and after the intervention, but did not conduct a formal time series statistical analysis. One study ^110^ used the American College of Chest Physicians diagnostic criteria for VAP rather than the NNIS definition, but as the ACCP criteria are slightly more stringent, it is unlikely that this affects the applicability of the results significantly. Results revealed a statistically significant decrease in the incidence of VAP in three of the four hospitals evaluated in the two studies (one community hospital, one adult tertiary care hospital and one pediatric tertiary care hospital). Another community hospital failed to note a decrease in VAP rates but also had the lowest rate of completion of the module among RCPs. The baseline rates of VAP were lower than other included studies (8.75/1,000 ventilator days and 12.6/1,000 ventilator days respectively), but still above the pooled NNIS median during that time period.

An educational intervention targeting semirecumbent patient positioning was carried out in another study at a tertiary care hospital. ^114^ The study used a multifaceted intervention using clinician reminders (incorporating an order for semirecumbent positioning into standardized order sets) and interactive education for physicians and nurses; adherence was measured at baseline and at two and six months after the intervention. As VAP rate was not measured, we could not fully apply our study quality criteria. The study achieved a statistically significant improvement in the proportion of patients with the head of the bed elevated above 30 degrees (from 26 percent pre-intervention to 88 percent post-intervention.)

Before-After Studies With Moderate Internal and External Validity. A continuous quality improvement intervention was conducted in a study ^111^ in a community hospital, focusing on hand hygiene and semirecumbent patient positioning. The study also used audit and feedback of VAP rates to practitioners (Table 8b). Although this study had reasonable internal validity, the applicability of its results is questionable. The study was conducted in 1989, and many aspects of ICU care have changed since then, as have VAP diagnostic criteria. Nevertheless, the study did document improvement in hand hygiene after the intervention as well as a reduction in VAP rates.

Table 8b Articles addressing prevention of ventilator-associated pneumonia: simple before-after studies of moderate methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Kelleghan 1993 ^111^ | United States | Spring 1989-Spring 1990 | 18 months. | Hand hygiene | QI Strategies: Clinician education, audit and feedback, regulatory incentives | Infection rate prior to intervention: 17 VAP per 1,000 ventilator days
| Community hospital | | | Head of bed elevation above 30 degrees | A CQI-based intervention was performed by a multidisciplinary Nosocomial Pneumonia Prevention Team consisting of members from nursing, infection control, physicians, and respiratory care. The team developed a prevention guideline for nurses and RTs consisting of hand washing, HOB elevation, ventilator care (scheduled circuit changes, suction catheter changes etc), neurologic assessment, and oral care. The guideline was presented to RNs and RTs in educational meetings including feedback on infection rates and demonstrations using equipment and mannequins. | Infection rate after intervention: 5 VAP per 1,000 ventilator days
| | | | | Nurses received continuing education credit for attendance. Note, new equipment (heat and moisture exchangers) were also introduced after the educational campaign was completed. | Adherence to protocols for hand hygiene:
| | | | | | before intervention: 40%
| | | | | | after intervention: 58%
| | | | | | p values not reported
Lai 2003 ^109^ | United States | Second quarter of 1997 - First quarter of 1998 | 18 months | Head of bed elevation above 30 degrees | QI Strategies: Clinician education, audit and feedback | Infection rate prior to intervention: Surgical ICU: 45.1 VAP per 1,000 ventilator-days; Medical ICU: 22.4 VAP per 100 ventilator-days
| Tertiary care or university hospital | | | | A team consisting of the hospital epidemiologist, infection control practitioners, ICU directors and ICU managers developed and implemented preventive interventions. The interventions consisted of elevation of the head of the bed and changes in maintenance of nasogastric feeding tubes and prolongation of the time between changing of inline suction catheters. | Infection rate after intervention:
| | | | | Infection rates were presented quarterly to ICU staff at staff meetings and via charts. | Surgical ICU: 27.9 VAP per 100 ventilator-days; Medical ICU: 11.6 VAP per 100 ventilator-days
| | | | | | p values not supplied
Rosenthal 2006 ^116^ | Argentina | 11/2001–12/2002 | 1 year | Hand hygiene | QI Strategies: Clinician education, audit and feedback | Infection rate prior to intervention: 51.28 VAP per 1,000 ventilator days
| Two non-teaching community hospitals | | | | All clinical staff received 1-hour educational sessions on VAP, discussing the epidemiology and pathogenesis, hand hygiene, proper handling of secretions and catheters, and percussion and postural drainage to stimulate coughing. Feedback of VAP rates was provided to ICU staff monthly at infection control meetings, and to ICU administrators. | Infection rate after intervention: 35.52 VAP per 1,000 ventilator days
| | | | | | p<0.01
Salahuddin 2004 ^115^ | Pakistan | 1/2003–12/2003 | 1 year | Hand hygiene | QI Strategies: Clinician education | Infection rate prior to intervention: 13.2 VAP per 1,000 ventilator days
| Tertiary care or university hospital | | | Head of bed elevation above 30 degrees | A clinical guideline was developed for VAP prevention by physicians and the ICU head nurse. The elements of the guideline were: hand washing, protective gown/glove use for specific groups of patients, head of bed elevation >30 degrees, avoiding gastric over distension, use of NIPPV to avoid intubations and facilitate early extubation, use of OG tubes instead of NG tubes, provide adequate sedation, prevent accidental extubation, perform oral hygiene with chlorhexidine, and removal of inline humidifiers from ventilators. An educational program, based on the guideline, was administered to ICU nursing and junior medical staff through weekly lectures, departmental presentations,“reinforcement at the bedside and visual aids posted in the ICU.” | Infection rate after intervention: 6.5 VAP per 1,000 ventilator days
| | | | | | p=0.02

A staggered educational intervention consisting of semirecumbent patient positioning and interventions targeting suctioning technique, ^109^ along with audit and feedback of infection rates to staff, was also successful in reducing VAP rates in both a surgical and medical ICU in a tertiary care hospital (Table 8b). The study also conducted a cost analysis showing that nearly $350,000 was saved as a result of preventing a total of 66 episodes of VAP. However, only one time point of data was provided pre-intervention, limiting the internal validity of the results.

A study conducted in two Argentinean ICUs ^116^ used a brief educational intervention consisting of a 1-hour lecture to all ICU staff, along with implementation of a nosocomial infection surveillance system using NNIS methodology. The study also had a markedly high rate of VAP (51.3 episodes/1,000 ventilator-days) and did document a significant reduction.

A prevention guideline recommending hand hygiene and semirecumbent patient positioning was disseminated in a study from Pakistan ^115^ that used a focused educational intervention, but without use of a self-study module. This study was of good internal validity, also documenting infection rates at three time points before and after the intervention. The intervention was associated with a 51 percent relative decrease in the incidence of VAP, but the authors noted that an outbreak of Acinetobacter VAP took place immediately before implementation of the intervention. Thus, part of the observed results may have represented regression to the mean rather than a true intervention effect.

Before-After Studies With Poor Internal and External Validity. Five studies met all our inclusion criteria, but had methodologic flaws that seriously limited the internal or external validity of the results (Table 8c). ^60, ^ ^62, ^ ^108, ^ ^113, ^ ^116^ One study ^108^ incorporated scheduled changes of the ventilator circuit as one of the main preventive interventions; this is explicitly discouraged by both the ATS/IDSA and CDC guidelines. Another ^113^ restricted reporting of infection rates to studies that documented improvement in process outcomes. One study ^112^ provided virtually no details on the QI intervention that was conducted. Finally, a study conducted in an ICU in Guatemala combined an educational intervention on hand hygiene with an intensive educational intervention focusing on aseptic suctioning technique. ^60^ The hospital had no formal infection control mechanisms in place prior to the study and had a remarkably high baseline rate of VAP (113/1,000 ventilator-days). Although the rate was reduced substantially, it remained high (40/1,000 ventilator-days) post-intervention. The study did document markedly improved compliance with hand hygiene. The rates of other HAIs (CAUTI, SSI, and CLABSI) did not change.

## Catheter-Associated Urinary Tract Infection

### Included Studies: Settings, Goals, and Target Populations

Our search identified ten articles that addressed prevention of catheter-associated urinary tract infections (Tables 11a–11e). All explicitly sought to reduce the incidence of CAUTI and/or reduce unnecessary urethral catheterization, with the exception of one study (discussed previously ^60^ in the VAP section) that introduced a hand hygiene intervention and reported its effects on VAP, SSI, and CAUTI. Six of ten included studies ^60, ^ ^61, ^ ^117^ – ^120^ were performed outside the U.S. An equal number of studies targeted CAUTI in ICU patients ^60, ^ ^61, ^ ^119^ – ^121^ and general inpatient ward patients. ^117, ^ ^118, ^ ^122^ – ^124^ All studies targeted adult patients. The baseline rate of CAUTI varied from 10.3 to 36 UTI per 1,000 urethral catheter-days (median, 15.1/1,000 catheter-days). By comparison, the NNIS mean for medical-surgical ICUs in 2003 was 3.3 CAUTI per 1,000 catheter-days (IQR 2.1 – 5.2/1,000 catheter-days) in major teaching hospitals and 3.1 (IQR 1.6 – 5.1) per 1,000 catheter-days in non-teaching hospitals.

Table 11a Articles addressing prevention of catheter-associated urinary tract infections (studies addressing reduction in catheter usage): controlled studies

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Cornia 2003 ^123^ | United States | 11/2000 – 3/2001 | 8 weeks | Removal of unnecessary catheters | QI Strategies: Clinician reminder | Mean duration indwelling catheter in place (first study period):
| Tertiary care or university hospital | | | | Resident physicians were required to enter an order for urinary catheter placement in the hospital's computerized physician order entry (CPOE) system. The computer study order required that an indication be selected for placement, provided routine catheter care instructions, and had a default stop date of 72 hours after placement. A reminder appeared after 72 hours asking the ordering physician to renew or discontinue the catheter order. Physicians had the option of using the computer order, a written order, or no order. | Control: 6.63 days
| | | | | | Intervention: 4.72 days
| | | | | | p<0.01
| | | | | | Mean duration indwelling catheter in place (second study period):
| | | | | | Control group: 8.53days
| | | | | | Intervention group: 5.56 days
| | | | | | p<0.01
Saint 2005 ^124^ | United States | 6/2001–12/ 2002 | 8 months | Removal of unnecessary catheters | QI Strategies: Clinician reminder | Rate of use of indwelling urinary catheters
| Tertiary care or university hospital | | | | A printed reminder was attached to the physician notes in the charts of patients who had a urinary catheter in place for >48 hours. The reminder required the physician to either order removal of the catheter or check a specific reason for continuing the catheter (among 6 reasons that were specified.) Initially, the reminders were frequently ignored, so plastic tape flags asking physicians to “sign here” and alphanumeric reminder paging were used to increase compliance with the reminder. | Control:
| | | | | | prior to intervention: 27.8% of patients
| | | | | | after intervention: 32.0% of patients
| | | | | | Intervention: before intervention: 14.4% of patients after intervention: 13.3% of patients
| | | | | | p value not reported

Table 11b Articles addressing prevention of catheter-associated urinary tract infections (studies addressing reduction in catheter usage): simple before-after studies of moderate methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
*Greco 1991 ^61^ | Italy | 12/1988 – 6/1989 | 19 months | Aseptic insertion and catheter care | QI Strategies: Clinician education, audit and feedback, clinician reminder | UTI associated with indwelling catheters:
| Multiple hospitals of different types | | | | Series of meetings with surgeons and nurses from each of participating wards. Data on infection incidence and practices were discussed and best practices reviewed including: appropriate use of perioperative antibiotics (pre-operative, limited duration, appropriate selection), avoidance of preoperative shaving, closed drainage of urinary catheters and surgical drains, implementation of respiratory exercises, use of hygienic measures for Urinary catheters. | Infection rate prior to intervention: 12.9 per 100 urinary catheters
| | | | | | Infection rate after intervention: 11.9 per 100 urinary catheters
| | | | | | p=NS
Danchaivijitr, 1992 ^118^ | Thailand | Not specified | Not specified | Reduction in placement of catheters | QI Strategies: Clinician reminder | Rate of use of indwelling catheters:
| Multiple hospitals of different types | | | | An “indication sheet” was attached to charts. This sheet listed indications for urethral catheterization and was to be filled out by prescribers. It listed 5 specific indications for catheterization (urinary retention, recording hourly urine output, injury to urethra, irrigation of urinary bladder, and “other”); prescribers were to order catheterization only for one of the specific indications. | before intervention: 8.1% of patients
| | | | | | after intervention: 8.6% of patients
| | | | | | p=NS
Huang 2004 ^119^ | Taiwan | 1/2002–12/2002 | 1 year | Removal of unnecessary catheters | QI Strategies: Clinician reminder | Rate of symptomatic urinary tract infection:
| Tertiary care or university hospital | | | | Nursing staff reminded physicians daily to remove urinary catheters if they were no longer needed five days after being inserted. Catheters were placed or removed at the discretion of the physicians in charge | Infection rate prior to intervention: 11.5 per 1,000 catheter-days
| | | | | | Infection rate after intervention: 8.3 per 1,000 catheter-days
| | | | | | p<0.01
| | | | | | Mean duration indwelling catheter in place:
| | | | | | before intervention: 7.0 days
| | | | | | after intervention: 4.6 days
| | | | | | p<0.01
Dumigan 1998 ^121^ | United States | 5/1996–10/1997 | 18 months | Aseptic insertion and catheter care | QI strategies: Clinician education, organizational change | Rate of symptomatic urinary tract infection:
| Community hospital with residents | | | Removal of unnecessary catheters | Multidisciplinary effort used to reduce CAUTI was implemented according to plan-do-check-act methodology. Multidisciplinary committee (including physicians, nurses, and infection control practitioners) created protocols for physicians, nurses, and the laboratory regarding urinary catheter use and procedures. Physicians were targeted by creating a list of indications for catheter use. Nurses received a video presentation on insertion technique and standardized protocols for catheter care. Indications for removing catheters were developed, and nurses were allowed to remove catheters without a physician's order if they were present. After protocols were developed, an extensive educational campaign was used to disseminate them to nurses, housestaff, and attending physicians. Note: an audit/feedback intervention (feedback of CAUTI infection rates) was in place prior to the intervention. | Infection rate prior to intervention (CAUTI per 1,000 catheter-days) SICU: 10.3, MICU, 15.8, CICU, 15.1
| | | | | | Infection rate after intervention: SICU: 8.6; MICU: 11.2; CICU: 8.3.
| | | | | | p value 0.03 for CICU only; NS for others
Topal 2005 ^122^ | United States | Fall 2002–Spring 2003 | 18 months | Reduction in placement of catheters / Removal of unnecessary catheters | QI strategies: Clinician education, clinician reminder, organizational change | Rate of symptomatic urinary tract infection:
| Tertiary care or university hospital | | | | Three interventions were implemented to reduce urinary catheter use and CAUTI. Physicians were prompted (using the computerized physician order entry system) to discontinue catheters, maintain catheters for 48 hours, or maintain catheters chronically each time a catheter was placed in the ED. Physician and nursing staff were educated on lower-risk alternatives to indwelling devices. A nurse-driven protocol was introduced to allow nurses to discontinue catheters independent of a physician's order when patients no longer met criteria for catheter use. Bladder scanners were purchased to allow nurses to assess for urinary retention. | Infection rate prior to intervention: 36 per 1,000 catheter-days
| | | | | | Infection rate after intervention: 11 per 1,000 catheter-days
| | | | | | p<0.01

* This study addresses prevention of surgical site infections and catheter-associated urinary tract infections

Table 11d Articles addressing prevention of catheter-associated urinary tract infections (studies addressing catheter care): simple before-after studies of moderate methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Rosenthal 2004 ^120^ | Argentina | 1/2001–9/2002 | 22 months | Hand hygiene | QI Strategies: Clinician education, audit and feedback | Rate of symptomatic urinary tract infection:
| Private hospital | | | Aseptic catheter care | An educational intervention with performance feedback was delivered to ICU staff. The education focused on compliance with handwashing before catheter insertion, and positioning the catheter to avoid compression of the catheter by the patient's leg. It is not clear if the intervention targeted nurses, physicians, or both. Feedback on compliance with these practices was provided to ICU staff (through posters in the ICU) and at infection control meetings. Compliance rates and CAUTI rates were fed back to the ICU administrators. | Infection rate prior to intervention: 21.3 per 1,000 catheter-days
| | | | | | Infection rate after intervention: 12.39 per 1,000 catheter-days
| | | | | | p<0.01
| | | | | | Adherence to protocols for hand hygiene:
| | | | | | before intervention: 23.1%
| | | | | | after intervention: 65.2%
| | | | | | Compliance with aseptic insertion and catheter care guidelines:
| | | | | | before intervention: 83%
| | | | | | after intervention: 96%
| | | | | | p<0.01 for both process measures

Table 11e Articles addressing prevention of catheter-associated urinary tract infections (studies addressing catheter care): simple before-after studies of poor methodologic quality

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
*Berg 1995 ^60^ | Guatemala | Not specified | 1 year | Hand hygiene | QI Strategies: Clinician education | Rate of symptomatic urinary tract infection:
| Tertiary care or university hospital | | | | A multifaceted intervention was used to target nosocomial infections in the ICU, with both general measures and measures targeting VAP and CAUTI. Nurses and physicians received 15 educational sessions on aseptic technique, stressing proper hand washing. The educational sessions used lectures and demonstrations, and individual clinicians also received positive and negative feedback and reminder signs at the bedside. The VAP intervention targeted proper use of sterile rinse water and improvement in aseptic technique for suctioning. Providers received more than 15 interactive conferences on the detection, management, and prevention of nosocomial pneumonia; these included lectures, demonstrations, individual instruction and feedback, and contests. The CAUTI intervention consisted of changing open urinary drainage systems to closed systems (aseptic catheter care), with an educational session on the new catheter. The intervention did not specifically target CLABSI, but those outcomes are reported | before intervention: 18 per 1,000 catheter-days
| | | | | | after intervention: 13 per 1,000 catheter-days
| | | | | | p=NS
| | | | | | Adherence to protocols for hand hygiene
| | | | | | Before intervention: 5%
| | | | | | After intervention: 63%
| | | | | | p<0.01

* This study addresses prevention of surgical site infections, central line-associated bloodstream infections, ventilator-associated pneumonia and catheter-associated urinary tract infections.

### Preventive Interventions and Measured Outcomes

We identified reduction in unnecessary catheter use, aseptic insertion and catheter care, and hand hygiene as key preventive interventions for CAUTI. Of the included studies, six ^118, ^ ^119, ^ ^121^ – ^124^ explicitly addressed reduction in placement of catheters or removal of unnecessary catheters once already placed, four ^61, ^ ^117, ^ ^120, ^ ^121^ addressed aseptic insertion and catheter care, and two ^60, ^ ^120^ hand hygiene. Among the four studies addressing insertion and catheter care, three ^117, ^ ^120, ^ ^121^ implemented specific guidelines for catheter care after insertion, and one ^121^ addressed catheter insertion technique.

The measured outcomes varied across studies. Seven studies measured CAUTI rate, measured as rate of symptomatic CAUTI in six studies ^60, ^ ^61, ^ ^119^ – ^122^ and asymptomatic bacteriuria in one. ^123^ Five studies measured catheter usage, ^118, ^ ^119, ^ ^122^ – ^124^ reported as the percentage of inpatients catheterized in three studies ^118, ^ ^122, ^ ^124^ and the average duration of catheterization in two others. ^119, ^ ^123^ Two studies, both of which implemented a catheter care policy ^117, ^ ^120^ reported the rate of adherence to the policy (Tables 11a–11e).

### Quality Improvement Strategies

Provider reminders were used in six studies, ^61, ^ ^118, ^ ^119, ^ ^122^ – ^124^ all of which sought to reduce unnecessary catheter use through a printed ^61, ^ ^118, ^ ^119, ^ ^122^ or computerized ^123, ^ ^124^ reminder to physicians (Tables 11a–11e). Six studies ^60, ^ ^61, ^ ^117, ^ ^120^ – ^122^ used provider education, specifically targeting nurses in one study ^117^ and all clinical staff in the others. Two studies ^61, ^ ^120^ used audit and feedback and two ^121, ^ ^122^ used an organizational change strategy by allowing nurses to remove urethral catheters without a physician order.

### Methodologic Quality of Included Studies

We identified three controlled before-after (CBA) studies ^117, ^ ^123, ^ ^124^ and seven simple before-after studies. ^60, ^ ^61, ^ ^118^ – ^122^ The CBA studies were generally of fair methodologic quality. With regards to factors affecting internal validity, the rationale for selection of the control group was not explained in any of the three studies, and no study reported if outcomes assessors were blinded to treatment group assignment. None of these studies reported CAUTI rate as a primary outcome, instead focusing on process measures (duration of urethral catheterization in two studies ^123, ^ ^124^ and adherence to a guideline for urethral catheterization in one ^117^ ). This likely serves to increase their external validity, given the inherent difficulty in comparing CAUTI rates between hospitals.

The methodologic quality of the SBA studies was moderate within the limits of the study design. All studies reporting infection rates reported rates (Table 12) adjusted for device utilization, and all but one ^61^ used NNIS definitions. However, only two studies reported data at more than one time point before and after the intervention ^61, ^ ^121^ and three of seven studies reporting infection rates ^60, ^ ^119, ^ ^120^ reported process measures as well.

Table 12 Quality criteria for simple before-after studies addressing catheter-associated urinary tract infections

| Internal Validity | | | External Validity
Author | Did the study report data on more than one time point before and after the intervention? | If the study reported infection rates, did it also report process measurements? | Was the intervention performed independent of other QI efforts or other changes? | Did the study use NNIS/CDC methods for measuring infections? | Did the study report infection rates in terms of device utilization?
Berg 1995 ^60^ | o | • | ▴ | • | •
Danchaivijitr, 1992 ^118^ | o | N/A | ▴ | N/A | N/A
Greco 1991 ^61^ | • | o | o | o | •
Huang 2004 ^119^ | o | • | • | • | •
Rosenthal 2004 ^120^ | o | • | • | • | •
Topal 2005 ^122^ | o | o | ▴ | • | •
Dumigan 1998 ^121^ | • | o | ▴ | • | •

•: Yes

o: No

▴: Unclear

We will separately discuss the results of the studies addressing reduction in catheter usage and the studies addressing catheter care.

### Studies Addressing Reduction in Catheter Usage

Seven studies ^61, ^ ^118, ^ ^119, ^ ^121^ – ^124^ sought to reduce urethral catheter usage, 5 ^118, ^ ^119, ^ ^122^ – ^124^ through use of a paper- or computer-based reminder to clinicians (Table 11a). Two ^123, ^ ^124^ were controlled studies and five ^61, ^ ^118, ^ ^119, ^ ^121, ^ ^122^ were simple before-after studies.

Reminders incorporated into an existing computerized physician order entry system were used in two studies, ^122, ^ ^123^ one CBA ^123^ and one SBA. ^122^ In a controlled crossover trial at an academic medical center, ^123^ the intervention consisted of a computerized order requiring an indication for catheter placement and a default 72-hour stop date for the catheter. The intervention successfully reduced the duration of catheterization on the study ward, but was not powered to detect a difference in CAUTI. A similar CPOE reminder with a 48-hour automatic stop date was used in another study, ^122^ but in addition, nurses were empowered to discontinue catheters independent of a physician order according to a prespecified protocol. Significant reductions in both catheter use and CAUTI rates were demonstrated, albeit in the setting of a relatively high baseline rate of CAUTI (36/1,000 catheter-days.)

Three studies ^118, ^ ^119, ^ ^124^ used a paper-based resminder. A controlled trial ^124^ used a chart prompt to physicians after a catheter had been in place for 48 hours, asking for a specific clinical indication to continue catheterization. Although hampered by initial implementation problems, the study did significantly reduce the percentage of days patients were catheterized compared to control. There was no difference in the need for urethral re-catheterization after catheter removal between intervention and control groups. A similar indication sheet was used in another before-after study ^118^ requiring documentation of the indication for catheterization before it could be placed, but this failed to reduce the overall rate of catheterization. Nurses were required to remind physicians to remove unnecessary catheters five days after insertion in a before-after study; ^119^ this intervention significantly reduced both the mean duration of catheterization and CAUTI rates in ICU patients.

Finally, one study ^121^ conducted in ICU patients empowered nurses to remove catheters without a physician order if prespecified indications were met. Nurses also received an educational intervention on catheter care. The intervention reduced CAUTI rates in all three ICUs studied.

### Studies Addressing Catheter Care

Two studies conducted educational interventions on catheter care with implementation of a clinical guideline in order to reduce CAUTI (Tables 11c–11e). A controlled before-after trial in general ward patients ^117^ introduced an infection control liaison nurse to conduct the intervention and found an improvement in adherence to the guideline for catheter care on the study wards compared to the control wards. The study did not measure CAUTI rates. The other study ^120^ was a simple before-after trial in ICU patients that also used audit and feedback of infection rates. The intervention was associated with increased guideline adherence, increased compliance with hand hygiene, and a reduced rate of CAUTI.

Table 11c Articles addressing prevention of catheter-associated urinary tract infections (studies addressing catheter care): controlled studies

Author | Setting and Hospital Type | Study period | Length of follow-up | Preventive Interventions | Quality improvement intervention | Results
Ching 1990 ^117^ | Hong Kong | Not specified | Not specified | Aseptic catheter care | QI Strategies: Clinician education | Adherence to a clinical guideline for preventing
| Tertiary care or university hospital | | | | An infection control liaison nurse was selected for each ward in the intervention group, with another nurse appointed as their assistant. The ICLNs and the assistants received a 3-hour interactive training session from the infection control team on a new guideline for appropriate urinary catheter care. The guideline recommended proper securing of the catheter, preventing the catheter and tube from kinking, and emptying the draining spigot into a collecting container. The ICLNs then presented demonstration tutorials and lectures to regular ward nurses in the intervention wards. The tutorials were in small groups and attendance was mandatory; the lecture was a 30-minute lecture on the new guideline. The control wards received only the lectures. | UTI:
| | | | | | Control:
| | | | | | before intervention: 32.2%
| | | | | | after intervention: 51.8%
| | | | | | Intervention:
| | | | | | before intervention: 37.9%
| | | | | | after intervention: 64.0%
| | | | | | p value for comparison<0.01

Finally, one study discussed previously in the VAP section ^60^ introduced an educational intervention targeting hand hygiene in an ICU in Guatemala (Table 11e). No effect on CAUTI was found, although adherence to hand hygiene protocols did improve.