# Introduction

Healthcare-associated infections (HAIs) are considered to be the greatest risk patients face in the hospital environment. HAIs can occur in any patient care setting, but infections in hospitalized patients account for the vast majority of HAIs. Hospitalized patients are additionally susceptible to experiencing serious consequences of HAIs due to comorbid illnesses. According to estimates from the Centers for Disease Control and Prevention (CDC), up to two million patients (nearly one in 20 hospitalized patients) experience a healthcare-associated infection every year in the U.S., leading to approximately 88,000 deaths and $4.5 billion in extra costs per year. Moreover, the incidence of HAIs appears to have increased over the last three decades, ^1^ despite the fact that the majority of HAIs are thought to be preventable. ^2^

Efforts to monitor and prevent HAIs have existed for decades. These efforts have followed the public health methodology of surveillance and prevention. The effectiveness of such methods was provided by the Study of the Effectiveness of Nosocomial Infection Control (SENIC) study, ^3^ which demonstrated that hospitals with structured infection control programs achieved sustained reductions in HAI rates, whereas hospitals with less comprehensive programs saw increased infection rates.

The growing focus on improving patient safety over the past few years has catalyzed even greater efforts to curb HAIs. Public reporting of infection rates has been proposed as a means of educating patients and encouraging preventive efforts; ^4^ currently, six states require reporting of HAIs, and legislation requiring some type of reporting has been proposed in the majority of states. The Healthcare Infection Control Practices Advisory Committee (HICPAC) recently published guidance on the public reporting of healthcare associated infections, which suggested that central line insertion practices and infection rates, surgical antimicrobial prophylaxis and infection rates, and influenza vaccination coverage among patients and healthcare personnel are areas that may be appropriate for public reporting. ^5^ These efforts are in parallel to those already being undertaken by many national and international organizations. The Joint Commission for Accreditation of Healthcare Organizations (JCAHO) has made prevention of HAI one of their Patient Safety Goals for 2007. ^6^ The Institute for Healthcare Improvement (IHI) made the institution of practices to prevent HAIs (specifically surgical site infections, central line-associated bloodstream infections, and ventilator-associated pneumonia) three of the six “planks” of their “100,000 Lives” campaign. ^7^ These preventive interventions were organized into “bundles”, in an effort to promote complete adherence with all of the recommended interventions for all eligible patients. The IHI's recent press statements that over 122,000 “lives were saved” at hospitals participating in the campaign, though methodologically controversial, is likely to increase the enthusiasm for implementing these and the other recommended practices. Finally, prevention of HAIs was recognized as one of the 20 “Priority Areas for National Action” in the 2003 Institute of Medicine report, “Transforming Health Care Quality”. ^8^

## Major Healthcare-Associated Infections

Within the hospital, infections in surgical patients and infections in intensive care unit (ICU) patients are particularly prevalent. The Harvard Medical Practice Study II ^9^ found that surgical site infections (SSI) were the second most common overall adverse event (behind only adverse drug events) in all hospitalized patients. The incidence of HAI in ICU patients has been estimated to be as high as 30 percent, ^10^ and 25 percent of all HAIs are estimated to occur in ICU patients. ^11^ Surgical site infections (SSI) and three other types of infections commonly seen in ICU patients—central-line associated bloodstream infections (CLABSI), catheter-associated urinary tract infections (CAUTI), and ventilator-associated pneumonia (VAP)—account for more than 80 percent of all HAIs. ^10^

Data on the incidence of HAIs in U.S. hospitals primarily comes from the CDC's National Nosocomial Infection Surveillance System (NNIS). The NNIS consists of over 300 hospitals which voluntarily report data on several types of nosocomial infections (including SSI, CLABSI, VAP, and CAUTI), using standardized reporting criteria. Data from NNIS are important for use in benchmarking, ^12^ although the data are not intended for use in direct hospital-to-hospital comparison of infection rates. The pathogenesis, incidence, and prevention of these HAIs are briefly outlined below.

### Surgical Site Infections

Surgical site infections (SSIs) frequently complicate operations, with an estimated annual incidence of 780,000 cases per year. ^13^ The Centers for Disease Control and Prevention (CDC) publishes a widely used set of diagnostic criteria for each type of SSI: superficial incisional, deep incisional and organ space infections (Table 1). The 2004 NNIS report published mean SSI rates that ranged from 0.45 per 100 cases for low-risk cholecystectomy to 11.25 per 100 cases for high-risk colorectal surgery. ^14^ For example, in coronary artery bypass graft (CABG) operations, the rate for average-risk patients was 3.45/100 cases. In the same group of patients, the rate of superficial infections was 1.87/100 cases, the rate of deep incisional infections was 0.89/100 cases and the rate of organ space infections was 0.68/100 cases. SSIs increase length of stay and costs substantially. One study estimated that each SSI increased hospital charges by $4,768 (2006 dollars). ^15^ Another study estimated that patients diagnosed with SSIs after discharge incurred $3,696 in additional outpatient costs (2006 dollars). ^16^

Table 1 CDC/NNIS definitions for nosocomial infections, 2004

Infection | Definition
Surgical site infections (SSI) | Superficial Incisional Infections:
| A superficial SSI must meet the following criteria:
| Infection occurs within 30 days after the operative procedure and involves only skin and subcutaneous tissue of the incision and patient has at least one of the following:
| a Purulent drainage from the superficial incision; b Organisms isolated from an aseptically obtained culture of fluid or tissue from the superficial incision; c At least one of the following signs or symptoms of infection: pain or tenderness, localized swelling, redness, or heat, and superficial incision is deliberately opened by surgeon, unless incision is culture-negative; d Diagnosis of superficial incisional SSI by the surgeon or attending physician
| Deep Incisional SSI
| A deep incisional SSI must meet the following criteria:
| Infection occurs within 30 days after the operative procedure if no implant is left in place or within one year if implant is in place and the infection appears to be related to the operative procedure and involves deep soft tissues (e.g., fascial and muscle layers) of the incision and patient has at least one of the following:
| a Purulent drainage from the deep incision but not from the organ/space component of the surgical site; b A deep incision spontaneously dehisces or is deliberately opened by a surgeon when the patient has at least one of the following signs or symptoms: fever (>38°C) or localized pain or tenderness, unless incision is culture-negative; c An abscess or other evidence of infection involving the deep incision is found on direct examination, during reoperation, or by histopathologic or radiologic examination; d Diagnosis of a deep incisional SSI by a surgeon or attending physician
| Organ/Space SSI:
| An organ/space SSI involves any part of the body, excluding the skin incision, fascia, or muscle layers, that is opened or manipulated during the operative procedure. An example is appendectomy with subsequent subdiaphragmatic abscess, which would be reported as an organ/space SSI at the intraabdominal specific site. An organ/space SSI must meet the following criteria:
| Infection occurs within 30 days after the operative procedure if no implant is left in place or within 1 year if implant is in place and the infection appears to be related to the operative procedure and infection involves any part of the body, excluding the skin incision, fascia, or muscle layers, that is opened or manipulated during the operative procedure and patient has at least one of the following:
| a Purulent drainage from a drain that is placed through a stab wound into the organ/space; b Organisms isolated from an aseptically obtained culture of fluid or tissue in the organ/space; c An abscess or other evidence of infection involving the organ/space that is found on direct examination, during reoperation, or by histopathologic or radiologic examination; d Diagnosis of an organ/space SSI by a surgeon or attending physician
Central line-associated bloodstream infections (CLABSI) | Patient must have had an indwelling central venous catheter in place at the time of, or within 48 hours of the onset of the event.
| Laboratory Confirmed Bloodstream Infection (LCBI)
| LCBI criteria may be used for all patients. LCBI must meet at least one of the following three criteria:
| Criterion 1: Patient has a recognized pathogen cultured from one or more blood cultures and organism cultured from blood is not related to an infection at another site.
| Criterion 2: Patient has at least one of the following signs or symptoms: fever (>38°C), chills, or hypotension and signs and symptoms and positive laboratory results are not related to infection at another site and at least one of the following:
| a common skin contaminant (e.g., diphtheroids, Bacillus sp., Propionibacterium sp., coagulase-negative staphylococci, or micrococci) is cultured from two or more blood cultures drawn on separate occasions; b common skin contaminant (e.g., diphtheroids, Bacillus sp., Propionibacterium sp., coagulase-negative staphylococci, or micrococci) is cultured from at least one blood culture from a patient with an intravascular line, and physician institutes appropriate antimicrobial therapy; c positive antigen test on blood (e.g., H. influenzae, S. pneumoniae, N. meningitidis, or Group B Streptococcus).
| Criterion 3: Patient ≤ 1 year of age has at least one of the following signs or symptoms: fever (>38°C, rectal), hypothermia (<37°C, rectal), apnea, or bradycardia and signs and symptoms and positive laboratory results are not related to an infection at another site and at least one of the following:
| a common skin contaminant (e.g., diphtheroids, Bacillus sp., Propionibacterium sp., coagulase-negative staphylococci, or micrococci) is cultured from two or more blood cultures drawn on separate occasions; b common skin contaminant (e.g., diphtheroids, Bacillus sp., Propionibacterium sp., coagulase-negative staphylococci, or micrococci) is cultured from at least one blood culture from a patient with an intravascular line, and physician institutes appropriate antimicrobial therapy; c positive antigen test on blood or urine (e.g., H. influenzae, S. pneumoniae, N. meningitidis, or Group B Streptococcus).
| Clinical Sepsis (CSEP): CSEP may be used only to report a primary BSI in neonates and infants. To report a CSEP, the following criterion must be met:
| Patient ≤ 1 year of age has at least one of the following clinical signs or symptoms with no other recognized cause: fever (>38°C, rectal), hypothermia (<37°C, rectal), apnea, or bradychardia and blood culture not done or no organisms or antigen detected in blood and no apparent infection at another site and physician institutes treatment for sepsis.
Ventilator-associated pneumonia (VAP) | PNU 1: Clinically defined pneumonia (in mechanically ventilated patient)
| Radiographic criteria:
| Two or more serial chest radiographs with at least one of the following:
| New or progressive and persistent infiltrate
| Consolidation
| Cavitation
| Pneumatoceles, in infants <1 year old
| NOTE: In patients without underlying pulmonary or cardiac disease, one definitive chest radiograph is acceptable
| Clinical Criteria:
| For any patient, at least one of the following:
| a Fever (>38°C or >100.4°F) with no other recognized cause; b Leukopenia (<4,000 WBC/mm3) or leukocytosis (>12,000 WBC/mm3) For adults >70 years old, altered mental status with no other recognized cause and at least two of the following:; c New onset of purulent sputum, or change in character of sputum, or increased respiratory secretions, or increased suctioning requirements; d New onset or worsening cough, or dyspnea, or tachypnea; e Rales or bronchial breath sounds; f Worsening gas exchange, increased oxygen requirements, or increased ventilation demand)
Catheter-associated urinary tract infection (CAUTI) | Symptomatic urinary tract infection:
| Criterion 1: Patient has at least one of the following signs or symptoms with no other recognized cause: fever (>38°C), urgency, frequency, dysuria, or suprapubic tenderness and patient has a positive urine culture, that is, >10^5^ microorganisms per cm^3^ of urine with no more than two species of microorganisms.
| Criterion 2: Patient has at least two of the following signs or symptoms with no other recognized cause: fever (>38°C), urgency, frequency, dysuria, or suprapubic tenderness and at least one of the following:
| a Positive dipstick for leukocyte esterase and/or nitrate. Pyuria (urine specimen with >10 WBC/mm^3^ or >3 WBC/high power field of unspun urine); c Organisms seen on Gram stain of unspun urine; d At least two urine cultures with repeated isolation of the same uropathogen (gram-negative bacteria or S. saprophyticus) with >10^2^ colonies/mL in nonvoided specimens; e >10^5^ colonies/mL of a single uropathogen (gram-negative bacteria or S. saprophyticus) in a patient being treated with an effective antimicrobial agent for a urinary tract infection; f Physician diagnosis of a urinary tract infection; g Physician institutes appropriate therapy for a urinary tract infection
| Criterion 3: Patient <1 year of age has at least one of the following signs or symptoms with no other recognized cause: fever (>38°C), hypothermia (<37°C), apnea, bradycardia, dysuria, lethargy, or vomiting and patient has a positive urine culture, that is, >10^5^ microorganisms per cm^3^ of urine with no more than two species of microorganisms.
| Criterion 4: Patient <1 year of age has at least one of the following signs or symptoms with no other recognized cause: fever (>38°C), hypothermia (<37°C), apnea, bradycardia, dysuria, lethargy, or vomiting and at least one of the following:
| a Positive dipstick for leukocyte esterase and/or nitrate; b Pyuria (urine specimen with >10 WBC/mm^3^ or >3 WBC/high power field of unspun urine); c Organisms seen on Gram stain of unspun urine; d At least two urine cultures with repeated isolation of the same uropathogen (gram-negative bacteria or S. saprophyticus) with >10^2^ colonies/mL in nonvoided specimens; e >10^5^ colonies/mL of a single uropathogen (gram-negative bacteria or S. saprophyticus) in a patient being treated with an effective antimicrobial agent for a urinary tract infection; f Physician diagnosis of a urinary tract infection; g Physician institutes appropriate therapy for a urinary tract infection
| Catheter-associated asymptomatic bacteriuria:
| Criterion 1: Patient has had an indwelling urinary catheter within 7 days before the culture and patient has a positive urine culture, and patient has no fever (>38°C), urgency, frequency, dysuria, or suprapubic tenderness.

Several organizations, including the CDC, the National Surgical Infection Prevention Project (NSIPP) and the Surgical Care Improvement Project (SCIP), have proposed preventive interventions to reduce the incidence of SSIs. The CDC strongly recommends several preventive measures that are well supported in the literature (Table 2) and are also recommended by NSIPP and SCIP. ^13^ However, adherence to these practices remains suboptimal, including that of the best-studied preventive practice, antimicrobial prophylaxis. The current guidelines recommend three aspects of antimicrobial prophylaxis: appropriate timing, appropriate selection, and appropriate duration.

Table 2 Recommended preventive interventions

Healthcare-associated infection | Preventive intervention | Definition | Level of supporting evidence | Notes
All target HAIs | Hand hygiene | Washing hands before and after each patient contact | I | Universally recommended as key strategy to present HAIs of all types. Current recommendations encourage use of waterless, alcohol-based hand rubs.
Central line-associated bloodstream infections (CLABSI) | Maximal sterile barrier precautions | Use aseptic technique including the use of a cap, mask, sterile gown, sterile gloves, and a large sterile sheet for the insertion of all central venous catheters (CVC) | I
| Chlorhexidine skin antisepsis | Use 2% chlorhexidine gluconate solution for skin disinfection at the CVC insertion site | I
| Appropriate insertion site selection | Avoid femoral site for non-emergency CVC insertion | I | CVC insertion at the internal jugular or subclavian site is preferred.
| Prompt removal of unnecessary catheters | Removal of CVC that is no longer essential for care | I | Routine removal of CVC and routine replacement of CVC over guidewire are explicitly discouraged.
Surgical site infection (SSI) | Appropriate use of perioperative antibiotics | Administration of appropriate prophylactic antibiotic with correct timing and duration | I | Generally defined as 1^st^ generation cephalosporin administered within 1 hour prior to surgical incision and discontinued within 24 hours
| Avoidance of shaving of the operative site | | I | Use of clippers encouraged when necessary
| Perioperative glucose control | Maintenance of blood glucose <150mg/dl during postoperative period (tighter control may be more beneficial in specific patient populations) | I | Especially important for patients undergoing coronary artery bypass grafting
Ventilator-associated pneumonia (VAP) | Semirecumbent positioning | Elevation of the head of the bed to more between 30 and 45 degrees | I
| Daily assessment of readiness for weaning | Minimize duration of mechanical ventilation by minimizing sedative administration (including daily “sedation holidays”) and/or using protocolized weaning | II
Catheter-associated urinary tract infection (CAUTI) | Aseptic insertion and catheter care | Use of skin antisepsis at insertion and proper aseptic technique for maintenance of catheter and drainage bag; use of closed urinary drainage system | I
| Reduction in unnecessary catheter use | Avoiding use of catheter unless clinically indicated; prompt removal of catheters when indications for use are no longer present | I | Generally accepted indications for urethral catheterization include bladder outlet obstruction, urinary incontinence, need for frequent urine output monitoring, and postoperative state. Duration of catheterization is a significant risk factor for CAUTI, and unnecessary catheterization is common.

Level of supporting evidence:

I: Level IA recommendation by Centers for Disease Control and Prevention, or Level I recommendation by Infectious Diseases Society of America/American Thoracic Society.

II: Level II recommendation by Infectious Diseases Society of America/American Thoracic Society.

Appropriate timing consists of administration of antimicrobial prophylaxis within one hour before the surgical incision (or within two hours if a flouroquinolone or vancomycin is used); appropriate selection refers to using antibiotics effective against the pathogens likely to be encountered in a specific type of surgery (e.g., cefazolin for hip or knee arthroplasty); and appropriate duration of therapy mandates discontinuing antibiotics within 24 hours after surgery. ^13, ^ ^17^ Adherence to these measures in practice is suboptimal. A retrospective study of over 30,000 Medicare patients published in 2005 found that prophylaxis was given within one hour of incision in only 55.7 percent of patients and discontinued within 24 hours of surgery in 40.7 percent of patients; guideline-concordant therapy was appropriately used in 92.6 percent of patients. ^18^ These data indicate that improving antimicrobial prophylaxis practices, particularly antibiotic timing, has the potential to positively impact SSI rates. Several groups, including the Institute for Healthcare Improvement (IHI) and the Surgical Care Improvement Project (SCIP) have tried to promote use of these practices nationwide. ^19^

### Central Line-Associated Bloodstream Infections

More than five million central venous catheters (CVC) are inserted into patients in the U.S. every year. ^20^ Several types of infections can occur in patients with CVCs. The skin at the insertion site of the catheter may become infected (so-called exit-site infection). The internal surface of the device itself may become colonized with bacteria, which occurs in 25 percent of catheters left in place for five days. The clinical significance of colonization alone is unclear, but (along with migration of skin flora along the external surface of the catheter) it predisposes to the most serious consequence of catheter-related infection—central-line associated bloodstream infection (CLABSI), ^21^ when a patient develops bacteremic infection associated with the presence of a CVC. It is estimated that one of the two types of infection above (exit-site infection or CLABSI) occur in 3–7 percent of catheters, ^21^ resulting in approximately 80,000 episodes of CLABSI in the U.S. every year. ^11^ Most of these infections occur in patients with temporary central venous catheters, often placed in ICU patients. CLABSI are estimated to result in an absolute increase in mortality of 10–30 percent for ICU patients, ^10, ^ ^22, ^ ^23^ and the total yearly costs to the U.S. health care system are between $300 million and $2 billion. ^11^

CLABSI are measured according to criteria established by the CDC's National Nosocomial Infection Surveillance System (Table 1). For CLABSI, VAP, and CAUTI, rates of infections are adjusted for the individual hospital's rate of use of the associated device (catheter or mechanical ventilator), and the infection rates are reported as infections per 1,000 device-days. The NNIS reports an average CLABSI rate of 4.1–6.1 infections per 1,000 catheter-days in medical-surgical ICUs, and even higher rates in other types of ICUs (e.g., burn units, 10.0 per 1,000 catheter-days). ^14^

Prevention of CLABSI involves close attention to several factors. Basic rules of infection control should be followed, principally involving appropriate hand hygiene. ^24^ Ensuring a sterile environment at the time of insertion of the catheter (through use of maximal sterile barrier precautions and skin disinfection with chlorhexidine) has been demonstrated to reduce the rates of infection in controlled studies, ^25, ^ ^26^ and specific insertion practices have been recommended by the CDC and other major organizations (Table 2). Appropriate dressing and handling of the catheter is clearly important, but no specific strategy has been unequivocally associated with reduction of infections (apart from hand hygiene). ^21^ Removal of catheters that are no longer necessary is another important step, as increasing duration of catheterization predisposes to catheter colonization and subsequent CLABSI. ^21^ Despite extensive research on methods to prevent CLABSI, adherence to recommended preventive practices is suboptimal. A recent survey found that ICU policies regarding insertion and care of CVCs varied widely, with only 28 percent requiring maximal sterile barrier use and 36 percent requiring hand hygiene prior to catheter insertion. ^27^ Due to the close link between insertion practices and infections, and the suboptimal rate of adherence to these practices, the CDC's Healthcare Associated Infection Practices Committee suggested CVC insertion practices as a candidate quality measure for states considering public reporting programs. ^5^

### Ventilator-Associated Pneumonia

Ventilator-associated pneumonia (VAP) is a common and morbid condition affecting ICU patients. The diagnosis of VAP can be difficult. The CDC definition is widely used, but the current diagnostic criteria are entirely clinical in nature, ^28, ^ ^29^ and a standard for invasive or microbiologic diagnosis has yet to be established (Table 1). Nevertheless, VAP is estimated to occur in 9–27 percent of patients intubated for more than 48 hours, ^29^ and patients with VAP have a higher risk of dying in the ICU than similar patients without VAP, though the magnitude of this risk is controversial. ^30^ Patients with VAP remain hospitalized for 7–9 excess days, and costs are estimated to be between $12,000 and $40,000 per patient. ^30^

The pathogenesis of VAP is dependent on the duration of mechanical ventilation, colonization of the aerodigestive tract with bacteria, aspiration of contaminated secretions, and impaired host defenses. ^31^ Prevention of VAP thus focuses on reducing the duration of intubation and various strategies to prevent colonization and aspiration. Multiple practice guidelines for prevention of VAP have appeared in the last 5 years, ^28, ^ ^31^ – ^33^ reflecting the rapidly evolving body of research on prevention of VAP.

### Catheter-Associated Urinary Tract Infection

Urinary tract infections associated with urethral catheters (CAUTI) are the most common HAI in hospitals in the U.S., and account for approximately 40 percent of all HAIs. ^34^ Over 30 million urinary catheters are inserted in hospitalized patients in the U.S. each year, ^35^ and in these patients, colonization of the catheter resulting in asymptomatic bacteriuria occurs in approximately 3–10 percent of patients per day. Once bacteriuria develops, approximately 25 percent develop symptomatic UTI, and approximately three percent develop bacteremia. ^11^ Though the attributable morbidity, mortality, and costs of CAUTI are much lower than CLABSI, VAP, and SSI on a per-patient basis, due to the frequency of urethral catheterization in hospitalized patients, asymptomatic bacteriuria and CAUTI often precipitate antibiotic therapy and may serve as a reservoir for resistant pathogens. ^36, ^ ^37^

Preventive strategies for CAUTI have been evaluated since the 1960s, and (like CVC prevention) focus on reducing unnecessary catheter use and reducing colonization of the insertion site and catheter apparatus. Use of a closed urinary drainage system was the first intervention proven to prevent CAUTI, and these systems are now in standard use. ^36, ^ ^37^ Avoiding obstruction of the drainage system and using aseptic insertion practices (Table 2) are also recommended. While urinary catheters are needed in certain common situations (principally, postoperative states, urinary incontinence, need for frequent urinary output monitoring, and bladder obstruction), ^38^ evidence shows that catheters are frequently kept in place when no indications are present, resulting in up to 50 percent of urinary catheter-days being unnecessary. ^39^ This unnecessary catheter use predisposes to colonization and eventual symptomatic CAUTI.

## Research Questions

In this report, we will systematically review the evidence supporting quality improvement strategies to reduce the incidence of healthcare-associated infections. We will focus our attention on strategies to reduce HAIs in the inpatient setting, specifically addressing prevention of surgical site infections, central line-associated bloodstream infection, ventilator associated pneumonia, and catheter associated urinary tract infection. Our intent is to identify strategies that successfully increase adherence to effective preventive practices for each of these infections and reduce infection rates. Our specific research questions are:

1 Do quality improvement strategies increase adherence to evidence-based preventive interventions for healthcare-associated infections?
  a Which QI strategies increase use of interventions known to prevent surgical site infections?
  b Which QI strategies increase use of interventions known to prevent central venous catheter-associated bloodstream infections?
  c Which QI strategies increase use of interventions known to prevent ventilator-associated pneumonia?
  d Which QI strategies increase use of interventions known to prevent urinary catheter-associated urinary tract infections?
  e In each of these areas, are QI strategies associated with reductions in the incidence of infections (as well as improving adherence)?
  f Are QI strategies associated with adverse effects?
  g Are QI strategies cost-effective?
2 What are the critical components of effective QI strategies?
  a What is the evidence for QI strategies targeting the simultaneous implementation of multiple preventive interventions (“bundling”)?
  b What strategies are effective at increasing use of preventive interventions across different disease processes?
3 What are the limitations of current research in this field, and what areas require further study?