# Technical Experts and Peer Reviewers

[underlined: Technical Expert Panel]

Martin Eccles, M.D., Centre for Health Services Research, University of Newcastle upon Tyne, EPOC

Russell Glasgow, Ph.D., Kaiser Permanente, Colorado

Jeremy Grimshaw, M.B.Ch.B., Ph.D., University of Ottawa, Cochrane Collaboration Effective Practice and Organisation of Care Group (EPOC)

Charles Homer, M.D., M.P.H., National Institute for Children's Health Care Quality

Harmon Jordan, Sc.D., previously with New England Medical Center Evidence-based Practice Center, currently at Abt Associates

Val Lawrence, M.D., M.Sc., The University of Texas Health Science Center at San Antonio and South Texas Veterans Health Care System

Andrew Oxman, M.D., M.Sc., Department of Health Services Research, Norwegian Directorate for Health and Social Welfare, EPOC

James Zazzali, Ph.D., RAND

[underlined: Peer Reviewers]

David Atkins, M.D., M.P.H., Chief Medical Officer, Agency for Healthcare Research and Quality, Center for Outcomes and Evidence

Victoria Fraser, M.D.,Professor of Medicine, Co-Director Division of Infectious Diseases, Washington University School of Medicine

Stephan Harbarth, M.D., M.S., (For Dr. Didier Pittet), Hôpitaux Universitaires de Genève Service de Prévention et Contrôle de l'Infection

Jukka Korpela, M.D., Ph.D., Medical Bacteriology Program Officer, Bacteriology and Mycology Branch, Division of Microbiology and Infectious Diseases NIAID / NIH / DHHS

Ebbing Lautenbach, M.D., M.P.H., Assistant Professor of Medicine and Epidemiology U. of Pennsylvania

Trish Perl, M.D., M.Sc., Assistant Professor of Medicine, Johns Hopkins University School of Medicine, Division of Infectious Diseases, Joint Appointment, Epidemiology, Johns Hopkins School of Public Health and Hygiene

Peter Pronovost, M.D., Ph.D., Professor, Departments of Anesthesiology and Critical Care, Surgery, and Health Policy, Johns Hopkins University of Medicine

Roger Resar, M.D., Senior Fellow, Institute for Healthcare Improvement (IHI)

Thomas R. Russell, M.D., Executive Director, American College of Surgeons

Sanjay Saint, M.D., M.P.H., Research Investigator, Ann Arbor VA Medical Center Director, VA/UM Patient Safety Enhancement Program Associate Professor of Medicine, University of Michigan Medical School, University of Michigan

Margaret Toth, M.D., Chief Quality Officer, Delmarva Foundation, Ohio KePRO