# Listing of Excluded Studies

## References

Abdel-Razek A. Nosocomial infections in ventilated patients. Middle East J Anesthesiol. 1992;11(4):369-79. Not an evaluation of a QI intervention. [pmid: 1625647].
Abi-Said D, Raad I, Umphrey J, et al. Infusion therapy team and dressing changes of central venous catheters. Infect Control Hosp Epidemiol. 1999;20(2):101-5. Not an evaluation of a QI intervention. [pmid: 10064212].
Adams-Chapman I, Stoll BJ. Prevention of nosocomial infections in the neonatal intensive care unit. Curr Opin Pediatr. 2002;14(2):157-64. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 11981284].
Alcohol for hand hygiene: new comparative studies add to the evidence base. Can Commun Dis Rep. 2003;29(1):4–6. Not an evaluation of a QI intervention
Al-Hashemy AM, Seleem MI, Khan ZA, et al. Postoperative wound infection in surgical procedures. Saudi Med J. 2004;25(8):1122-3. Not an evaluation of a QI intervention. [pmid: 15322616].
Allen SD, Conger KB. Serratia marcescens infection of the urinary tract: a nosocomial infection. J Urol. 1969;101(4):621-3. Not an evaluation of a QI intervention. [pmid: 4887310].
Alpert JJ, Heagarty MC, Robertson L, et al. Effective use of comprehensive pediatric care. Utilization of health resources. American Journal of Diseases of Children. 1968;116(5):529. Excluded topic. [pmid: 5687483].
Alvarado CJ, Reichelderfer M. APIC guideline for infection prevention and control in flexible endoscopy. Association for Professionals in Infection Control. Am J Infect Control. 2000;28(2):138-55. Excluded topic. [pmid: 10760223].
Aly H, Herson V, Duncan A, et al. Is bloodstream infection preventable among premature infants? A tale of two cities. Pediatrics. 2005;115(6):1513-8. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 15930211].
Amer FA, Mohtady HA, el-Behedy IM, et al. Bacteria of nosocomial urinary tract infections at a university hospital in Egypt: identification and associated risk factors. Infect Control Hosp Epidemiol. 2004;25(11):895-7. Not an evaluation of a QI intervention. [pmid: 15566017].
Andersen C, Hart J, Vemgal P, et al. Prospective evaluation of a multi-factorial prevention strategy on the impact of nosocomial infection in very-low-birthweight infants. J Hosp Infect. 2005;61:162-7. Other. [pmid: 16240469].
Andriole VT. Hospital acquired urinary infections and the indwelling catheter. Urol Clin North Am. 1975;2(3):451-69. Not an evaluation of a QI intervention. [pmid: 1103410].
Antimicrobial prophylaxis for surgery. Treat Guidel Med Lett. 2004;2(20):27–32. Not an evaluation of a QI intervention
APIC position paper: prevention of device-mediated bloodborne infections to healthcare workers. Association for Professionals in Infection Control and Epidemiology,Inc. Am J Infect Control. 1998;26(6):578–80. Not an evaluation of a QI intervention
Aronow HU, Bolton LB, Aydin C, et al. Patient focused care: evaluating the dual goals of quality improvement and cost reduction abstract. AHSR & FHSR Annual Meeting Abstract Book. 1994;11:8. Study design did not meet criteria for RCT, CBA, ITS or SBA.
Austin TW, Austin MA, Coleman B, et al. Total knee replacement surgery and surgical site infection: a prospective audit. Can J Surg. 2004;47(2):145. Not an evaluation of a QI intervention. [pmid: 15132473].
Avery CM, Jamieson N, Calne RY. Effective administration of heparin and antibiotic prophylaxis. Br J Surg. 1995;82(8):1136-7. Not an evaluation of a QI intervention. [pmid: 7648175].
Babcock HM. Surveillance for surgical-site infections: it' getting better all the time. Infect Control Hosp Epidemiol. 2003;24(10):722-3. Not an evaluation of a QI intervention. [pmid: 14587930].
Bagnulo H. Principles and problems in surgical infections. Introduction. Surg Infect (Larchmt). 2001;2(Suppl 1):S1-2. Not an evaluation of a QI intervention. [pmid: 12594859].
Bailey DR, Riedel DC. Study evaluates Blue Cross recertification experiment. Modern Hospital. 1968;110(2):106. Excluded topic. [pmid: 5637443].
Ball C. Medical devices and their role in the incidence of ventilator-associated pneumonia—challenging some sacred cows!. Intensive Crit Care Nurs. 2005;21(3):131-4. Not an evaluation of a QI intervention. [pmid: 15907665].
Bard biocath hydrophilic-coated Foley catheters. Health Devices. 1988;17(2):69. Not an evaluation of a QI intervention
Barson AJ. Fatal Pseudomonas aeruginosa bronchopneumonia in a children' hospital. Arch Dis Child. 1971;46(245):55-60. Not an evaluation of a QI intervention. [pmid: 5555490]. [pmcid: 1647571].
Bartlett RC. Control of hospital-associated infection. Prog Clin Pathol. 1972;4:259-82. Not an evaluation of a QI intervention. [pmid: 4677446].
Bates DW, Makary MA, Teich JM, et al. Asking residents about adverse events in a computer dialogue: how accurate are they?. Jt Comm J Qual Improv. 1998;24(4):197-202. Not an evaluation of a QI intervention. [pmid: 9589332].
Bishop-Kurylo D. The clinical experience of continuous quality improvement in the neonatal intensive care unit. J Perinat Neonatal Nurs. 1998;12(1):51-7. No eligible outcomes. [pmid: 9782877].
Blenkharn JJ. Prevention of bacteriuria during urinary catheterization of patients in an intensive care unit: evaluation of the ‘Ureofix 500’ closed drainage system. J Hosp Infect. 1985;6(2):187-93. Not an evaluation of a QI intervention. [pmid: 2862194].
Bleyer AJ, Mason L, Russell G, et al. A randomized, controlled trial of a new vascular catheter flush solution (minocycline-EDTA) in temporary hemodialysis access. Infect Control Hosp Epidemiol. 2005;26(6):520-4. Not an evaluation of a QI intervention. [pmid: 16018426].
Bloom B, Craddock A, Delmore P, et al. Reducing acquired infections in the NICU: observing and implementing meaningful differences in process between high and low acquired infection rate centers. Journal of Perinatology. 2003;23(6):489. No eligible outcomes. [pmid: 13679937].
Bodiwala GG, George TK. Surgical gloves during wound repair in the accident-and-emergency department. Lancet. 1982;2(8289):91-2. Not an evaluation of a QI intervention. [pmid: 6123821].
Boelle PY, Golliot F, Valleron AJ. A framework for benchmarking hospital performance: application to surgical site infection. Stud Health Technol Inform. 2003;95:777-82. Not an evaluation of a QI intervention. [pmid: 14664082].
Bond P, Harris C. Best practice in urinary catheterisation and catheter care. Nurs Times. 2005;101(8):54, 6, 8. Not an evaluation of a QI intervention
Bonten MJ, Gaillard CA, Hulst Rvd, et al. Intermittent enteral feeding: the influence on respiratory and digestive tract colonization in mechanically ventilated intensive-care-unit patients. Am J Respir Crit Care Med. 1996;154(2 Pt 1):394-9. Not an evaluation of a QI intervention. [pmid: 8756812].
Bonten MJ, Gaillard CA, Tiel FHv, et al. Colonization and infection with Enterococcus faecalis in intensive care units: the role of antimicrobial agents. Antimicrob Agents Chemother. 1995;39(12):2783-6. Not an evaluation of a QI intervention. [pmid: 8593020]. [pmcid: 163030].
Booth AL, Weeks RM, Hutcheson RH, et al. A statewide characterization of hospital infection control practices and practitioners. Infect Control. 1980;1(4):227-32. Not an evaluation of a QI intervention. [pmid: 6905814].
Borlu M, Utas S. Pyoderma gangrenosum after cholecystectomy. J Eur Acad Dermatol Venereol. 2001;15(2):185-6. Not an evaluation of a QI intervention. [pmid: 11495536].
Boyce JM, Jackson MM, Pugliese G, et al. Methicillin-resistant Staphylococcus aureus (MRSA): a briefing for acute care hospitals and nursing facilities. The AHA Technical Panel on Infections Within Hospitals. Infect Control Hosp Epidemiol. 1994;15(2):105-15. Not an evaluation of a QI intervention. [pmid: 8201231].
Boyce TG. Utility of peripheral venous blood cultures in patients with central venous catheters. Pediatr Infect Dis J. 2000;19(5):491-2. Not an evaluation of a QI intervention. [pmid: 10819359].
Brock VB. The impact of performance feedback on handwashing behaviors. The University of Alabama at Birmingham ** D 2002. Other: article not available
Brook AD, Ahrens TS, Schaiff R, et al. Effect of a nursing-implemented sedation protocol on the duration of mechanical ventilation see comments. Critical Care Medicine. 1999;27(12):2609. Not an evaluation of a QI intervention. [pmid: 10628598].
Brown SM, Lubimova AV, Khrustalyeva NM, et al. Use of an alcohol-based hand rub and quality improvement interventions to improve hand hygiene in a Russian neonatal intensive care unit. Infection Control & Hospital Epidemiology. 2003;24(3):172. Excluded topic. [pmid: 12683507].
Brox N, Ghazarian P. Reducing surgical site infection through process improvement initiatives. Kans Nurse. 2004;79(4):10-1. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 16381346].
Brun-Buisson C. New technologies and infection control practices to prevent intravascular catheter-related infections. Am J Respir Crit Care Med. 2001;164(9):1557-8. Not an evaluation of a QI intervention. [pmid: 11719292].
Brun-Buisson C. Nosocomial pneumonia during mechanical ventilation. Thorax. 1996;51(7):771-2. Not an evaluation of a QI intervention. [pmid: 8882091].
Brunelle D. Impact of a dedicated infusion therapy team on the reduction of catheter-related nosocomial infections. J Infus Nurs. 2003;26:362-6. Other: interventions did not include our target interventions. [pmid: 14624176].
Carling P, Fung T, Killion A, et al. Favorable impact of a multidisciplinary antibiotic management program conducted during 7 years. Infection Control & Hospital Epidemiology. 2003;24(9):699. No eligible outcomes. [pmid: 14510254].
Carroll P. Preventing nosocomial pneumonia. Rn. 1998;61(6):44-7. quiz 8. Not an evaluation of a QI intervention. [pmid: 9668905].
Casey J, Davies J. A nurse led central line insertion service. Edtna Erca J. 2003;29(4):203-5. Not an evaluation of a QI intervention. [pmid: 14748429].
Cerwenka H, Wolf G, Mischinger HJ, et al. Natural killer cell deficiency and severe wound infection after thyroid surgery. Eur J Surg. 2001;167(10):792-4. Not an evaluation of a QI intervention. [pmid: 11775734].
Chan YM, Ngai SW, Hon E, et al. Could the incidence of postoperative urinary tract infection be reduced by reversing the sequence of vaginal cleansing and urethral catheterization?. J Hosp Infect. 2000;46(1):67-72. Not an evaluation of a QI intervention. [pmid: 11023726].
Children's hospitals prevent post-surgical infections. Perform Improv Advis. 2005;9(6):61–3. Not an evaluation of a QI intervention
Childs SJ. Perioperative prevention of infection in genitourinary surgery. Antibiot Chemother. 1985;33:1-29. Not an evaluation of a QI intervention. [pmid: 3888091].
Chinn R, Dembitsky W, Eaton L, et al. Multicenter experience: prevention and management of left ventricular assist device infections. Asaio J. 2005;51(4):461-70. Not an evaluation of a QI intervention. [pmid: 16156314].
Chonmide ON, McMahon M, Gillen P, et al. Non-specialist paediatric surgery—where should it be performed?. Ir Med J. 1999;92(7):439. Not an evaluation of a QI intervention. [pmid: 10967871].
“Close the loop” in QI for ASCs. OR Manager. 2000;16(3):17, 20. Not an evaluation of a QI intervention
Cobb DK, High KP, Sawyer RG, et al. A controlled trial of scheduled replacement of central venous and pulmonary-artery catheters. N Engl J Med. 1992;327(15):1062-8. Not an evaluation of a QI intervention. [pmid: 1522842].
Cohran J, Larson E, Roach H, et al. Effect of intravascular surveillance and education program on rates of nosocomial bloodstream infections. Heart Lung. 1996;25(2):161-4. Not an evaluation of a QI intervention. [pmid: 8682688].
Collier C, Miller DP, Borst M. Community hospital surgeon-specific infection rates. Infect Control. 1987;8(6):249-54. Not an evaluation of a QI intervention. [pmid: 3654124].
Collis DK, Steinhaus K. Total hip replacement without deep infection in a standard operating room. J Bone Joint Surg Am. 1976;58(4):446-50. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 1270462].
Collopy BT, Hart JA, Hooper JC, et al. An inter-hospital criteria audit of infection in total hip-joint replacement surgery. Aust Clin Rev. 1984(13):19–21. Not an evaluation of a QI intervention
Complications of colonic and rectal surgery: discussion. Dis Colon Rectum. 1973;16(1):23–8. Not an evaluation of a QI intervention
Controlling antimicrobial resistance. An integrated action plan for Canadians. Can Commun Dis Rep. 1997;23 Suppl 7:i–iv, 1–32, i–iv, 1-. Not an evaluation of a QI intervention
Couzigou C, Lamory J, Salmon-Ceron D, et al. Short peripheral venous catheters: effect of evidence-based guidelines on insertion, maintenance and outcomes in a university hospital. J Hosp Infect. 2005;59(3):197-204. Excluded topic. [pmid: 15694976].
Crow S. Infection control in the emergency room. Nurs Clin North Am. 1980;15(4):869-82. Not an evaluation of a QI intervention. [pmid: 6935635].
Crummy V. Hospital-acquired urinary tract infection. Nurs Times. 1985;81(23):suppl 7-12. Not an evaluation of a QI intervention. [pmid: 3847908].
Cunha BA. Diagnosis and prevention of intravenous central line-associated infections. Heart Lung. 1995;24(4):261-2. Not an evaluation of a QI intervention. [pmid: 7591792].
Cunha BA. Nosocomial urinary tract infections. Heart Lung. 1982;11(6):545-51. Not an evaluation of a QI intervention. [pmid: 6290427].
Dagan O, Cox PN, Ford-Jones L, et al. Nosocomial infection following cardiovascular surgery: comparison of two periods, 1987 vs. 1992. Crit Care Med. 1999;27:104-8. Other: QI intervention not described. [pmid: 9934902].
Dancer SJ, Crawford A. Keeping MRSA out of a district general hospital. J Hosp Infect. 1999;43(Suppl):S19-27. No eligible outcomes. [pmid: 10658755].
Dann AI. Central line sepsis in children with gastrointestinal disorders. Gastroenterol Nurs. 1994;16(6):259-63. Not an evaluation of a QI intervention. [pmid: 8075161].
Dart CR, Cooke RP. Central venous catheter care. Br J Hosp Med. 1995;53(3):113-4. Not an evaluation of a QI intervention. [pmid: 7728312].
Daschner F. Stress ulcer prophylaxis and the risk of nosocomial pneumonia in artificially ventilated patients. Eur J Clin Microbiol. 1987;6(2):129-31. Not an evaluation of a QI intervention. [pmid: 3595579].
Davis KJ, Evans SL, Campbell RS, et al. Heat-moisture exchangers and risk of nosocomial pneumonia. Infect Control Hosp Epidemiol. 2000;21(9):618. Not an evaluation of a QI intervention. [pmid: 11001272].
de Gentile A, Rivas N, Sinkowitz-Cochran R, et al. Nosocomial infections in a children's hospital in Argentina: impact of a unique infection control intervention program. Infection Control & Hospital Epidemiology. 2001;22(12):762. No eligible outcomes. [pmid: 11876454].
Degroot J. Indwelling catheters. Am J Nurs. 1975;75(3):448-9. Not an evaluation of a QI intervention. [pmid: 1038317].
DeLise DC, Leasure AR. Benchmarking: measuring the outcomes of evidence-based practice. Outcomes Manag Nurs Pract. 2001;5(2):70-4. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 11898330].
Dickerson N, Horton P, Smith S, et al. Clinically significant central venous catheter infections in a community hospital: association with type of dressing. J Infect Dis. 1989;160(4):720-2. Not an evaluation of a QI intervention. [pmid: 2794563].
DiConsiglio J. Combine & conquer. Mater Manag Health Care. 2004;13(10):32-4. Not an evaluation of a QI intervention. [pmid: 15559598].
Dimick JB, Pronovost PJ, Heitmiller RF, et al. Intensive care unit physician staffing is associated with decreased length of stay, hospital cost, and complications after esophageal resection. Crit Care Med. 2001;29(4):753-8. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 11373463].
Dinc L, Erdil F. The effectiveness of an educational intervention in changing nursing practice and preventing catheter-related infection for patients receiving total parenteral nutrition. International Journal of Nursing Studies. 2000;37(5):371. No eligible outcomes. [pmid: 10785528].
Dittmer ID, Tomson CR. Pulmonary abscess complicating central venous hemodialysis catheter infection. Clin Nephrol. 1998;49(1):66. Not an evaluation of a QI intervention. [pmid: 9491291].
Dittmer ID. Infections associated with central venous catheterisation for plasmapheresis. Aust N Z J Med. 1998;28(6):835. Not an evaluation of a QI intervention. [pmid: 9972418].
dos Santos CC, Zhang H, Slutsky AS. From bench to bedside: bacterial growth and cytokines. Crit Care. 2002;6(1):4-6. Not an evaluation of a QI intervention. [pmid: 11940256]. [pmcid: 137387].
Doughty DB. Preventing and managing surgical wound dehiscence. Home Healthc Nurse. 2004;22(6):364-7. Not an evaluation of a QI intervention. [pmid: 15184776].
Drakulovic MB, Djokic D, Torres A. Colonization with Pseudomonas aeruginosa in critically ill patients and measures for its prevention. Neth J Med. 1999;55(3):100-2. Not an evaluation of a QI intervention. [pmid: 10509066].
Dries DJ, McGonigal MD, Malian MS, et al. Protocol-driven ventilator weaning reduces use of mechanical ventilation, rate of early reintubation, and ventilator-associated pneumonia. J Trauma. 2004;56(5):943-51. discussion 51–2. Not an evaluation of a QI intervention. [pmid: 15179231].
Early intervention prevents pneumonia in high-risk populations. Med Manag Netw. 1999;7(2):6–9. Not an evaluation of a QI intervention
Earsing KA, Hobson DB, White KM. Best-practice protocols: preventing central line infection. Nurs Manage. 2005;36:18-24. Duplicate publication. [pmid: 16210947].
East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proceedings / AMIA Annual Symposium. 1999:251. Excluded topic
Eggimann P, Hugonnet S, Sax H, et al. Long-term reduction of vascular access-associated bloodstream infection. Ann Intern Med. 2005;142:875-6. Duplicate publication. [pmid: 15897546].
Elward AM. Pediatric ventilator-associated pneumonia. Pediatr Infect Dis J. 2003;22(5):445-6. Not an evaluation of a QI intervention. [pmid: 12792388].
Evans AT. Nosocomial infections and the urologist. J Urol. 1974;111(6):813-6. Not an evaluation of a QI intervention. [pmid: 4598375].
Everitt DE, Soumerai SB, Avorn J, et al. Changing surgical antimicrobial prophylaxis practices through education targeted at senior department leaders. Infection Control & Hospital Epidemiology. 1990;11:578. Other: no baseline data reported. [pmid: 2124233].
Fanning C, Johnston BL, MacDonald S, et al. Postdischarge surgical site infection surveillance. Can J Infect Control. 1995;10(3):75-9. Not an evaluation of a QI intervention. [pmid: 8555514].
Fanning MF. Reducing postoperative pulmonary complications in cardiac surgery patients with the use of the best evidence. J Nurs Care Qual. 2004;19(2):95-9. Excluded topic. [pmid: 15077825].
Farley JE, Srinivasan A, Richards A, et al. Handheld computer surveillance: shoe-leather epidemiology in the “palm” of your hand. Am J Infect Control. 2005;33(8):444-9. Not an evaluation of a QI intervention. [pmid: 16216657].
Ferraz EM, Ferraz AA, Coelho HS, et al. Postdischarge surveillance for nosocomial wound infection: does judicious monitoring find cases?. Am J Infect Control. 1995;23(5):290-4. Not an evaluation of a QI intervention. [pmid: 8585640].
Ferrer R, Artigas A. Clinical review: non-antibiotic strategies for preventing ventilator-associated pneumonia. Crit Care. 2002;6(1):45-51. Not an evaluation of a QI intervention. [pmid: 11940265]. [pmcid: 137396].
Field J. Prevention of infection: central venous catheters. Nurs Stand. 2002;16(38):40-4. Not an evaluation of a QI intervention. [pmid: 12077955].
Filippo AD, Gaudio ARD. Device-related infections in critically ill patients. Part II: Prevention of ventilator-associated pneumonia and urinary tract infections. J Chemother. 2003;15(6):536-42. Not an evaluation of a QI intervention. [pmid: 14998076].
Flanders E, Hinnant JR. Ambulatory surgery postoperative wound surveillance. Am J Infect Control. 1990;18(5):336-9. Not an evaluation of a QI intervention. [pmid: 2252227].
Forchielli ML, Lo CW, Richardson D, et al. Central venous line related bacteremia during total parenteral nutrition and/or chemotherapy infusions in children. Ann Ig. 1997;9(1):35-40. Not an evaluation of a QI intervention. [pmid: 9284587].
Forster DH, Krause G, Gastmeier P, et al. Can quality circles improve hospital-acquired infection control?. J Hosp Infect. 2000;45(4):302-10. No eligible outcomes. [pmid: 10973748].
Fraenkel D, Rickard C, Thomas P, et al. A prospective, randomized trial of rifampicin-minocycline-coated and silver-platinum-carbon-impregnated central venous catheters. Crit Care Med. 2006;34(3):668-75. Not an evaluation of a QI intervention. [pmid: 16505651].
Franklin CM. Does ICU care determine the outcome of caring for patients with pneumococcal bacteremia?. Chest. 1995;108(5):1475. Not an evaluation of a QI intervention. [pmid: 7587469].
Fridkin SK, Gaynes RP. Antimicrobial resistance in intensive care units. Clin Chest Med. 1999;20(2):303–16, viii. Not an evaluation of a QI intervention
Fridkin SK. Increasing prevalence of antimicrobial resistance in intensive care units. Crit Care Med. 2001;29(4 Suppl):N64-8. Not an evaluation of a QI intervention. [pmid: 11292878].
Friedewald M, Elwin C. New graduate nurses and infection control: knowledge versus practice. Australian Infection Control. 2003;8(1):21. Not an evaluation of a QI intervention.
From the NIH: Urinary catheter care may increase risk of infection. Jama. 1981;246(1):30. Not an evaluation of a QI intervention
Fryklund B, Haeggman S, Burman LG. Transmission of urinary bacterial strains between patients with indwelling catheters—nursing in the same room and in separate rooms compared. J Hosp Infect. 1997;36(2):147-53. Not an evaluation of a QI intervention. [pmid: 9211162].
Gastmeier P, Sohr D, Brandt C, et al. Reduction of orthopaedic wound infections in 21 hospitals. Arch Orthop Trauma Surg. 2005;125(8):526-30. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 16189690].
GDEPIH-GOSPIZ Belgian consensus strategies to control antibiotic-resistant bacteria in hospitals. Acta Clin Belg. 1999;54(1):15–6. Not an evaluation of a QI intervention
Geubbels EL, Bakker HG, Houtman P, et al. Promoting quality through surveillance of surgical site infections: five prevention success stories. Am J Infect Control. 2004;32(7):424-30. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 15525920].
Geyer S. Breathing easy. Vigilance and education can prevent VAP. Mater Manag Health Care. 2004;13(7):14, 6–7. Not an evaluation of a QI intervention
Gibbs H. Journal of Infection Control Nursing. Catheter toilet and urinary tract infections. Nurs Times. 1986;82(23):75-6. Not an evaluation of a QI intervention. [pmid: 3637812].
Glenwright HD, Martin MV. Infection control in dentistry. A practitioner' guide. British Dental Association. Br Dent J. 1993;175(1 Suppl):8. Not an evaluation of a QI intervention.
Goetz AM, Kedzuf S, Wagener M, Muder RR. Feedback to nursing staff as an intervention to reduce catheter-associated urinary tract infections. American Journal of Infection Control. 1999;27:402. Other: interventions did not include our target interventions. [pmid: 10511486].
Goetz AM, Muder RR. The problem of methicillin-resistant Staphylococcus aureus: a critical appraisal of the efficacy of infection control procedures with a suggested approach for infection control programs. Am J Infect Control. 1992;20(2):80-4. Not an evaluation of a QI intervention. [pmid: 1590603].
Goode CJ, Piedalue F. Evidence-based clinical practice. J Nurs Adm. 1999;29(6):15-21. Not an evaluation of a QI intervention. [pmid: 10377921].
Gorecki PJ, Schein M, Mehta V, et al. Surgeons and infectious disease specialists:different attitudes towards antibiotic treatment and prophylaxis in common abdominalsurgical infections. Surg Infect (Larchmt). 2000;1(2):115–23; discussion 25–6. Not an evaluation of a QI intervention
Gorecki W, Grochowska E, Krysta M, et al. A prospective comparison of antibiotic usage in pediatric surgical patients: the safety, advantage, and effectiveness of the Surgical Infection Society guidelines versus a common practice. J Pediatr Surg. 2002;37(10):1430-4. Excluded topic. [pmid: 12378448].
Gould D, Chamberlain A. The use of a ward-based educational teaching package to enhance nurses' compliance with infection control procedures. Journal of Clinical Nursing. 1997;6:55. Other: out of scope. [pmid: 9052110].
Grady NPO, Alexander M, Dellinger EP, et al. Guidelines for the prevention of intravascular catheter-related infections. Infect Control Hosp Epidemiol. 2002;23(12):759-69. Not an evaluation of a QI intervention. [pmid: 12517020].
Greene JN. Catheter-related complications of cancer therapy. Infect Dis Clin North Am. 1996;10(2):255-95. Not an evaluation of a QI intervention. [pmid: 8803621].
Hand washing, cleaning, disinfection and sterilization in health care. Can Commun Dis Rep. 1998;24 Suppl 8:i–xi, 1–55, i–xi, 1–7. Not an evaluation of a QI intervention
Hanucharurnkui S, Vinya-nguag P. Effects of promoting patients' participation in self-care on postoperative recovery and satisfaction with care. Nurs Sci Q. 1991;4(1):14-20. Not an evaluation of a QI intervention. [pmid: 1705685].
Harper P. Guidelines for preventing hospital-acquired infection. Nurs Times. 2001;97(13):34-6. Not an evaluation of a QI intervention.
Harris JR, Miller TH. Preventing nosocomial pneumonia: evidence-based practice. Crit Care Nurse. 2000;20(1):51–66; quiz 7–8. Not an evaluation of a QI intervention
Heriteau FL, Alberti C, Cohen Y, et al. Nosocomial infection and multidrug-resistant bacteria surveillance in intensive care units: a survey in France. Infect Control Hosp Epidemiol. 2005;26(1):13-20. Not an evaluation of a QI intervention. [pmid: 15693404].
HIV and bloodborne infections in emergency medicine. American College of Emergency Physicians. Ann Emerg Med. 1997;29(4):571–2. Not an evaluation of a QI intervention
Hixson S, Sole ML, King T. Nursing strategies to prevent ventilator-associated pneumonia. AACN Clin Issues. 1998;9(1):76–90; quiz 145–6. Not an evaluation of a QI intervention
Hong SW, Ching TY, Fung JP, et al. The employment of ward opinion leaders for continuing education in the hospital. Medical Teacher. 1990;12(2):209. No eligible outcomes. [pmid: 2079896].
Hopkins J, Shoemaker W, Greenfield S, et al. Treatment of surgical emergencies with and without an algorithm. Archives of Surgery. 1980;115(6):745. Excluded topic. [pmid: 7387362].
Hospital cuts time on ventilators, ICU LOS. Healthc Benchmarks. 1999;6(5):57–9. Study design did not meet criteria for RCT, CBA, ITS or SBA
Hospital-acquired pneumonia in adults: diagnosis, assessment of severity, initial antimicrobial therapy, and preventive strategies. A consensus statement, American Thoracic Society, November 1995. Am J Respir Crit Care Med. 1996;153(5):1711–25. Not an evaluation of a QI intervention
How a hospital uses its surgical site infection measure. Jt Comm Perspect. 2001;21(10):8–9. Not an evaluation of a QI intervention
Ibeziako PA, Ayeni O. Postoperative wound sepsis in obstetric and gynecologic surgery. Int Surg. 1979;64(2):67-70. Not an evaluation of a QI intervention. [pmid: 541189].
Ibrahim EH, Ward S, Sherman G, et al. Experience with a clinical guideline for the treatment of ventilator-associated pneumonia. Crit Care Med. 2001;29(6):1109-15. Not an evaluation of a QI intervention. [pmid: 11395584].
ICU improvement project cuts central line infections 50%. Perform Improv Advis.2005;9(12):137–8, 3. Study design did not meet criteria for RCT, CBA, ITS or SBA
Infection control during gastrointestinal endoscopy. Guidelines for clinical application.Gastrointest Endosc. 1988;34(3 Suppl):37S–40S. Not an evaluation of a QI intervention
Injection safety. Trop Doct. 2003;33(1):48–9. Not an evaluation of a QI intervention
Isakow W, Kollef MH. Preventing ventilator-associated pneumonia: an evidence-based approach of modifiable risk factors. Semin Respir Crit Care Med. 2006;27(1):5-17. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 16508876].
Jansen D. The impact of a clinical nurse's role on CVC infections and bacteremia: a two year comparative, retrospective study. Aust Nurs J. 1994;1:22-5. Other: no eligible preventive practices. [pmid: 7697164].
Jarvis WR. Benchmarking for prevention: the Centers for Disease Control and Prevention's National Nosocomial Infections Surveillance (NNIS) system experience. Infection. 2003;31(Suppl 2):44-8. Not an evaluation of a QI intervention. [pmid: 15018472].
Jenkinson H. Urinary catheter-related infection: an education programme for users. Br J Community Nurs. 2005;10(2):77-80. Not an evaluation of a QI intervention. [pmid: 15788945].
Jenks PJ, Shaw EJ. Recurrent septicaemia due to “Achromobacter group B”. J Infect. 1997;34(2):143-5. Not an evaluation of a QI intervention. [pmid: 9138138].
Johnson S, Gerding DN, Olson MM, et al. Prospective, controlled study of vinyl glove use to interrupt Clostridium difficile nosocomial transmission. American Journal of Medicine. 1990;88(2):137. Not an evaluation of a QI intervention. [pmid: 2301439].
Jorbeck H, Sterner G, Enocksson E, et al. Staphylococcal infection in pregnancy at term. Scand J Infect Dis Suppl. 1990;71:86-8. Not an evaluation of a QI intervention. [pmid: 2287921].
Kamgang P, Tintillier M, Pochet JM, et al. Pretibial swelling revealing infected vascular graft. Acta Clin Belg. 2004;59(4):229-31. Not an evaluation of a QI intervention. [pmid: 15597732].
Kapadia F, Rodrigues C. Central venous catheter infections. Intensive Care Med. 1996;22(7):714. Not an evaluation of a QI intervention. [pmid: 8844243].
Kaye J, Ashline V, Erickson D, et al. Critical care bug team: a multidisciplinary team approach to reducing ventilator-associated pneumonia. Am J Infect Control. 2000;28:197-201. Other. [pmid: 10760228].
Keenan SP, Heyland DK, Jacka MJ, et al. Ventilator-associated pneumonia. Prevention, diagnosis, and therapy. Crit Care Clin. 2002;18(1):107-25. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 11910725].
Keith DD, Garrett KM, Hickox G, et al. Ventilator-associated pneumonia: improved clinical outcomes. J Nurs Care Qual. 2004;19(4):328-33. quiz 34–5. Not an evaluation of a QI intervention. [pmid: 15535538].
Kelly AJ, Bailey R, Davies EG, et al. An audit of early wound infection after elective orthopaedic surgery. J R Coll Surg Edinb. 1996;41(2):129-31. Not an evaluation of a QI intervention. [pmid: 8632389].
Khanam T, Branthwaite MA, English IC, et al. The control of pulmonary sepsis in intensive therapy units. A study at the Brompton Hospital, London. Anaesthesia. 1973;28(1):17-28. Not an evaluation of a QI intervention. [pmid: 4631430].
Khatib M, Jamaleddine G, Abdallah A, et al. Hand washing and use of gloves while managing patients receiving mechanical ventilation in the ICU. Chest. 1999;116:172-5. Other: out of scope. [pmid: 10424522].
Kiernan M. Reducing the risks of device-related infection caused by staphylococci. Prof Nurse. 2003;18(8):441-4. Not an evaluation of a QI intervention. [pmid: 12715534].
Killion A. Reducing the risk of infection from indwelling urethral catheters. Nursing. 1982;12(5):84-8. Not an evaluation of a QI intervention. [pmid: 6918845].
Kirk SJ, Cooper GC, Moorehead RJ, et al. Wound sepsis in 10,000 surgical patients. Ulster Med J. 1990;59(1):36-40. Not an evaluation of a QI intervention. [pmid: 2349747]. [pmcid: 2448258].
Kitson A, Harvey G, Hyndman S, et al. The Impact of a Nursing Quality Assurance Approach, the Dynamic Standard Setting System (DySSSy), on Nursing Practice and Patient Outcomes (The ODySSSy Project). National Institute for Nursing Report. 1994; 2. Other: article not available
Kjaeldgaard P, Cordtz T, Sejberg D, et al. The DANOP-DATA system: a low-cost personal computer based program for monitoring of wound infections in surgical ward. J Hosp Infect. 1989;13(3):273-9. Not an evaluation of a QI intervention. [pmid: 2567757].
Kramer B. Ventilator-associated pneumonia in critically ill patients. Ann Intern Med. 1999;130(12):1027-8. Not an evaluation of a QI intervention. [pmid: 10383357].
Krasner D. The AHCPR pressure ulcer infection control recommendations revisited. Ostomy Wound Manage. 1999;45(1A Suppl):88S-91S. quiz 2S-3S. Not an evaluation of a QI intervention. [pmid: 10085979].
Krukowski ZH, Matheson NA. Ten-year computerized audit of infection after abdominal surgery. Br J Surg. 1988;75(9):857-61. Not an evaluation of a QI intervention. [pmid: 3179658].
Krzywda E. Central to vascular access: clinical practice. Nutr Clin Pract. 1996;11(3):87-8. Not an evaluation of a QI intervention. [pmid: 8807924].
Kunin CM. Nosocomial urinary tract infections and the indwelling catheter: what is new and what is true?. Chest. 2001;120(1):10-2. Not an evaluation of a QI intervention. [pmid: 11451807].
Lacroix J, Gauvin F. Habit and the hub. Crit Care Med. 2003;31(5):1583-4. Not an evaluation of a QI intervention. [pmid: 12771640].
Lange BJ, Weiman M, Feuer EJ, et al. Impact of changes in catheter management on infectious complications among children with central venous catheters. Infect Control Hosp Epidemiol. 1997;18:326-32. Other: no eligible preventive practices. [pmid: 9154475].
Langley JM, Hanakowski M, Leblanc JC. Unique epidemiology of nosocomial urinary tract infection in children. Am J Infect Control. 2001;29(2):94-8. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 11287876].
Lapchik MS, Filho AC, Pestana JO, et al. Risk factors for nosocomial urinary tract and postoperative wound infections in renal transplant patients: a matched-pair case-control study. J Urol. 1992;147(4):994-8. Not an evaluation of a QI intervention. [pmid: 1552621].
Laurent C. Preventing infection from indwelling catheters. Nurs Times. 1998;94(25):60–2, 4. Not an evaluation of a QI intervention
LaVoie K, Kopnick M. Impact of dressing materials on central venous catheter infection rates. J Intraven Nurs. 1998;21(3):140-2. Not an evaluation of a QI intervention. [pmid: 9652271].
Lawson P. Zapping VAP with evidence-based practice. Nursing. 2005;35(5):66-7. Not an evaluation of a QI intervention. [pmid: 15879977].
Ledger WJ, Reite AM, Headington JT. A system for infectious disease surveillance on an obstetric service. Obstet Gynecol. 1971;37(5):769-78. Not an evaluation of a QI intervention. [pmid: 5091757].
Leon C, Alvarez-Lerma F, Ruiz-Santana S, et al. Antiseptic chamber-containing hub reduces central venous catheter-related infection: a prospective, randomized study. Crit Care Med. 2003;31(5):1318-24. Not an evaluation of a QI intervention. [pmid: 12771597].
Levy MM, Pronovost PJ, Dellinger RP, et al. Sepsis change bundles: converting guidelines into meaningful change in behavior and clinical outcome. Crit Care Med. 2004;32(11 Suppl):S595-7. Not an evaluation of a QI intervention. [pmid: 15542969].
Liberati A, Pifferi RDA, Torri V, et al. Antibiotic prophylaxis to reduce respiratory tract infections and mortality in adults receiving intensive care. Cochrane Database Syst Rev. 2004(1):CD000022. Not an evaluation of a QI intervention
Lief D. A practical guide for the prevention of catheter-associated urinary tract infections. Auaa J. 1985;6(1):16-7. Not an evaluation of a QI intervention. [pmid: 2933019].
Lindan R. Catheter care team heads off urinary infections. Hospitals. 1972;46(10):86-94. Not an evaluation of a QI intervention. [pmid: 5024751].
Logghe C, Ossel CV, Hoore WD, et al. Evaluation of chlorhexidine and silver-sulfadiazine impregnated central venous catheters for the prevention of bloodstream infection in leukaemic patients: a randomized controlled trial. J Hosp Infect. 1997;37(2):145-56. Not an evaluation of a QI intervention. [pmid: 9364263].
Maas A, Flament P, Pardou A, et al. Central venous catheter-related bacteraemia in critically ill neonates: risk factors and impact of a prevention programme. J Hosp Infect. 1998;40:211-24. Other: no eligible preventive practices. [pmid: 9830592].
Maki DG, Hennekens CH, Bennett JV. Prevention of catheter-associated urinary tract infection. An additional measure. Jama. 1972;221(11):1270-1. Not an evaluation of a QI intervention. [pmid: 5068631].
Maki DG, Stolz SM, Wheeler S, et al. Prevention of central venous catheter-related bloodstream infection by use of an antiseptic-impregnated catheter. A randomized, controlled trial. Ann Intern Med. 1997;127(4):257-66. Not an evaluation of a QI intervention. [pmid: 9265424].
Manso E, Sio GD, Biavasco F, et al. Vancomycin-resistant enterococci. Lancet. 1993;342(8871):616-7. Not an evaluation of a QI intervention. [pmid: 8102743].
Marelich GP, Murin S, Battistella F, et al. Protocol weaning of mechanical ventilation in medical and surgical patients by respiratory care practitioners and nurses: effect on weaning time and incidence of ventilator-associated pneumonia. Chest. 2000;118(2):459. Not an evaluation of a QI intervention. [pmid: 10936141].
Marena C, Lodola L, Zecca M, et al. Assessment of handwashing practices with chemical and microbiologic methods: preliminary results from a prospective crossover study. AJIC: American Journal of Infection Control. 2002;30(6):334. No eligible outcomes.
Mathews PJ. Ventilator-associated infections. Part II. Reducing the risks. Nursing. 1997;27(3):50-1. Not an evaluation of a QI intervention. [pmid: 9171629].
Mathews PJ. Ventilator-associated infections. Reducing the risks. Part I. Nursing. 1997;27(2):59-61. Not an evaluation of a QI intervention. [pmid: 9171609].
Mathias JM. Curbing CABG infection rates. OR Manager. 1999;15:36. Other: no eligible preventive practices.
McConkey SJ, L'Ecuyer PB, Murphy DM, et al. Results of a comprehensive infection control program for reducing surgical-site infections in coronary artery bypass surgery: further data from the authors. Infect Control Hosp Epidemiol. 1999;20:791-2. Duplicate publication. [pmid: 10614600].
McConnell SA, Gubbins PO, Anaissie EJ. Do antimicrobial-impregnated central venous catheters prevent catheter-related bloodstream infection?. Clin Infect Dis. 2003;37(1):65-72. Not an evaluation of a QI intervention. [pmid: 12830410].
McDonald H. Changing practice: modified clean technique for intermittent catheterization. SCI Nurs. 2001;18(1):30-3. No eligible outcomes. [pmid: 12035475].
McKinney BC. Cut your patients' risk of nosocomial UTI. Rn. 1995;58(11):20-3. quiz 4. Not an evaluation of a QI intervention. [pmid: 7501976].
Meakins JL, Wicklund B, Forse RA, et al. The surgical intensive care unit: current concepts in infection. Surg Clin North Am. 1980;60(1):117-32. Not an evaluation of a QI intervention. [pmid: 6899492].
Medical devices alert. Subject: Transmission of blood-borne pathogens via springloadedlancet devices. Can J Med Technol. 1991;53(1):51–2. Not an evaluation of a QI intervention
Meduri GU, Johanson WGJ. International Consensus Conference: clinical investigation of ventilator-associated pneumonia. Introduction. Chest. 1992;102(5 Suppl 1):551S-2S. Not an evaluation of a QI intervention. [pmid: 1424928].
Meduri GU. Ventilator-associated pneumonia in patients with respiratory failure. A diagnostic approach. Chest. 1990;97(5):1208-19. Not an evaluation of a QI intervention. [pmid: 2184998].
Meister S. Emerging risks: inappropriately prolonged mechanical ventilation. QRC Advis. 1993;9(6):1-3. Not an evaluation of a QI intervention. [pmid: 10125145].
Mermel L. Central venous catheter-related infections and their prevention: is there enough evidence to recommend tunneling for short-term use?. Crit Care Med. 1998;26(8):1315-6. Not an evaluation of a QI intervention. [pmid: 9710087].
Midgley JW, Osterhage RA. Effect of nursing instruction and length of hospitalization on postoperative complications in cholecystectomy patients. Nursing Research. 1973;22(1):69. Excluded topic. [pmid: 4486185].
Miller J, Preston TD, Dann PE, et al. Charting v computers in a postoperative cardiothoracic ITU. Nurs Times. 1978;74(34):1423-5. Excluded topic. [pmid: 80788].
Miller MR, Pronovost PJ, Burstin HR. Pediatric patient safety in the ambulatory setting. Ambul Pediatr. 2004;4(1):47-54. Not an evaluation of a QI intervention. [pmid: 14731091].
Miller SD, Andrassy RJ. Complications in pediatric surgical oncology. J Am Coll Surg. 2003;197(5):832-7. Not an evaluation of a QI intervention. [pmid: 14585421].
Mitchell RG. Urinary Tract Infections Caused by Salmonellae. Lancet. 1965;14:1092-3. Not an evaluation of a QI intervention. [pmid: 14283766].
Mitchell RG. Urinary Tract Infections Due to Coagulase-Negative Staphylococci. J Clin Pathol. 1964;17:105-6. Not an evaluation of a QI intervention. [pmid: 14149929].
Model these best practices to prevent surgical infections. Perform Improv Advis. 2004;8(5):49–51. Not an evaluation of a QI intervention
Montagnac R, Schillinger F. Rifampicin-protamine protocol applied for prevention of central catheter sepsis in haemodialysis. Nephrol Dial Transplant. 1993;8(3):289-90. Not an evaluation of a QI intervention. [pmid: 8385301].
Montesinos I, Salido E, Delgado T, et al. Epidemiology of methicillin-resistant Staphylococcus aureus at a university hospital in the Canary Islands. Infect Control Hosp Epidemiol. 2003;24(9):667-72. Not an evaluation of a QI intervention. [pmid: 14510249].
Mooney BR, Armington LC. Infection control: how to prevent nosocomial infections. Rn. 1987;50(9):20-3. Not an evaluation of a QI intervention. [pmid: 3423638].
Moretti EW, Ofstead CL, Kristy RM, et al. Impact of central venous catheter type and methods on catheter-related colonization and bacteraemia. J Hosp Infect. 2005;61(2):139-45. Not an evaluation of a QI intervention. [pmid: 16026898].
Mulin B, Rouget C, Clement C, et al. Association of private isolation rooms with ventilator-associated Acinetobacter baumanii pneumonia in a surgical intensive-care unit. Infect Control Hosp Epidemiol. 1997;18(7):499-503. Not an evaluation of a QI intervention. [pmid: 9247833].
Murtough SM, Hiom SJ, Palmer M, et al. Biocide rotation in the healthcare setting: is there a case for policy implementation?. J Hosp Infect. 2001;48(1):1-6. Not an evaluation of a QI intervention. [pmid: 11358464].
National Clostridium difficile Standards Group: Report to the Department of Health. J Hosp Infect. 2004;56 Suppl 1:1–38. Not an evaluation of a QI intervention
Neumayer L, Mastin M, Vanderhoof L, et al. Using the Veterans Administration National Surgical Quality Improvement Program to improve patient outcomes. J Surg Res. 2000;88:58-61. Other: interventions did not include our target interventions. [pmid: 10644468].
Newell WRaJ. Assessing, treating and managing patients with sepsis. Nurs Stand. 2005;19(50):56-64. Not an evaluation of a QI intervention. [pmid: 16138619].
Ng SP, Gomez JM, Lim SH, et al. Reduction of nosocomial infection in a neonatal intensive care unit (NICU). Singapore Med J. 1998;39:319-23. Other: no eligible preventive practices. [pmid: 9885694].
Ngo A, Murphy S. A theory-based intervention to improve nurses' knowledge, self-efficacy, and skills to reduce PICC occlusion. J Infus Nurs. 2005;28(3):173-81. Excluded topic. [pmid: 15912072].
Niederman MS, Summer ATaW. Invasive diagnostic testing is not needed routinely to manage suspected ventilator-associated pneumonia. Am J Respir Crit Care Med. 1994;150(2):565-9. Not an evaluation of a QI intervention. [pmid: 8049849].
Noer HH, Jensen LP, Kalms SB, et al. The use of a personal computer program for monitoring wound infections and other complications in orthopedics. Int J Clin Monit Comput. 1991;8(1):13-8. Not an evaluation of a QI intervention. [pmid: 1919278].
Noone P, Shafi MS. Controlling infection in a district general hospital. J Clin Pathol. 1973;26(2):140-5. Not an evaluation of a QI intervention. [pmid: 4487926]. [pmcid: 477670].
Nosocomial pneumonia in intubated patients. N Engl J Med. 1988;318(22):1465–7. Not an evaluation of a QI intervention
Noy D, Creedy D. Postdischarge surveillance of surgical site infections: a multi-method approach to data collection. Am J Infect Control. 2002;30(7):417-24. Not an evaluation of a QI intervention. [pmid: 12410219].
Nystrom B. Hospital infection control in Sweden. Chemotherapy. 1988;34(6):541-7. Not an evaluation of a QI intervention. [pmid: 3243097].
O'Grady NP, Gerberding JL, Weinstein RA, et al. Patient safety and the science of prevention: the time for implementing the Guidelines for the prevention of intravascular catheter-related infections is now. Crit Care Med. 2003;31(1):291-2. Not an evaluation of a QI intervention. [pmid: 12545031].
O'Grady NP. On the road to avoiding adverse events: educational programs pave the way. Crit Care Med. 2003;31(7):2077-8. Not an evaluation of a QI intervention. [pmid: 12847410].
O'Grady PN, Alexander M, Dellinger EP, et al. Guidelines for the prevention of intravascular catheter-related infections. Am J Infect Control. 2002;30(8):476-89. Not an evaluation of a QI intervention. [pmid: 12461511].
O'Riordan C, Adler JL, Banks HH, et al. A prospective study of wound infections on an orthopedic service with illustrative cases. Clin Orthop Relat Res. 1972;87:188-91. Not an evaluation of a QI intervention. [pmid: 5078029].
O'Riordan C, Adler JL, Banks HH, et al. Wound infections on an orthopedic service. A prospective study. Am J Epidemiol. 1972;95(5):442-50. Not an evaluation of a QI intervention. [pmid: 4259951].
Osmon SB, Kollef MH. Prevention of pneumonia in the hospital setting. Clin Chest Med. 2005;26(1):135-42. Not an evaluation of a QI intervention. [pmid: 15802175].
Oyama A. Intravenous line management and prevention of catheter-related infections in America. J Intraven Nurs. 2000;23(3):170-5. Not an evaluation of a QI intervention. [pmid: 11272974].
Panhotra BR, Saxena AK, Al-Arabi AAM. The effect of a continuous educational program on handwashing compliance among healthcare workers in an intensive care unit. Br J Infection Control. 2004;5(3):15. Other: out of scope.
Parienti JJ, Cheyron Dd, Ramakers M, et al. Alcoholic povidone-iodine to prevent central venous catheter colonization: A randomized unit-crossover study. Crit Care Med. 2004;32(3):708-13. Not an evaluation of a QI intervention. [pmid: 15090951].
Parienti JJ, Thibon P, Heller R, et al. Hand-rubbing with an aqueous alcoholic solution vs traditional surgical hand-scrubbing and 30-day surgical site infection rates: a randomized equivalence study. Jama. 2002;288(6):722-7. Not an evaluation of a QI intervention. [pmid: 12169076].
Parker LJ. Urinary catheter management: minimizing the risk of infection. Br J Nurs. 1999;8(9):563–6, 8, 70 passim. Not an evaluation of a QI intervention
Parker MJ, Pryor GA, Myles JW. The value of a special surgical team in preventing complications in the treatment of hip fractures. Int Orthop. 1994;18(3):184-8. Excluded topic. [pmid: 7927970].
Parkinson R, Gandhi M, Harper J, et al. Establishing an ultrasound guided peripherally inserted central catheter (PICC) insertion service. Clin Radiol. 1998;53(1):33-6. Not an evaluation of a QI intervention. [pmid: 9464433].
Perioperative red cell transfusion. Natl Inst Health Consens Dev Conf Consens Statement. 1988;7(4):1–6. Not an evaluation of a QI intervention
Philipneri M, Al-Aly Z, Amin K, et al. Routine replacement of tunneled, cuffed, hemodialysis catheters eliminates paraspinal/vertebral infections in patients with catheter-associated bacteremia. Am J Nephrol. 2003;23(4):202-7. Not an evaluation of a QI intervention. [pmid: 12771502].
Pick FC, Rose M, Wang D, et al. The prevention of spread of methicillin resistant Staphylococcus aureus in a spinal injuries centre. Paraplegia. 1994;32(11):732-5. Not an evaluation of a QI intervention. [pmid: 7885715].
Pingleton SK, Fagon JY, Leeper KVJ. Patient selection for clinical investigation of ventilator-associated pneumonia. Criteria for evaluating diagnostic techniques. Chest. 1992;102(5 Suppl 1):553S-6S. Not an evaluation of a QI intervention. [pmid: 1424929].
Piotrowski MM, Hinshaw DB. The safety checklist program: creating a culture of safety in intensive care units. Jt Comm J Qual Improv. 2002;28(6):306-15. Not an evaluation of a QI intervention. [pmid: 12066622].
Png DJ, Ong CL, Chan S. Surgical Nutritional Team and its impact on total parenteral nutrition in The National University Hospital, Singapore. International Journal of Clinical Practice. 1997;51:350. Other: no documentation of QI intervention. [pmid: 9489060].
Pons R, Blasco C, Jimenez J, et al. Nursing protocol for manipulation of haemodialysis catheters. Edtna Erca J. 1996;22(4):39-42. Not an evaluation of a QI intervention. [pmid: 10723350].
Prescott RJ, Ruckley CV, Garraway WM, et al. Functional assessment of patients undergoing day-care surgery for varicose veins or hernia: results from a randomised controlled trial. Health Bulletin. 1979;37(2):82. Excluded topic. [pmid: 220205].
Preventing infections associated with indwelling intravascular access devices. Can Commun Dis Rep. 1997;23 Suppl 8:i–iii, 1–32, i–iv, 1–16. Not an evaluation of a QI intervention
Price CS, Hacek D, Noskin GA, et al. An outbreak of bloodstream infections in an outpatient hemodialysis center. Infect Control Hosp Epidemiol. 2002;23(12):725-9. Not an evaluation of a QI intervention. [pmid: 12517014].
Pronovost PJ, Weast B, Bishop K, et al. Senior executive adopt-a-work unit: a model for safety improvement. Jt Comm J Qual Saf. 2004;30(2):59-68. Excluded topic. [pmid: 14986336].
Proposed recommended practices for surgical hand scrubs. Association of Operating Room Nurses. Aorn J. 1994;60(2):270, 3–6, 9–80. Not an evaluation of a QI intervention
Proposed recommended practices. Surgical scrubs. AORN Technical Practices Coordinating Committee. Aorn J. 1990;51(1):226–8, 30–4. Not an evaluation of a QI intervention
Quality Patrol. Keep it clean. Hosp Health Netw. 1997;71(19):21. Not an evaluation of a QI intervention
Quarrell EJ. Artificial ventilation. 3. Nursing care. Nurs Times. 1970;66(43):1360-2. Not an evaluation of a QI intervention. [pmid: 5470568].
Raad I, Darouiche R, Dupuis J, et al. Central venous catheters coated with minocycline and rifampin for the prevention of catheter-related colonization and bloodstream infections. A randomized, double-blind trial. The Texas Medical Center Catheter Study Group. Ann Intern Med. 1997;127(4):267-74. Not an evaluation of a QI intervention. [pmid: 9265425].
Raad I. Intravascular-catheter-related infections. Lancet. 1998;351(9106):893-8. Not an evaluation of a QI intervention. [pmid: 9525387].
Rackoff WR, Weiman M, Jakobowski D, et al. A randomized, controlled trial of the efficacy of a heparin and vancomycin solution in preventing central venous catheter infections in children. J Pediatr. 1995;127(1):147-51. Not an evaluation of a QI intervention. [pmid: 7608801].
Rahal JJ. Short-term therapy for intravascular catheter-related Staphylococcus aureus bacteremia. Clin Infect Dis. 2001;33(11):1946-7. author reply 9–51. Not an evaluation of a QI intervention. [pmid: 11692309].
Raine SJ. Quality assurance and the role of infection control: a retrospective study of hospital-acquired infection in a District General Hospital based on three sites, 1978-1988. J Hosp Infect. 1991;19(1):49-61. Not an evaluation of a QI intervention. [pmid: 1684597].
Rakshi K, Couriel JM. Management of acute bronchiolitis. Arch Dis Child. 1994;71(5):463-9. Not an evaluation of a QI intervention. [pmid: 7826123]. [pmcid: 1030068].
Rantala A, Lehtonen OP, Niinikoski J. Alcohol abuse: a risk factor for surgical wound infections?. Am J Infect Control. 1997;25(5):381-6. Not an evaluation of a QI intervention. [pmid: 9343620].
Raphaely RC. Acute respiratory failure in infants and children. Pediatr Ann. 1986;15(4):315-21. Not an evaluation of a QI intervention. [pmid: 3520455].
Recommended practices. Surgical attire. AORN Technical Practices Coordinating Committee. Aorn J. 1990;51(3):828, 30, 32 passim. Not an evaluation of a QI intervention
Recommended practices. Surgical hand scrubs. AORN Recommended Practices Coordinating Committee. Aorn J. 1990;52(4):830–6. Not an evaluation of a QI intervention
Reilly J, Noone A, Clift A, et al. A study of telephone screening and direct observation of surgical wound infections after discharge from hospital. J Bone Joint Surg Br. 2005;87(7):997-9. Not an evaluation of a QI intervention. [pmid: 15972920].
Reilly JS. The effect of surveillance on surgical wound infection rates. J Tissue Viability. 1999;9:57-60. Duplicate publication. [pmid: 10480972].
Reinarz JA. Nosocomial infections. Clin Symp. 1978;30(6):1-35. Not an evaluation of a QI intervention. [pmid: 371904].
Rello J, Diaz E. Optimal use of antibiotics for intubation-associated pneumonia. Intensive Care Med. 2001;27(2):337-9. Not an evaluation of a QI intervention. [pmid: 11396275].
Rello J. Acinetobacter baumannii infections in the ICU: customization is the key. Chest. 1999;115(5):1226-9. Not an evaluation of a QI intervention. [pmid: 10334129].
Rello J. Impact of nosocomial infections on outcome: myths and evidence. Infect Control Hosp Epidemiol. 1999;20(6):392-4. Not an evaluation of a QI intervention. [pmid: 10395139].
Reprocessing of flexible gastrointestinal endoscopes. American Society for Gastrointestinal Endoscopy. Gastrointest Endosc. 1996;43(5):540–5. Not an evaluation of a QI intervention
Reynolds HY. Prevention and future control of hospital-associated infections commonly caused by gram-negative bacteria. Prev Med. 1974;3(4):507-14. Not an evaluation of a QI intervention. [pmid: 4216016].
Rigdon RO. Protocols for the prevention of intravascular device-related infections. Crit Care Nurs Q. 2001;24(2):39-47. Not an evaluation of a QI intervention. [pmid: 11858421].
Rijnders B. Diagnosis of catheter-related bacteremia in cancer patients. J Clin Microbiol. 2001;39(8):3022. Not an evaluation of a QI intervention. [pmid: 11499396]. [pmcid: 88289].
Rijnders BJ, Wijngaerden EV, Vandecasteele SJ, et al. Treatment of long-term intravascular catheter-related bacteraemia with antibiotic lock: randomized, placebo-controlled trial. J Antimicrob Chemother. 2005;55(1):90-4. Not an evaluation of a QI intervention. [pmid: 15574481].
Rijnders BJ, Wijngaerden EV, Vandecasteele SJ, et al. Uncertainties and future research topics in the management of suspected catheter-related infection. Clin Infect Dis. 2001;33(11):1946. author reply 9–51. Not an evaluation of a QI intervention.
Rijnders BJ. Catheter-related infection can be prevented...if we take the arterial line seriously too!. Crit Care Med. 2005;33(6):1437-9. Not an evaluation of a QI intervention. [pmid: 15942377].
Ringham S. The ambulant catheterised patient in hospital. Nurs Times. 1984;80(37):suppl 11-2. Not an evaluation of a QI intervention.
Roberts FJ, Walsh A, Wing P, et al. The influence of surveillance methods on surgical wound infection rates in a tertiary care spinal surgery service. Spine. 1998;23(3):366-70. Not an evaluation of a QI intervention. [pmid: 9507627].
Roberts RB. The anaesthetist, cross-infection and sterilization techniques—a review. Anaesth Intensive Care. 1973;1(5):400-6. Not an evaluation of a QI intervention. [pmid: 4586717].
Roe B. Catheter care: an overview. Int J Nurs Stud. 1985;22(1):45-56. Not an evaluation of a QI intervention. [pmid: 3844384].
Roggla G, Roggla M. Semirecumbent position in intensive care patients. Lancet. 2000;355(9208):1012. author reply 3. Not an evaluation of a QI intervention. [pmid: 10768453].
Rosen MJ. AIDS: pulmonary complications and intensive care. Acute Care. 1988;14–15:229-43. Not an evaluation of a QI intervention.
Rosenfeld BA, Dorman T, Breslow MJ, et al. Intensive care unit telemedicine: alternate paradigm for providing continuous intensivist care. Crit Care Med. 2000;28(12):3925-31. Not an evaluation of a QI intervention. [pmid: 11153637].
Rosenthal VD, Guzman S, Safdar N. Reduction in nosocomial infection with improved hand hygiene in intensive care units of a tertiary care hospital in Argentina. Am J Infect Control. 2005;33:392-7. Duplicate publication. [pmid: 16153485].
Rubinson L, Diette GB. Best practices for insertion of central venous catheters in intensive-care units to prevent catheter-related bloodstream infections. J Lab Clin Med. 2004;143(1):5-13. Not an evaluation of a QI intervention. [pmid: 14749680].
Rumbak MJ, Cancio MR. Significant reduction in methicillin-resistant Staphylococcus aureus ventilator-associated pneumonia associated with the institution of a prevention protocol. Crit Care Med. 1995;23(7):1200-3. No eligible outcomes. [pmid: 7600827].
Rupp ME, Fitzgerald T, Marion N, et al. Effect of silver-coated urinary catheters: efficacy, cost-effectiveness, and antimicrobial resistance. Am J Infect Control. 2004;32(8):445-50. Not an evaluation of a QI intervention. [pmid: 15573050].
Rupp ME, Lisco SJ, Lipsett PA, et al. Effect of a second-generation venous catheter impregnated with chlorhexidine and silver sulfadiazine on central catheter-related infections: a randomized, controlled trial. Ann Intern Med. 2005;143(8):570-80. Not an evaluation of a QI intervention. [pmid: 16230723].
Ryan RM, Maduako K, White C, et al. Routine monitoring of all postoperative outcomes at one year: longitudinal study at the Royal National Throat, Nose and Ear Hospital. Bmj. 1996;313(7054):403. Not an evaluation of a QI intervention. [pmid: 8761231]. [pmcid: 2351794].
Sabui T, Tudehope D, Lennon I. Recurrent late onset group B streptococcal infection with parotitis. J Paediatr Child Health. 1999;35(2):224-5. Not an evaluation of a QI intervention. [pmid: 10365369].
Safdar N. Bloodstream infection: an ounce of prevention is a ton of work. Infect Control Hosp Epidemiol. 2005;26(6):511-4. Not an evaluation of a QI intervention. [pmid: 16018424].
Saint S, Savel RH, Matthay MA. Enhancing the safety of critically ill patients by reducing urinary and central venous catheter-related infections. Am J Respir Crit Care Med. 2002;165(11):1475-9. Not an evaluation of a QI intervention. [pmid: 12045119].
Salgado C, Giannetta E, Hayden F, et al. Preventing nosocomial influenza by improving the vaccine acceptance rate of clinicians. Infection Control and Hospital Epidemiology. 2004;25(11):923. Excluded topic. [pmid: 15566025].
Sanderson PJ. Preventing hospital acquired urinary and respiratory infection. Bmj. 1995;310(6992):1452-3. Not an evaluation of a QI intervention. [pmid: 7613281]. [pmcid: 2549818].
Schmidt JM, Schimpeler SM. Obstetric and gynecologic abdominal wound infections: a comprehensive nurse-managed program. J Perinat Neonatal Nurs. 1990;4(3):25-43. Not an evaluation of a QI intervention. [pmid: 2243325].
Schurink CA, Lucas PJ, Hoepelman IM, et al. Computer-assisted decision support for the diagnosis and treatment of infectious diseases in intensive care units. Lancet Infect Dis. 2005;5(5):305-12. Not an evaluation of a QI intervention. [pmid: 15854886].
Segura M, Alvarez-Lerma F, Tellado JM, et al. A clinical trial on the prevention of catheter-related sepsis using a new hub model. Ann Surg. 1996;223(4):363-9. Not an evaluation of a QI intervention. [pmid: 8633914]. [pmcid: 1235131].
Seto WH, Ching TY, Yuen KY, et al. The enhancement of infection control in-service education by ward opinion leaders. Am J Infect Control. 1991;19:86-91. Duplicate publication. [pmid: 2053717].
Sharek PJ, Benitz WE, Abel NJ, Freeburn MJ, Mayer ML, Bergman DA. Effect of an evidence-based hand washing policy on hand washing rates and false-positive coagulase negative staphylococcus blood and cerebrospinal fluid culture rates in a level III NICU. J Perinatol. 2002;22(2):137-43. Other: out of scope. [pmid: 11896519].
Sherman RA, Flynn NM, Bradford M, et al. Multilumen catheter sepsis and an educational program to combat it. Am J Infect Control. 1988;16(4):31A-4A. No eligible outcomes.
Shoji KT, Axnick K, Rytel MW. Infections and antibiotic use in a large municipal hospital 1970-1972: a prospective analysis of the effectiveness of a continuous surveillance program. Health Lab Sci. 1974;11(4):283-92. Not an evaluation of a QI intervention. [pmid: 4413855].
Shorr AF, Kollef MH. Ventilator-associated pneumonia: insights from recent clinical trials. Chest. 2005;128(5 Suppl 2):583S-91S. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 16306057].
Should you consider a bloodless program? Hosp Peer Rev. 1998;23(9):163–8. Not an evaluation of a QI intervention
Siebert WT. Practical ways to avoid hospital acquired infections. Med Times. 1977;105(7):(82)15d-(82)23d. Not an evaluation of a QI intervention.
Simchen E, Zucker D, Siegman IY, et al. Method for separating patient and procedural factors while analyzing interdepartmental differences in rates of surgical infections: the Israeli Study of Surgical Infection in Abdominal Operations. J Clin Epidemiol. 1996;49(9):1003-7. Not an evaluation of a QI intervention. [pmid: 8780608].
Souvignet C, Frebourg G, Baril L. Identifying patients with severe hospital-acquired infections due to Staphylococcus aureus by using the Healthcare Cost and Utilization Project (HCUP): problems and pitfalls. Infect Control Hosp Epidemiol. 2004;25(6):450-1. Not an evaluation of a QI intervention. [pmid: 15242188].
Srinivasan A, Karchmer T, Richards A, et al. A prospective trial of a novel, silicone-based, silver-coated foley catheter for the prevention of nosocomial urinary tract infections. Infect Control Hosp Epidemiol. 2006;27(1):38-43. Not an evaluation of a QI intervention. [pmid: 16418985].
Staph with lower vancomycin resistance in US. OR Manager. 1997;13(10):7. Not an evaluation of a QI intervention
Stevens E. Bladder ultrasound: avoiding unnecessary catheterizations. Medsurg Nurs. 2005;14(4):249-53. Not an evaluation of a QI intervention. [pmid: 16206895].
Stickler DJ. The role of antiseptics in the management of patients undergoing short-term indwelling bladder catheterization. J Hosp Infect. 1990;16(2):89-108. Not an evaluation of a QI intervention. [pmid: 1976689].
Stiletto RJ. Bacterial colonization of the respiratory tract under artificial ventilation: is there proof of clinically relevant effects of the endotracheal tube orientation under positioning therapy?. Crit Care Med. 2003;31(3):973-4. Not an evaluation of a QI intervention. [pmid: 12627016].
Stone J, Manasse R. Pseudoepidemic of urinary tract infections due to Trichosporon beigelii. Infect Control Hosp Epidemiol. 1989;10(7):312-5. Not an evaluation of a QI intervention. [pmid: 2663974].
Stone SP. Hand hygiene—the case for evidence-based education. J R Soc Med. 2001;94(6):278-81. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 11387416]. [pmcid: 1281522].
Strandvik G, Mayall M. Safer central venous access. Anaesthesia. 2005;60(6):618-9. author reply 9. Not an evaluation of a QI intervention. [pmid: 15948323].
Strieter RM, Lynch JP. Complications in the ventilated patient. Clin Chest Med. 1988;9(1):127-39. Not an evaluation of a QI intervention. [pmid: 3280226].
Stronge JL. Infection of the urinary tract associated with catheters. Nurs Times. 1976;72(11):426-7. Not an evaluation of a QI intervention. [pmid: 1264747].
Stucke VA, Thompson RE. Infection transfer by respiratory condensate during positive pressure respiration. Nurs Times. 1980;76(9):suppl 13 3–4. Not an evaluation of a QI intervention
Study examines policy; how well is it followed? Hosp Infect Control. 1981;8(1):67. Not an evaluation of a QI intervention
Sujijantararat R, Booth RZ, Davis LL. Nosocomial urinary tract infection: nursing-sensitive quality indicator in a Thai hospital. J Nurs Care Qual. 2005;20(2):134-9. Not an evaluation of a QI intervention. [pmid: 15839292].
Summaries for patients. Can antibiotic-coated catheters help decrease the incidenceof bloodstream infections in patients in the intensive care unit? Ann Intern Med. 2005;143(8):I36. Not an evaluation of a QI intervention
Surin VV. Effect of different surveillance methods on statistics of postoperative wound infections. J Hosp Infect. 1988;11(2):116-20. Not an evaluation of a QI intervention. [pmid: 2896678].
Surveillance cultures in neutropenia. Lancet. 1989;1(8649):1238–9. Not an evaluation of a QI intervention
Suwitra K. Catheter associated fungal urinary tract infection. Acta Med Indones. 2004;36(2):97-9. Not an evaluation of a QI intervention. [pmid: 15673943].
Swoboda S, Earsing K, Strauss K, et al. Electronic monitoring and voice prompts improve hand hygiene and decrease nosocomial infections in an intermediate care unit. Critical Care Medicine. 2004;32(2):358. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 14758148].
Tambyah PA. Catheter-associated urinary tract infections: diagnosis and prophylaxis. Int J Antimicrob Agents. 2004;24(Suppl 1):S44-8. Not an evaluation of a QI intervention. [pmid: 15364306].
Taneja N, Rani P, Emmanuel R, et al. Nosocomial urinary tract infection due to Leuconostoc mesenteroides at a tertiary care centre in north India. Indian J Med Res. 2005;122(2):178-9. Not an evaluation of a QI intervention. [pmid: 16177477].
Tanowitz HB, Weiss LM, Currie BP. Rational approaches to antibiotic therapy of ventilator-associated pneumonias. Crit Care Med. 2001;29(6):1277-8. Not an evaluation of a QI intervention. [pmid: 11395620].
Tebbs SE, Moss H, Faroqui MH, et al. Central-venous-catheter related bacteraemia. Lancet. 1995;345(8952):800-1. Not an evaluation of a QI intervention. [pmid: 7891513].
The control of hospital infection with mechanical ventilation. Health Estate. 2000;54(7):29–30. Not an evaluation of a QI intervention
Thibon P, Coutour XL, Leroyer R, et al. Randomized multi-centre trial of the effects of a catheter coated with hydrogel and silver salts on the incidence of hospital-acquired urinary tract infections. J Hosp Infect. 2000;45(2):117-24. Not an evaluation of a QI intervention. [pmid: 10860688].
Thompson D, Holzmueller C, Hunt D, et al. A morning briefing: setting the stage for a clinically and operationally good day. Jt Comm J Qual Patient Saf. 2005;31(8):476-9. Not an evaluation of a QI intervention. [pmid: 16156196].
Thompson DA, Lubomski L, Holzmueller C, et al. Integrating the intensive care unit safety reporting system with existing incident reporting systems. Jt Comm J Qual Patient Saf. 2005;31(10):585-93. Not an evaluation of a QI intervention. [pmid: 16294671].
Tobin MJ. Critical care medicine in AJRCCM 2000. Am J Respir Crit Care Med. 2001;164(8 Pt 1):1347-61. Not an evaluation of a QI intervention. [pmid: 11704579].
Tobin MJ. Critical care medicine in AJRCCM 2002. Am J Respir Crit Care Med. 2003;167(3):294-305. Not an evaluation of a QI intervention. [pmid: 12554619].
Todd B. Preventing bloodstream infection. Am J Nurs. 2006;106(1):29-30. Not an evaluation of a QI intervention.
Todd J, Bertoch D, Dolan S. Use of a large national database for comparative evaluation of the effect of a bronchiolitis/viral pneumonia clinical care guideline on patient outcome and resource utilization. Archives of Pediatrics & Adolescent Medicine. 2002;156(11):1086. Not an evaluation of a QI intervention. [pmid: 12413334].
Todd J. Evaluation of the introduction of the Groshong central venous catheter into the oncology/haematology department of a district general hospital. Eur J Cancer Care (Engl). 1997;6(3):215-21. Not an evaluation of a QI intervention. [pmid: 9335673].
Toldos CM, Ortiz G, Camara M, et al. Application of pulsed-field gel electrophoresis in an outbreak of infection due to Klebsiella oxytoca. J Med Microbiol. 1997;46(10):889-90. Not an evaluation of a QI intervention. [pmid: 9364148].
Toltzis P, Blumer JL. Preventing central venous line infections by altering the composition of the infusate. Crit Care Med. 1999;27(9):2036-8. Not an evaluation of a QI intervention. [pmid: 10507644].
Tomic V, Svetina Sorli P, Trinkaus D, et al. Comprehensive strategy to prevent nosocomial spread of methicillin-resistant Staphylococcus aureus in a highly endemic setting. Archives of Internal Medicine. 2004;164(18):2038-43. No eligible outcomes. [pmid: 15477440].
Torres A, Carlet J. Ventilator-associated pneumonia. European Task Force on ventilator-associated pneumonia. Eur Respir J. 2001;17(5):1034-45. Not an evaluation of a QI intervention. [pmid: 11488306].
Torres A, Gonzalez J, Ferrer M. Evaluation of the available invasive and non-invasive techniques for diagnosing nosocomial pneumonias in mechanically ventilated patients. Intensive Care Med. 1991;17(8):439-48. Not an evaluation of a QI intervention. [pmid: 1797886].
Trick WE, Weinstein RA. Intravascular catheter use. How to tell when the medicine is worse than the malady. Am J Respir Crit Care Med. 2001;163(7):1515-6. Not an evaluation of a QI intervention. [pmid: 11401863].
Tulaimat A, Mokhlesi B. Noninvasive ventilation for persistent weaning failure. Am J Respir Crit Care Med. 2004;169(9):1073. author reply -4. Not an evaluation of a QI intervention. [pmid: 15107307].
Tuteur PG. Pneumonia after coronary artery bypass grafting: a case for continued evaluation. Ann Thorac Surg. 1991;51(2):177-8. Not an evaluation of a QI intervention. [pmid: 1671194].
Universal precautions for preventing transmission of bloodborne pathogens in healthcare facilities: report of a consensus committee meeting. Cmaj. 1989;140(7):824–6. Not an evaluation of a QI intervention
Valenti WM. AIDS: problem solving in infection control. Infection control, human immunodeficiency virus, and home health care: I. Infection risk to the patient. Am J Infect Control. 1994;22(6):371-2. Not an evaluation of a QI intervention. [pmid: 7695117].
Vandenbroucke-Grauls CM. Towards better prevention of pneumonia in the intensive care unit?. Lancet. 1993;341(8850):932. Not an evaluation of a QI intervention. [pmid: 8096272].
Veenstra DL, Saint S, Saha S, et al. Efficacy of antiseptic-impregnated central venous catheters in preventing catheter-related bloodstream infection: a meta-analysis. Jama. 1999;281(3):261-7. Not an evaluation of a QI intervention. [pmid: 9918482].
Vovan TT, Brenner M, Chen JC. Acidified enteral feeds: is it physiologic?. Crit Care Med. 1999;27(11):2577-8. Not an evaluation of a QI intervention. [pmid: 10579288].
Wagner DP, Knaus WA. Mortality in nosocomial urinary-tract infection. N Engl J Med. 1983;308(2):102-3. Not an evaluation of a QI intervention. [pmid: 6847932].
Walder B, Pittet D, Tramer MR. Prevention of bloodstream infections with central venous catheters treated with anti-infective agents depends on catheter type and insertion time: evidence from a meta-analysis. Infect Control Hosp Epidemiol. 2002;23(12):748-56. Not an evaluation of a QI intervention. [pmid: 12517018].
Walter CW. Cross-infection and the anesthesiologist. Twelfth annual Baxter-Travenol Lecture. Anesth Analg. 1974;53(5):631-44. Not an evaluation of a QI intervention. [pmid: 4606396].
Warren DK, Kollef MH. Prevention of hospital infection. Microbes Infect. 2005;7(2):268-74. Not an evaluation of a QI intervention. [pmid: 15725388].
Warren JW. Catheter-associated bacteriuria. Clin Geriatr Med. 1992;8(4):805-19. Not an evaluation of a QI intervention. [pmid: 1423136].
Warren JW. Catheter-associated urinary tract infections. Infect Dis Clin North Am. 1997;11(3):609-22. Not an evaluation of a QI intervention. [pmid: 9378926].
Warren JW. Catheter-associated urinary tract infections. Int J Antimicrob Agents. 2001;17(4):299-303. Not an evaluation of a QI intervention. [pmid: 11295412].
Warren JW. Urethral catheters, condom catheters, and nosocomial urinary tract infections. Infect Control Hosp Epidemiol. 1996;17(4):212-4. Not an evaluation of a QI intervention. [pmid: 8935727].
Wenzel RP, Edmond MB. The evolving technology of venous access. N Engl J Med. 1999;340(1):48-50. Not an evaluation of a QI intervention. [pmid: 9878645].
Widmer AF. Infection control and prevention strategies in the ICU. Intensive Care Med. 1994;20(Suppl 4):S7-11. Not an evaluation of a QI intervention. [pmid: 7699156].
Wilkes AR, Stevens AJ. Breathing system filters used with Entonox. Anaesthesia. 2000;55(8):817-8. Not an evaluation of a QI intervention. [pmid: 10947710].
Willis J. Catheters—urinary tract infections. Nurs Times. 1995;91(35):48, 50. Not an evaluation of a QI intervention
Wilson M. Catheterisation under scrutiny. Nurs Times. 1990;86(49):71-2. Not an evaluation of a QI intervention. [pmid: 2255633].
Wilson M. Control of infection in catheterisation. Community Nurse. 1996;2(2):31-2. Not an evaluation of a QI intervention. [pmid: 9445685].
Wing AJ. Infections of the urinary tract. II. Management. Br Med J. 1970;4(726):35-8. Not an evaluation of a QI intervention. [pmid: 4919120].
Woodrow P. Will nursing ICU patients in semi-recumbent positions reduce rates of nosocomial infection?. Nurs Crit Care. 2000;5(4):174-8. Not an evaluation of a QI intervention. [pmid: 11235413].
Wu A, Pronovost P. Telling patients the truth. Health Aff (Millwood). 2003;22(3):249. author reply Not an evaluation of a QI intervention. [pmid: 12757291].
Wyatt TD, Timoney R. The effect of introducing a policy for catheter care on the catheter infection rate in a small hospital. J Hosp Infect. 1987;9(3):230-4. Not an evaluation of a QI intervention. [pmid: 2886526].
Yap FH, Gomersall CD, Fung KS, et al. Increase in methicillin-resistant Staphylococcus aureus acquisition rate and change in pathogen pattern associated with an outbreak of severe acute respiratory syndrome. Clin Infect Dis. 2004;39(4):511-6. Not an evaluation of a QI intervention. [pmid: 15356814].
Yucel N, Lefering R, Maegele M, et al. Reduced colonization and infection with miconazole-rifampicin modified central venous catheters: a randomized controlled clinical trial. J Antimicrob Chemother. 2004;54(6):1109-15. Not an evaluation of a QI intervention. [pmid: 15537696].
Zimmerman JL. Problem-solving approach to adult respiratory distress syndrome. New Horiz. 1993;1(4):578-83. Not an evaluation of a QI intervention. [pmid: 8087577].
Zuschneid I, Schwab F, Geffers C, et al. Reducing central venous catheter-associated primary bloodstream infections in intensive care units is possible: data from the German nosocomial infection surveillance system. Infect Control Hosp Epidemiol. 2003;24(7):501-5. Study design did not meet criteria for RCT, CBA, ITS or SBA. [pmid: 12887238].