# Literature Search Strategy

Date: 2/13/06

#1 | Patient-Centered Care [mh] or Progressive Patient Care [mh] or Critical Pathways [mh] or Delivery of Health Care, Integrated [mh] or Patient Care Team [mh] or Behavior Control [mh] or ((coordination [tw] or coordinated [tw] or Multifactorial [tw] or Multi-factorial [tw] or Multicomponent [tw] or Multi-component [tw] or multidisciplinary [tw] or multi-disciplinary [tw] or interdisciplinary [tw] or inter-disciplinary [tw] or integrated [tw] or community-based [tw] or organized [tw] or comprehensive [tw]) and (program*[tw] or care [tw] or approach [tw] or intervention [tw] or strategy [tw] or strategies [tw] or management [tw] or managing [tw] or center*[tw])) or Organization and Administration [mh] or bundle*[tw] | 813885
targets QI strategies that tend to be multi-factorial using relevant MeSH terms and title words
#2 | Total Quality Management [mh] OR Quality control [mh] OR TQM [tw] OR CQI [tw] OR (quality [tw] AND (continuous [tw] OR total [tw]) AND (management [tw] OR improvement [tw])) | 41902
targets TQM and CQI
#3 | Education, Continuing [mh] OR Education, Nursing [mh] OR Education, Medical [mh] OR Inservice Training [mh] OR Programmed Instruction [mh] OR ((Education [tw]AND Continuing [tw]) AND (medical [tw] OR professional* [tw] OR nursing [tw] OR physician* [tw] OR nurse* [tw])) OR (outreach [tw] AND (visit* [tw] OR educational [tw]) OR (academic [tw] AND detailing [tw])) | 170009
targets provider education
#4 | Diffusion of Innovation [mh] OR (Diffusion [ti] AND (Innovation [ti] OR technology [ti])) | 6710
targets diffusion of innovation
#5 | Medical audit [mh] OR ((Audit [tw] OR feedback [tw] OR compliance [tw] OR adherence [tw] OR training [tw]) AND (improvement* [tw] OR improving [tw] OR improves [tw] OR improve [tw] OR guideline* [tw] OR practice* [tw] OR medical [tw] OR provider* [tw] OR physician* [tw] OR nurse* [tw] OR clinician* [tw] OR academic [tw] OR visit* [tw])) OR Reminder Systems [mh] OR Reminder* [tw] OR ((financial [tw] OR economic [tw] OR physician* [tw] OR patient*) AND incentive* [tw]) OR Reimbursement Mechanisms [mh] or Guideline Adherence [mh] OR practice guidelines [mh] | 184663
targets audit & feedback, reminder systems, and financial incentives
#6 | Medical Informatics [mh] OR computer [tw] OR (decision [tw] AND (support [tw] or analysis [tw)) | 345989
#7 | #1 or #2 or #3 Or #4 or #5 or #6 | 1326026
All QI studies
#8 | Surgical wound infection[mh] OR surgical site infection*[tiab] OR postoperative infection*[ti] OR postsurgical infection*[ti] OR wound infection*[ti] OR sternal wound infection*[tiab] OR postoperative[ti] OR post-surgical[ti] | 59870
Surgical site infection terms
#9 | #7 AND #8 | 3438
Combination of QI terms with SSI terms
#10 | Randomised [ti] OR Randomized [ti] OR Controlled [ti] OR intervention [ti] OR evaluation [ti] OR impact [ti] OR effectiveness [ti] OR Evaluation [ti] OR Studies [ti] OR study [ti] Comparative [ti] OR Feasibility [ti] OR Program [ti] OR Design [ti] OR Clinical Trial [pt] OR Randomized Controlled Trial [pt] OR Epidemiologic Studies [mh] OR Evaluation Studies [mh] OR Comparative Study [mh] OR Feasibility Studies [mh] OR Intervention Studies [mh] OR Program Evaluation [mh] OR Epidemiologic Research Design [mh] | 2702355
RCT search
#11 | ((meta-analysis [pt] OR meta-analysis [tw] OR metanalysis [tw]) OR ((review [pt] OR guideline [pt] OR consensus [ti] OR guideline* [ti] OR literature [ti] OR overview [ti] OR review [ti] OR Decision Support Techniques [mh]) AND ((Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw])) OR (handsearch* [tw] OR search* [tw] OR searching [tw]) AND (hand [tw] OR manual [tw] OR electronic [tw] OR bibliographi* [tw] OR database* OR (Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw]))))) OR ((synthesis [ti] OR overview [ti] OR review [ti] OR survey [ti]) AND (systematic [ti] OR critical [ti] OR methodologic [ti] OR quantitative [ti] OR qualitative [ti] OR literature [ti] OR evidence [ti] OR evidence-based [ti]))) BUTNOT (editorial [pt] OR comment [pt] OR letter [pt]) | 89605
Meta-analysis, systematic review search
#12 | #10 OR #11 | 2766210
All original research
#13 | #9 AND #12 | 1837
Combination of QI terms with SSI terms, limited to original research only
#14 | #13 AND Limits: English | 1532
#SSI/QI search limited to English only
#15 | (Catheterization, Central Venous [MeSH] OR central line*[ti] OR central venous catheter*[ti]) AND (Cross infection [mh] OR bacteremia [mh] OR nosocomial [tiab] OR “healthcare associated”[tiab] OR “hospital acquired”[tiab] OR bundle[tiab]) | 829
CLABSI search
(restrict to English only)
#16 | (Respiration, Artificial[mh] OR mechanically ventilated*[ti] OR intubated*[ti] OR mechanical ventilation*[ti] or ventilator associated*[ti]) AND (Cross infection [mh] OR bacteremia [mh] OR nosocomial [tiab] OR “healthcare associated”[tiab] OR “hospital acquired”[tiab] OR bundle[tiab] ) | 1034
VAP search
(restrict to English only)
#17 | (Urinary catheterization[mh] OR urinary catheter*[tiab]) AND (Cross infection [mh] OR bacteremia [mh] OR nosocomial [tiab] OR “hospital-acquired”[tiab] OR “healthcare-associated”[tiab] OR bundle[tiab]) | 602
UCUTI search
(restrict to English only)

Supplemental searches

#S1 | Cross infection[mh] AND systematic[sb] | 401
Nosocomial infection systematic reviews (limited to English only)
#S2 | Handwashing[mh] AND systematic[sb] | 60
Handwashing systematic reviews (limited to English only)
#S3 | Pronovost p[au] OR Gastmeier P[au] OR Gyssens IC[au] | 220
Author searches
| #14 OR #15 OR #16 OR #17 OR #S1 OR #S2 OR #S3
TOTAL CITATIONS | | 4678
(#14 +#16 +#18 + #20 +#S1 +#S2)