# Appendixes

Appendix A Literature Search Strategy

Appendix B Sample Data Abstraction Forms

Appendix C Listing of Excluded Studies

Appendix D Technical Experts and Peer Reviewers