# Included Articles

Adams RJ, Boath K, Homan S, et al. A randomized trial of peak-flow and symptom-based action plans in adults with moderate-to-severe asthma. Respirology. Dec. 2001;6(4):297-304. [pmid: 11844120].
Agrawal SK, Singh M, Mathew JL, et al. Efficacy of an individualized written home-management plan in the control of moderate persistent asthma: a randomized, controlled trial. Acta Paediatr. Dec. 2005;94(12):1742-1746. [pmid: 16421033].
Alexander J, Younger R, Cohen R, et al. Effectiveness of a nurse-managed program for children with chronic asthma. J Pediatr Nurs. 1988;3(5):312-317. [pmid: 3171895].
Allen RM, Jones MP, Oldenburg B. Randomised trial of an asthma self-monitoring or self-management programme for adults. Thorax. Jul. 1995;50(7):731-738. [pmid: 7570406]. [pmcid: 474644].
Anderson ME, Freas MR, Wallace AS, et al. Successful school-based intervention for inner-city children with persistent asthma. J Asthma. Jun. 2004;41(4):445-453. [pmid: 15281330].
Ayres JG, Campbell LM. A controlled assessment of an asthma self-monitoring or self-management plan involving a budesonide dose regimen. OPTIONS Research Group. Eur Respir J. May. 1996;9(5):886-892. [pmid: 8793447].
Bailey WC, Kohler CL, Richards JM Jr, et al. Asthma self-monitoring or self-management: do patient education programs always have an impact?. Arch Intern Med. Nov 8. 1999;159(20):2422-2428. [pmid: 10665890].
Bailey WC, Richards JM Jr, et al. A randomized trial to improve self-monitoring or self-management practices of adults with asthma. Arch Intern Med. Aug. 1990;150(8):1664-1668. [pmid: 2200380].
Baldwin D. Outcome of asthmatics attending asthma clinics utilising self-monitoring or self-management plans in general practice. Asthma in Gen Pract. 1997;5:31-32.
Barbanel D, Eldridge S, Griffiths C. Can a self-monitoring or self-management programme delivered by a community pharmacist improve asthma control? A randomised trial. Thorax. Oct. 2003;58(10):851-854. [pmid: 14514935]. [pmcid: 1746491].
Baren JM, Shofer FS, Ivey B, et al. A randomized, controlled trial of a simple emergency department intervention to improve the rate of primary care follow-up for patients with acute asthma exacerbations. Ann Emerg Med. Aug. 2001;38(2):115-122. [pmid: 11468604].
Bartholomew LK, Gold RS, Parcel GS, et al. Watch, Discover, Think, and Act: evaluation of computer-assisted instruction to improve asthma self-monitoring or self-management in inner-city children. Patient Educ Couns. Feb. 2000;39(23):269-280. [pmid: 11040726].
Berg J, Dunbar-Jacob J, Sereika SM. An evaluation of a self-monitoring or self-management program for adults with asthma. Clin Nurs Res. Aug. 1997;6(3):225-238. [pmid: 9281927].
Bheekie A, Syce JA, Weinberg EG. Peak expiratory flow rate and symptom self-monitoring of asthma initiated from community pharmacies. J Clin Pharm Ther. Aug. 2001;26(4):287-296. [pmid: 11493372].
Bolton MB, Tilley BC, Kuder J, et al. The cost and effectiveness of an education program for adults who have asthma. J Gen Intern Med. Sep–Oct. 1991;6(5):401-407. [pmid: 1744753].
Bonner S, Zimmerman BJ, Evans D, et al. An individualized intervention to improve asthma management among urban Latino and African-American families. J Asthma. Apr. 2002;39(2):167-179. [pmid: 11990232].
Brook U, Mendelberg A, Heim M. Increasing parental knowledge of asthma decreases the hospitalization of the child: a pilot study. J Asthma. 1993;30(1):45-49. [pmid: 8428857].
Brown JV, Bakeman R, Celano MP, et al. Home-based asthma education of young low-income children and their families. J Pediatr Psychol. Dec. 2002;27(8):677-688. [pmid: 12403858].
Brown R, Bratton SL, Cabana MD, et al. Physician asthma education program improves outcomes for children of low-income families. Chest. 2004;126(2):369-374. [pmid: 15302719].
Bryce FP, Neville RG, Crombie IK, et al. Controlled trial of an audit facilitator in diagnosis and treatment of childhood asthma in general practice see comments. BMJ. Apr 1. 1995;310(6983):838. [pmid: 7711623]. [pmcid: 2549220].
Buckingham K, Drummond N, Cameron I, et al. Costing shared care. Health Serv Manage. Feb. 1994;90(2):22. [pmid: 10134424].
Burkhart PV, Dunbar-Jacob JM, Fireman P, et al. Children's adherence to recommended asthma self-monitoring or self-management. Pediatr Nurs. Jul–Aug. 2002;28(4):409-414. [pmid: 12226965].
Butz A, Pham L, Lewis L, et al. Rural children with asthma: impact of a parent and child asthma education program. J Asthma. Dec. 2005;42(10):813-821. [pmid: 16393717]. [pmcid: 2276310].
Butz AM, Syron L, Johnson B, et al. Home-based asthma self-monitoring or self-management education for inner city children. Public Health Nurs. May–Jun. 2005;22(3):189-199. [pmid: 15982192].
Bynum A, Hopkins D, Thomas A, et al. The effect of telepharmacy counseling on metered-dose inhaler technique among adolescents with asthma in rural Arkansas. Telemed J E Health. 2001;7(3):207-217. [pmid: 11564356].
Cambach W, Chadwick-Straver RV, Wagenaar RC, et al. The effects of a community-based pulmonary rehabilitation programme on exercise tolerance and quality of life: a randomized controlled trial. Eur Respir J. Jan. 1997;10(1):104-113. [pmid: 9032501].
Catov JM, Marsh GM, Youk AO, et al. Asthma home teaching: two evaluation approaches. Dis Manag. Jun. 2005;8(3):178-187. [pmid: 15966783].
Chan DS, Callahan CW, Sheets SJ, et al. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. Oct 1. 2003;60(19):1976-1981. [pmid: 14531243].
Charlton I, Antoniou AG, Atkinson J, et al. Asthma at the interface: bridging the gap between general practice and a district general hospital. Arch Dis Child. Apr. 1994;70(4):313-318. [pmid: 8185365]. [pmcid: 1029785].
Charlton I, Charlton G, Broomfield J, et al. Evaluation of peak flow and symptoms only self management plans for control of asthma in general practice. BMJ. Dec 15. 1990;301(6765):1355-1359. [pmid: 2148702]. [pmcid: 1664498].
Christiansen SC, Martin SB, Schleicher NC, et al. Evaluation of a school-based asthma education program for inner-city children. J Allergy Clin Immunol. Nov. 1997;100(5):613-617. [pmid: 9389290].
Cicutto L, Murphy S, Coutts D, et al. Breaking the access barrier: evaluating an asthma center's efforts to provide education to children with asthma in schools. Chest. Oct. 2005;128(4):1928-1935. [pmid: 16236837].
Clark N, Feldman C, Evans D, et al. Managing better: children, parents, and asthma. Patient Educ Counsel. 1986;8(1):27-38.
Clark NM, Feldman CH, Evans D, et al. The impact of health education on frequency and cost of health care use by low income children with asthma. J Allergy Clin Immunol. Jul. 1986;78(1 Pt 1):108-115. [pmid: 3088085].
Clark NM, Gong M, Schork MA, et al. Impact of education for physicians on patient outcomes. Pediatrics. May. 1998;101(5):831. [pmid: 9565410].
Clark NM, Gong M, Schork MA, et al. Long-term effects of asthma education for physicians on patient satisfaction and use of health services. Eur Respir J. Jul. 2000;16(1):15. [pmid: 10933079].
Coleman CI, Reddy P, Laster-Bradley NM, et al. Effect of practitioner education on adherence to asthma treatment guidelines. Ann Pharmacother. 2003;37(78):956-1. [pmid: 12841800].
Colland VT, van Essen-Zandvliet LE, Lans C, et al. Poor adherence to self-medication instructions in children with asthma and their parents. Patient Educ Couns. Dec. 2004;55(3):416-421. [pmid: 15582348].
Cordina M, McElnay JC, Hughes CM. Assessment of a community pharmacy-based program for patients with asthma. Pharmacotherapy. Oct. 2001;21(10):1196-1203. [pmid: 11601666].
Cote J, Bowie DM, Robichaud P, et al. Evaluation of two different educational interventions for adult patients consulting with an acute asthma exacerbation. Am J Respir Crit Care Med. May. 2001;163(6):1415-1419. [pmid: 11371411].
Cote J, Cartier A, Robichaud P, et al. Influence of asthma education on asthma severity, quality of life and environmental control. Can Respir J. 2000;7(5):395-400. [pmid: 11058207].
Cote J, Cartier A, Robichaud P, et al. Influence on asthma morbidity of asthma education programs based on self-monitoring or self-management plans following treatment optimization. Am J Respir Crit Care Med. May. 1997;155(5):1509-1514. [pmid: 9154850].
Couturaud F, Proust A, Frachon I, et al. Education and self-monitoring or self-management: a one-year randomized trial in stable adult asthmatic patients. J Asthma. Sep. 2002;39(6):493-500. [pmid: 12375708].
Cowan S, Ernst P, Cartier A, et al. A population-based evaluation of a regional asthma education centre. Can Respir J. 2004;11(1):39. [pmid: 15010731].
Cowie RL, Revitt SG, Underwood MF, et al. The effect of a peak flow-based action plan in the prevention of exacerbations of asthma. Chest. Dec. 1997;112(6):1534-1538. [pmid: 9404750].
Cowie RL, Underwood MF, Little CB, et al. Asthma in adolescents: a randomized, controlled trial of an asthma program for adolescents and young adults with severe asthma. Can Respir J. Jul–Aug. 2002;9(4):253. [pmid: 12195271].
Dahl J, Gustafsson D, Melin L. Effects of a behavioral treatment program on children with asthma. J Asthma. 1990;27(1):41-46. [pmid: 1968453].
Daniels EC, Bacon J, Denisio S, et al. Translation squared: improving asthma care for high-disparity populations through a safety net practice-based research network. J Asthma. Jul–Aug. 2005;42(6):499-505. [pmid: 16293546].
De Oliveira M, Faresin S, Bruno V, et al. Evaluation of an educational programme for socially deprived asthma patients. Eur Respir J. 1999;14(4):908-914. [pmid: 10573241].
Deaves DM. An assessment of the value of health education in the prevention of childhood asthma. J Adv Nurs. Mar. 1993;18(3):354-363. [pmid: 8450129].
Delaronde S, Peruccio DL, Bauer BJ. Improving asthma treatment in a managed care population. Am J Manag Care. Jun. 2005;11(6):361-368. [pmid: 15974555].
Donaghy D. The asthma specialist and patient education. Prof Nurse. Dec. 1995;11(3):160-162. [pmid: 8552685].
Drummond N, Abdalla M, Buckingham JK, et al. Integrated care for asthma: a clinical, social, and economic evaluation. BMJ. 1994;308(26 Feb):559-564. [pmid: 8148678]. [pmcid: 2539573].
Drummond. Effectiveness of routine self monitoring of peak flow in patients with asthma. Grampian Asthma Study of Integrated Care (GRASSIC). BMJ. Feb 26. 1994;308(6928):564-567. [pmid: 8148679]. [pmcid: 2539575].
Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. Oct 26. 2002;325(7370):941. [pmid: 12399345]. [pmcid: 130060].
Eggleston PA, Butz A, Rand C, et al. Home environmental intervention in inner-city asthma: a randomized controlled clinical trial. Ann Allergy Asthma Immunol. Dec. 2005;95(6):518-524. [pmid: 16400889].
Evans D, Clark NM, Feldman CH, et al. A school health education program for children with asthma aged 8–11 years. Health Educ Q. Fall. 1987;14(3):267-279. [pmid: 3654234].
Evans D, Mellins R, Lobach K, et al. Improving care for minority children with asthma: professional education in public health clinics see comments. Pediatrics. Feb. 1997;99(2):157. [pmid: 9024439].
Evans Rr, Gergen P, Mitchell H, et al. A randomized clinical trial to reduce asthma morbidity among inner-city children: results of the National Cooperative Inner-City Asthma Study. J Pediatr. 1999;135(3):332-338. [pmid: 10484799].
Feifer R, Verbrugge R, Khalid M, et al. Improvements in asthma pharmacotherapy and self-monitoring or self-management: An example of a population-based disease management program. Disease Management & Health Outcomes. 2004;12(2):93-102.
Finkelstein JA, Lozano P, Fuhlbrigge AL, et al. Practice-level effects of interventions to improve asthma care in primary care settings: the Pediatric Asthma Care Patient Outcomes Research Team. Health Serv Res. Dec. 2005;40(6 Pt 1):1737-1757. [pmid: 16336546]. [pmcid: 1361234].
Finkelstein JA, Lozano P, Streiff KA, et al. Clinical effectiveness research in managed-care systems: lessons from the Pediatric Asthma Care PORT. Patient Outcomes Research Team. Health Serv Res. Jun. 2002;37(3):775-789. [pmid: 12132605]. [pmcid: 1434661].
Fireman P, Friday G, Gira C, et al. Teaching self-monitoring or self-management skills to asthmatic children and their parents in an ambulatory care setting. Pediatrics. 1981;68(3):341-348. [pmid: 6792585].
Gallefoss F, Bakke PS, Rsgaard PK. Quality of life assessment after patient education in a randomized controlled study on asthma and chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Mar. 1999;159(3):812-817. [pmid: 10051255].
Gallefoss F, Bakke PS. Cost-effectiveness of self-monitoring or self-management in asthmatics: a 1-yr follow-up randomized, controlled trial. Eur Respir J. Feb. 2001;17(2):206-213. [pmid: 11334121].
Gallefoss F, Bakke PS. How does patient education and self-monitoring or self-management among asthmatics and patients with chronic obstructive pulmonary disease affect medication?. Am J Respir Crit Care Med. Dec. 1999;160(6):2000-2005. [pmid: 10588620].
Gallefoss F, Bakke PS. Impact of patient education and self-monitoring or self-management on morbidity in asthmatics and patients with chronic obstructive pulmonary disease. Respir Med. Mar. 2000;94(3):279-287. [pmid: 10783940].
Garrett J, Fenwick JM, Taylor G, et al. Peak expiratory flow meters (PEFMs)—who uses them and how and does education affect the pattern of utilisation?. Aust N Z J Med. Oct. 1994;24(5):521-529. [pmid: 7848156].
Garrett J, Fenwick JM, Taylor G, et al. Prospective controlled evaluation of the effect of a community based asthma education centre in a multiracial working class neighbourhood. Thorax. Oct. 1994;49(10):976-983. [pmid: 7974314]. [pmcid: 475232].
Ghosh CS, Ravindran P, Joshi M, et al. Reductions in hospital use from self management training for chronic asthmatics. Soc Sci Med. Apr. 1998;46(8):1087-1093. [pmid: 9579760].
Glasgow NJ, Ponsonby AL, Yates R, et al. Proactive asthma care in childhood: general practice based randomised controlled trial. BMJ. Sep 20. 2003;327(7416):659. [pmid: 14500440]. [pmcid: 196449].
Gonzalez-Martin G, Joo I, Sanchez I. Evaluation of the impact of a pharmaceutical care program in children with asthma. Patient Educ Couns. Jan. 2003;49(1):13. [pmid: 12527148].
Gorton TA, Cranford CO, Golden WE, et al. Primary care physicians' response to dissemination of practice guidelines. Arch Fam Med. Feb. 1995;4(2):135. [pmid: 7842151].
Greineder DK, Loane KC, Parks P. A randomized controlled trial of a pediatric asthma outreach program. J Allergy Clin Immunol. Mar. 1999;103(3 Pt 1):436-440. [pmid: 10069877].
Grover N, Kumaraiah V, Prasadrao P, et al. Cognitive behavioural intervention in bronchial asthma. J Assoc Physicians India. 2002;50:896-900. [pmid: 12126343].
Guendelman S, Meade K, Benson M, et al. Improving asthma outcomes and self-monitoring or self-management behaviors of inner-city children: a randomized trial of the Health Buddy interactive device and an asthma diary. Arch Pediatr Adolesc Med. Feb. 2002;156(2):114-120. [pmid: 11814370].
Halterman JS, McConnochie KM, Conn KM, et al. A randomized trial of primary care provider prompting to enhance preventive asthma therapy. Arch Pediatr Adolesc Med. May. 2005;159(5):422-427. [pmid: 15867114].
Halterman JS, Szilagyi PG, Yoos HL, et al. Benefits of a school-based asthma treatment program in the absence of secondhand smoke exposure: results of a randomized clinical trial. Arch Pediatr Adolesc Med. May. 2004;158(5):460-467. [pmid: 15123479].
Hayward S. A randomised controlled evaluation of asthma self management in general practice. Asthma Gen Pract. 1996;4.
Heard AR, Richards IJ, Alpers JH, et al. Randomised controlled trial of general practice based asthma clinics. Med J Aust. Jul 19. 1999;171(2):68-71. [pmid: 10474578].
Henry RL, Gibson PG, Vimpani GV, et al. Randomized controlled trial of a teacher-led asthma education program. Pediatr Pulmonol. Dec. 2004;38(6):434-442. [pmid: 15690558].
Herborg H, Soendergaard B, Froekjaer B, et al. Improving drug therapy for patients with asthma—part 1: Patient outcomes. see comments. J Am Pharm Assoc (Wash). Jul–Aug. 2001;41(4):539. [pmid: 11486980].
Hill R, Williams J, Britton J, et al. Can morbidity associated with untreated asthma in primary school children be reduced?: a controlled intervention study. BMJ. Nov 9. 1991;303(6811):1169-1174. [pmid: 1747614]. [pmcid: 1671468].
Hilton S, Sibbald B, Anderson HR, et al. Controlled evaluation of the effects of patient education on asthma morbidity in general practice. Lancet. Jan 4. 1986;1(8471):26-29. [pmid: 2867269].
Homer C, Susskind O, Alpert H, et al. An evaluation of an innovative multimedia educational software program for asthma management: report of a randomized, controlled trial. Pediatrics. 2000;106(1 Pt 2):210-215. [pmid: 10888694].
Homer CJ, Forbes P, Horvitz L, et al. Impact of a quality improvement program on care and outcomes for children with asthma. Arch Pediatr Adolesc Med. May. 2005;159(5):464-469. [pmid: 15867121].
Horner SD. Effect of education on school-age children's and parents' asthma management. J Spec Pediatr Nurs. Jul–Sep. 2004;9(3):95-102. [pmid: 15553551].
Hoskins G, Neville RG, Smith B, et al. Do self-monitoring or self-management plans reduce morbidity in patients with asthma?. Br J Gen Pract. Mar. 1996;46(404):169-171. [pmid: 8731624]. [pmcid: 1239578].
Hughes DM, McLeod M, Garner B, et al. Controlled trial of a home and ambulatory program for asthmatic children. Pediatrics. Jan. 1991;87(1):54-61. [pmid: 1984619].
Hung CC, Chen YC, Mao HC, et al. Effects of systematic nursing instruction of mothers on using medication and on health status of asthmatic children. J Nurs Res. Mar. 2002;10(1):22-32. [pmid: 11923898].
Ignacio-Garcia JM, Gonzalez-Santos P. Asthma self-monitoring or self-management education program by home monitoring of peak expiratory flow. Am J Respir Crit Care Med. Feb. 1995;151(2 Pt 1):353-359. [pmid: 7842191].
Janson SL, Fahy JV, Covington JK, et al. Effects of individual self-monitoring or self-management education on clinical, biological, and adherence outcomes in asthma. Am J Med. Dec 1. 2003;115(8):620-626. [pmid: 14656614].
Janson-Bjerklie S, Shnell S. Effect of peak flow information on patterns of self-care in adult asthma. Heart Lung. Sep. 1988;17(5):543-549. [pmid: 3417465].
Jenkinson D, Davison J, Jones S, et al. Comparison of effects of a self management booklet and audiocassette for patients with asthma. BMJ. Jul 23. 1988;297(6643):267-270. [pmid: 3416147]. [pmcid: 1833935].
Johnson A, Berg G, Fleegler E, et al. A matched-cohort study of selected clinical and utilization outcomes for an asthma care support program. Dis Manag. Jun. 2005;8(3):144-154. [pmid: 15966780].
Jones KP, Mullee MA, Middleton M, et al. Peak flow based asthma self-monitoring or self-management: a randomised controlled study in general practice. British Thoracic Society Research Committee. Thorax. Aug. 1995;50(8):851-857. [pmid: 7570436]. [pmcid: 474903].
Jones KP, Mullee MA. Proactive, nurse-run asthma care in general practice reduces asthma morbidity: scientific fact or medical assumption?. Br J Gen Pract. Sep. 1995;45(398):497-499. [pmid: 7546875]. [pmcid: 1239375].
Kamps AW, Brand PL, Kimpen JL, et al. Outpatient management of childhood asthma by paediatrician or asthma nurse: randomised controlled study with one year follow up. Thorax. 2003;58(11):968. [pmid: 14586050]. [pmcid: 1746504].
Kamps AW, Roorda RJ, Kimpen JL, et al. Impact of nurse-led outpatient management of children with asthma on healthcare resource utilisation and costs. Eur Respir J. 2004;23(2):304. [pmid: 14979508].
Kauppinen R, Sintonen H, Tukiainen H. One-year economic evaluation of intensive vs conventional patient education and supervision for self-monitoring or self-management of new asthmatic patients. Respir Med. Feb. 1998;92(2):300-307. [pmid: 9616530].
Kauppinen R, Sintonen H, Vilkka V, et al. Long-term (3-year) economic evaluation of intensive patient education for self-monitoring or self-management during the first year in new asthmatics. Respir Med. Apr. 1999;93(4):283-289. [pmid: 10464894].
Kauppinen R, Vilkka V, Sintonen H, et al. Long-term economic evaluation of intensive patient education during the first treatment year in newly diagnosed adult asthma. Respir Med. Jan. 2001;95(1):56-63. [pmid: 11207019].
Kelly CS, Morrow AL, Shults J, et al. Outcomes evaluation of a comprehensive intervention program for asthmatic children enrolled in medicaid. Pediatrics. May. 2000;105(5):1029. [pmid: 10790458].
Kelso TM, Abou-Shala N, Heilker GM, et al. Comprehensive long-term management program for asthma: effect on outcomes in adult African-Americans. Am J Med Sci. Jun. 1996;311(6):272-280. [pmid: 8659554].
Kelso TM, Self TH, Rumbak MJ, et al. Educational and long-term therapeutic intervention in the ED: effect on outcomes in adult indigent minority asthmatics. Am J Emerg Med. Nov. 1995;13(6):632-637. [pmid: 7575800].
Kemple T, Rogers C. A mailed personalised self-monitoring or self-management plan improves attendance and increases patients' understanding of asthma. Prim Care Respir J. 2003 2003;12(4):110–114.
Klein JJ, van der Palen J, Uil SM, et al. Benefit from the inclusion of self-treatment guidelines to a self-monitoring or self-management programme for adults with asthma. Eur Respir J. Mar. 2001;17(3):386-394. [pmid: 11405516].
Knoell DL, et al. Measurement of outcomes in adults receiving pharmaceutical care in a comprehensive asthma outpatient clinic. Pharmacotherapy. Dec 16, 2003 1998;18:1365.
Kotses H, Stout C, McConnaughy K, et al. Evaluation of individualized asthma self-monitoring or self-management programs. J Asthma. 1996;33(2):113-118. [pmid: 8609098].
Krishna S, Francisco BD, Balas EA, et al. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. Mar. 2003;111(3):503-510. [pmid: 12612228].
La Roche MJ, Koinis-Mitchell D, Gualdron L. A culturally competent asthma management intervention: a randomized controlled pilot study. Ann Allergy Asthma Immunol. Jan. 2006;96(1):80-85. [pmid: 16440537].
Lagerlov P, Loeb M, Andrew M, et al. Improving doctors' prescribing behaviour through reflection on guidelines and prescription feedback: a randomised controlled study. Qual Health Care. Sep. 2000;9(3):159. [pmid: 10980076]. [pmcid: 1743532].
Lahdensuo A, Haahtela T, Herrala J, et al. Randomised comparison of cost effectiveness of guided self management and traditional treatment of asthma in Finland. BMJ. Apr 11. 1998;316(7138):1138-1139. [pmid: 9552954]. [pmcid: 28518].
Lahdensuo A, Haahtela T, Herrala J, et al. Randomised comparison of guided self management and traditional treatment of asthma over one year. BMJ. Mar 23. 1996;312(7033):748-752. [pmid: 8605463]. [pmcid: 2350456].
LeBaron S, Zeltzer LK, Ratner P, et al. A controlled study of education for improving compliance with cromolyn sodium (Intal): the importance of physician-patient communication. Ann Allergy. Dec. 1985;55(6):811-818. [pmid: 3935013].
Legorreta A, Leung K, Berkbigler D, et al. Outcomes of a population-based asthma management program: quality of life, absenteeism, and utilization. Ann Allergy Asthma Immunol. 2000 2000;85(1):28–34.
Levy ML, Robb M, Allen J, et al. A randomized controlled evaluation of specialist nurse education following accident and emergency department attendance for acute asthma. Respir Med. Sep. 2000;94(9):900-908. [pmid: 11001084].
Lewis CE, Rachelefsky G, Lewis MA, et al. A randomized trial of A.C.T. (asthma care training) for kids. Pediatrics. Oct. 1984;74(4):478-486. [pmid: 6384911].
Liu C, Feekery C. Can asthma education improve clinical outcomes? An evaluation of a pediatric asthma education program. J Asthma. 2001;38(3):269-278. [pmid: 11392367].
Lopez-Vina A, del Castillo-Arevalo E. Influence of peak expiratory flow monitoring on an asthma self-monitoring or self-management education programme. Respir Med. Aug. 2000;94(8):760-766. [pmid: 10955751].
Lozano P, Finkelstein JA, Carey VJ, et al. A multisite randomized trial of the effects of physician education and organizational change in chronic-asthma care: health outcomes of the Pediatric Asthma Care Patient Outcomes Research Team II Study. Arch Pediatr Adolesc Med. Sep. 2004;158(9):875-883. [pmid: 15351753].
Lundborg CS, Wahlstrom R, Oke T, et al. Influencing prescribing for urinary tract infection and asthma in primary care in Sweden: a randomized controlled trial of an interactive educational intervention. J Clin Epidemiol. Aug. 1999;52(8):801. [pmid: 10465325].
Lwebuga-Mukasa J, Dunn-Georgiou E. A school-based asthma intervention program in the Buffalo, New York, schools. J Sch Health. Jan. 2002;72(1):27-32. [pmid: 11871359].
Magar Y, Vervloet D, Steenhouwer F, et al. Assessment of a therapeutic education programme for asthma patients: “un souffle nouveau”. Patient Educ Couns. Jul. 2005;58(1):41-46. [pmid: 15950835].
Malo JL, L'Archeveque J, Trudeau C, et al. Should we monitor peak expiratory flow rates or record symptoms with a simple diary in the management of asthma?. J Allergy Clin Immunol. Mar. 1993;91(3):702-709. [pmid: 8454792].
Mangione-Smith R, Schonlau M, Chan KS, et al. Measuring the effectiveness of a collaborative for quality improvement in pediatric asthma care: does implementing the chronic care model improve processes and outcomes of care?. Ambul Pediatr. Mar–Apr. 2005;5(2):75-82. [pmid: 15780018].
Marabini A, Brugnami G, Curradi F, et al. Short-term effectiveness of an asthma educational program: results of a randomized controlled trial. Respir Med. 2002;96(12):993-998. [pmid: 12477214].
Maslennikova G, Morosova ME, Salman NV, et al. Asthma education programme in Russia: educating patients. Patient Educ Couns. Feb. 1998;33(2):113-127. [pmid: 9732652].
Mayo PH, Richman J, Harris HW. Results of a program to reduce admissions for adult asthma see comments. Ann Intern Med. Jun 1. 1990;112(11):864. [pmid: 2344111].
McCowan C, Neville RG, Crombie IK, et al. The facilitator effect: results from a four-year follow-up of children with asthma. Br J Gen Pract. Mar. 1997;47(416):156. [pmid: 9167319]. [pmcid: 1312922].
McCowan C, Neville RG, Ricketts IW, et al. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. Jul–Sep. 2001;26(3):191. [pmid: 11706929].
McLean W, Gillis J, Waller R. The BC Community Pharmacy Asthma Study: A study of clinical, economic and holistic outcomes influenced by an asthma care protocol provided by specially trained community pharmacists in British Columbia. Can Respir J. 2003;10(4):195. [pmid: 12851665].
McNabb WL, Wilson-Pessano SR, Hughes GW, et al. Self-monitoring or self-management education of children with asthma: AIR WISE. Am J Public Health. Oct. 1985;75(10):1219-1220. [pmid: 4037168]. [pmcid: 1646372].
MeGhan SL, Wong E, Jhangri GS, et al. Evaluation of an education program for elementary school children with asthma. J Asthma. 2003;40(5):523-533. [pmid: 14529102].
Mesters I, van Nunen M, Crebolder H, et al. Education of parents about paediatric asthma: effects of a protocol on medical consumption. Patient Educ Couns. 1995 1995;25(2):131–136.
Mesters I, Meertens R, Kok G, et al. Effectiveness of a multidisciplinary education protocol in children with asthma (0–4 years) in primary health care. J Asthma. 1994;31(5):347. [pmid: 7928930].
Moldofsky H, Broder I, Davies G, et al. Videotape educational program for people with asthma. Can Med Assoc J. Mar 17. 1979;120(6):669-672. [pmid: 436049]. [pmcid: 1819150].
Morgan WJ, Crain EF, Gruchalla RS, et al. Results of a home-based environmental intervention among urban children with asthma. N Engl J Med. Sep 9. 2004;351(11):1068-1080. [pmid: 15356304].
Mulloy E, Donaghy D, Quigley C, et al. A one-year prospective audit of an asthma education programme in an out-patient setting. Ir Med J. Nov–Dec. 1996;89(6):226-228. [pmid: 8996955].
Neri M, Migliori GB, Spanevello A, et al. Economic analysis of two structured treatment and teaching programs on asthma. Allergy. May. 1996;51(5):313-319. [pmid: 8836335].
Neri M, Spanevello A, Ambrosetti M, et al. Short and long-term evaluation of two structured self management programmes on asthma. Monaldi Arch Chest Dis. Jun. 2001;56(3):208-210. [pmid: 11665499].
Onyirimba F, Apter A, Reisine S, et al. Direct clinician-to-patient feedback discussion of inhaled steroid use: its effect on adherence. Ann Allergy Asthma Immunol. Apr. 2003;90(4):411-415. [pmid: 12722963].
Osman L, Abdalla M, Beattie J, et al. Reducing hospital admission through computer supported education for asthma patients. Grampian Asthma Study of Integrated Care (GRASSIC). [see comment]. BMJ. 1994;308(6928):568-571. [pmid: 8093148]. [pmcid: 2539560].
Ostojic V, Cvoriscec B, Ostojic SB, et al. Improving asthma control through telemedicine: a study of short-message service. Telemed J E Health. Feb. 2005;11(1):28-35. [pmid: 15785218].
Perez MG, Feldman L, Caballero F. Effects of a self-monitoring or self-management educational program for the control of childhood asthma. Patient Educ Couns. Jan. 1999;36(1):47-55. [pmid: 10036559].
Perneger TV, Sudre P, Muntner P, et al. Effect of patient education on self-monitoring or self-management skills and health status in patients with asthma: a randomized trial. Am J Med. Jul. 2002;113(1):7-14. [pmid: 12106617].
Perrin JM, MacLean WE Jr, Gortmaker SL, et al. Improving the psychological status of children with asthma: a randomized controlled trial. J Dev Behav Pediatr. Aug. 1992;13(4):241-247. [pmid: 1506461].
Persaud DI, Barnett SE, Weller SC, et al. An asthma self-monitoring or self-management program for children, including instruction in peak flow monitoring by school nurses. J Asthma. 1996;33(1):37-43. [pmid: 8621369].
Pilotto LS, Smith BJ, Heard AR, et al. Trial of nurse-run asthma clinics based in general practice versus usual medical care. Respirology. Aug. 2004;9(3):356-362. [pmid: 15363008].
Put C, van den Bergh O, Lemaigre V, et al. Evaluation of an individualised asthma programme directed at behavioural change. Eur Respir J. Jan. 2003;21(1):109-115. [pmid: 12570118].
Rakos RF, Grodek MV, Mack KK. The impact of a self-administered behavioral intervention program on pediatric asthma. J Psychosom Res. 1985;29(1):101-108. [pmid: 3920390].
Rasmussen LM, Phanareth K, Nolte H, et al. Internet-based monitoring of asthma: a long-term, randomized clinical study of 300 asthmatic subjects. J Allergy Clin Immunol. Jun. 2005;115(6):1137-1142. [pmid: 15940125].
Ringsberg KC, Wiklund I, Wilhelmsen L. Education of adult patients at an “asthma school”: effects on quality of life, knowledge and need for nursing. Eur Respir J. Jan. 1990;3(1):33-37. [pmid: 2311729].
Ronchetti R, Indinnimeo L, Bonci E, et al. Asthma self-monitoring or self-management programmes in a population of Italian children: a multicentric study. Italian Study Group on Asthma Self-monitoring or self-management Programmes. Eur Respir J. Jun. 1997;10(6):1248-1253. [pmid: 9192924].
Rossiter LF, Whitehurst-Cook MY, Small RE, et al. The impact of disease management on outcomes and cost of care: a study of low-income asthma patients. Inquiry. Summer. 2000;37(2):188. [pmid: 10985112].
Runge C, Lecheler J, Horn M, et al. Outcomes of a Web-based patient education program for asthmatic children and adolescents. Chest. Mar. 2006;129(3):581-593. [pmid: 16537855].
Salisbury C, Francis C, Rogers C, et al. A randomised controlled trial of clinics in secondary schools for adolescents with asthma. Br J Gen Pract. Dec. 2002;52(485):988-996. [pmid: 12528584]. [pmcid: 1314468].
Schaffer SD, Tian L. Promoting adherence: effects of theory-based asthma education. Clin Nurs Res. 2004;13(1):69. [pmid: 14768768].
Schonlau M, Mangione-Smith R, Chan KS, et al. Evaluation of a quality improvement collaborative in asthma care: does it improve processes and outcomes of care?. Ann Fam Med. 2005;3(1):200-208. [pmid: 15928222]. [pmcid: 1466878].
Schott-Baer D, Christensen M. A pilot program to increase self-care of adult asthma patients. Medsurg Nurs. Jun. 1999;8(3):178-183. [pmid: 10661153].
Schulz M, Verheyen F, Muhlig S, et al. Pharmaceutical care services for asthma patients: a controlled intervention study. J Clin Pharmacol. 2001;41(6):668-676. [pmid: 11402636].
Shah S, Peat J, Mazurski E, et al. Effect of peer led programme for asthma education in adolescents: cluster randomised controlled trial. BMJ. 2001;322(7286):583-585. [pmid: 11238152]. [pmcid: 26550].
Shames RS, Sharek P, Mayer M, et al. Effectiveness of a multicomponent self-monitoring or self-management program in at-risk, school-aged children with asthma. Ann Allergy Asthma Immunol. Jun. 2004;92(6):611-618. [pmid: 15237762].
Shields MC, Griffin KW, McNabb WL. The effect of a patient education program on emergency room use for inner-city children with asthma. Am J Public Health. Jan. 1990;80(1):36-38. [pmid: 2293801].
Smith JR, Mildenhall S, Noble MJ, et al. The Coping with Asthma Study: a randomised controlled trial of a home based, nurse led psychoeducational intervention for adults at risk of adverse asthma outcomes. Thorax. Dec. 2005;60(12):1003-1011. [pmid: 16055616]. [pmcid: 1747261].
Smith NA, Seale JP, Ley P, et al. Effects of intervention on medication compliance in children with asthma. Med J Aust. Feb 3. 1986;144(3):119-122. [pmid: 3945199].
Snyder SE, Winder JA, Creer TJ. Development and evaluation of an adult asthma self-monitoring or self-management program: Wheezers Anonymous. J Asthma. 1987;24(3):153-158. [pmid: 3505528].
Stergachis A, Gardner JS, Anderson MT, et al. Improving pediatric asthma outcomes in the community setting: does pharmaceutical care make a difference?. J Am Pharm Assoc (Wash). Sep–Oct. 2002;42(5):743-752. [pmid: 12269709].
Stevens CA, Wesseldine LJ, Couriel JM, et al. Parental education and guided self-monitoring or self-management of asthma and wheezing in the pre-school child: a randomised controlled trial. Thorax. Jan. 2002;57(1):39-44. [pmid: 11809988]. [pmcid: 1746177].
Sullivan SD, Lee TA, Blough DK, et al. A multisite randomized trial of the effects of physician education and organizational change in chronic asthma care: cost-effectiveness analysis of the Pediatric Asthma Care Patient Outcomes Research Team II (PAC-PORT II). Arch Pediatr Adolesc Med. May. 2005;159(5):428-434. [pmid: 15867115].
Sullivan SD, Weiss KB, Lynn H, et al. The cost-effectiveness of an inner-city asthma intervention for children. J Allergy Clin Immunol. Dec 16 2003 2002;110(4):576.
Sundberg R, Tunsater A, Palmqvist M, et al. A randomized controlled study of a computerized limited education program among young adults with asthma. Respir Med. Mar. 2005;99(3):321-328. [pmid: 15733508].
Swanson V, Wright S, Power KG, et al. The impact of a structured programme of asthma care in general practice. Int J Clin Pract. Nov. 2000;54(9):573-580. [pmid: 11220984].
Thapar A. Educating asthmatic patients in primary care: a pilot study of small group education. Fam Pract. Mar. 1994;11(1):39-43. [pmid: 8034151].
Thomas M, McKinley RK, Freeman E, et al. Breathing retraining for dysfunctional breathing in asthma: a randomised controlled trial. Thorax. Feb. 2003;58(2):110-115. [pmid: 12554890]. [pmcid: 1746567].
Tieffenberg JA, Wood EI, Alonso A, et al. A randomized field trial of ACINDES: a child-centered training model for children with chronic illnesses (asthma and epilepsy). J Urban Health. Jun. 2000;77(2):280-297. [pmid: 10856009].
Toelle BG, Peat JK, Salome CM, et al. Evaluation of a community-based asthma management program in a population sample of schoolchildren. Med J Aust. Jun 7. 1993;158(11):742-746. [pmid: 8341186].
Tomson Y, Hasselstrom J, Tomson G, et al. Asthma education for Swedish primary care physicians—a study on the effects of “academic detailing” on practice and patient knowledge. Eur J Clin Pharmacol. 1997;53(34):191. [pmid: 9476030].
Turner MO, Taylor D, Bennett R, et al. A randomized trial comparing peak expiratory flow and symptom self-monitoring or self-management plans for patients with asthma attending a primary care clinic. Am J Respir Crit Care Med. Feb. 1998;157(2):540-546. [pmid: 9476870].
van der Palen J, Klein JJ, Zielhuis GA, et al. Behavioural effect of self-treatment guidelines in a self-monitoring or self-management program for adults with asthma. Patient Educ Couns. May. 2001;43(2):161-169. [pmid: 11369149].
van Es SM, Nagelkerke AF, Colland VT, et al. An intervention programme using the ASE-model aimed at enhancing adherence in adolescents with asthma. Patient Educ Couns. Sep. 2001;44(3):193-203. [pmid: 11553420].
Vazquez MI, Buceta JM. Effectiveness of self-monitoring or self-management programmes and relaxation training in the treatment of bronchial asthma: relationships with trait anxiety and emotional attack triggers. J Psychosom Res. Jan. 1993;37(1):71-81. [pmid: 8421262].
Vazquez MI, Buceta JM. Psychological treatment of asthma: effectiveness of a self-monitoring or self-management program with and without relaxation training. J Asthma. 1993;30(3):171-183. [pmid: 8325826].
Velsor-Friedrich B, Pigott TD, Louloudes A. The effects of a school-based intervention on the self-care and health of African-American inner-city children with asthma. J Pediatr Nurs. Aug. 2004;19(4):247-256. [pmid: 15308974].
Veninga CC, Denig P, Zwaagstra R, et al. Improving drug treatment in general practice. J Clin Epidemiol. Jul. 2000;53(7):762. [pmid: 10941955].
Verver S, Poelman M, Bogels A, et al. Effects of instruction by practice assistants on inhaler technique and respiratory symptoms of patients. A controlled randomized videotaped intervention study. Fam Pract. Feb. 1996;13(1):35-40. [pmid: 8671102].
Walders N, Kercsmar C, Schluchter M, et al. An interdisciplinary intervention for undertreated pediatric asthma. Chest. Feb. 2006;129(2):292-299. [pmid: 16478844].
Webber MP, Hoxie AM, Odlum M, et al. Impact of asthma intervention in two elementary school-based health centers in the Bronx, New York City. Pediatr Pulmonol. Dec. 2005;40(6):487-493. [pmid: 16193475].
Weingarten MA, Goldberg J, Teperberg Y, et al. A pilot study of the multidisciplinary management of childhood asthma in a family practice. J Asthma. 1985;22(5):261. [pmid: 3902784].
Weng HC. Impacts of a government-sponsored outpatient-based disease management program for patients with asthma: a preliminary analysis of national data from Taiwan. Dis Manag. Feb. 2005;8(1):48-58. [pmid: 15722704].
Wensley D, Silverman M. Peak flow monitoring for guided self-monitoring or self-management in childhood asthma: a randomized controlled trial. Am J Respir Crit Care Med. Sep 15. 2004;170(6):606-612. [pmid: 15184205].
White P, Atherton A, Hewett G, et al. Using information from asthma patients: a trial of information feedback in primary care. BMJ. Oct 21. 1995;311(7012):1065. [pmid: 7580666]. [pmcid: 2551370].
Whitman N, West D, Brough FK, et al. A study of a Self-Care Rehabilitation Program in pediatric asthma. Health Educ Q. Winter. 1985;12(4):333-342. [pmid: 4077545].
Wilson S, Latini D, Starr N, et al. Education of parents of infants and very young children with asthma: a developmental evaluation of the Wee Wheezers program.[erratum appears in J Asthma 1997;34(3):261]. J Asthma. 1996;33(4):239-254. [pmid: 8707779].
Wilson SR, Scamagas P, German DF, et al. A controlled trial of two forms of self-monitoring or self-management education for adults with asthma. Am J Med. Jun. 1993;94(6):564-576. [pmid: 8506881].
Windsor RA, Bailey WC, Richards JM Jr, et al. Evaluation of the efficacy and cost effectiveness of health education methods to increase medication adherence among adults with asthma. Am J Public Health. Dec. 1990;80(12):1519-1521. [pmid: 2240348]. [pmcid: 1405114].
Yilmaz A, Akkaya E. Evaluation of long-term efficacy of an asthma education programme in an out-patient clinic. Respir Med. 2002;96(7):519-524. [pmid: 12194637].
Yoon R, McKenzie DK, Bauman A, et al. Controlled trial evaluation of an asthma education programme for adults. Thorax. Nov. 1993;48(11):1110-1116. [pmid: 8296253]. [pmcid: 464888].
Yoos HL, Kitzman H, McMullen A, et al. Symptom monitoring in childhood asthma: a randomized clinical trial comparing peak expiratory flow rate with symptom monitoring. Ann Allergy Asthma Immunol. Mar. 2002;88(3):283-291. [pmid: 11926622].
Zeiger RS, Heller S, Mellon MH, et al. Facilitated referral to asthma specialist reduces relapses in asthma emergency room visits. J Allergy Clin Immunol. Jun. 1991;87(6):1160-1168. [pmid: 2045618].