# List of Acronyms/Abbreviations

Acronyms/Abbreviations | Definition
AHRQ | Agency for Healthcare Research and Quality
CBA | Controlled Before-After Trial
CME | Continuing Medical Education
COPD | Chronic obstructive pulmonary disease
CQI | Continuous Quality Improvement
ED | Emergency Department
EPC | Evidence-based Practice Center
EPOC | Cochrane Effective Practice and Organisation of Care
FEV_1_ | Forced Expiratory Volume in 1 second
HEPA filter | High efficiency particulate air filter
IOM | Institute of Medicine
NHLBI | National Heart, Lung, and Blood Institute
PF | Peak Flow
QI | Quality Improvement
QOL | Quality of Life
QRCT | Quasi-Randomized Controlled Trial
RCT | Randomized Controlled Trial
TQM | Total Quality Management