# References

1 Marketos SG, Ballas CN. Bronchial asthma in the medical literature of Greek antiquity. J Asthma. 1982;19(4):263-9. [pmid: 6757243].
2 Akinbami LJ, Rhodes JC, Lara M. Racial and ethnic differences in asthma diagnosis among children who wheeze. Pediatrics. May. 2005;115(5):1254-60. [pmid: 15867032].
3 Asthma prevalence and control characteristics by race/ethnicity—United States, 2002. Morb Mortal Wkly Rep. 2004 Feb 27;53(7):145–8.
4 Brown JV, Demi AS, Celano MP, et al. A home visiting asthma education program: challenges to program implementation. Health Educ Behav. Feb. 2005;32(1):42-56. [pmid: 15642753].
5 Halfon N, Newacheck PW. Childhood asthma and poverty: differential impacts and utilization of health services. Pediatrics. Jan. 1993;91(1):56-61. [pmid: 8416505].
6 Healthy People 2010. Volume 2, Chapter 24: Respiratory Diseases. 2002 [cited 2005 September 6]; Available from: http://www.healthypeople.gov/Document/HTML/Volume2/24Respiratory.htm#_Toc489704825.
7 Lara M, Rosenbaum S, Rachelefsky G, et al. Improving childhood asthma outcomes in the United States: a blueprint for policy action. Pediatrics. May. 2002;109(5):919-30. [pmid: 11986457].
8 Practical Guide for the Diagnosis and Management of Asthma: Based on the Expert Panel Report 2: Guidelines for the Diagnosis and Management of Asthma. Bethesda, MD: National Institutes of Health, U.S. Department of Health and Human Services; National Heart, Lung, and Blood Institute, National Asthma Education and Prevention Program; 1997. Report No.: Pub. No. 97-4063.
9 Expert Panel Report: Guidelines for the Diagnosis and Management of Asthma: Update on Selected Topics 2002. Bethesda, MD: National Heart, Lung, and Blood Institute; National Institutes of Health; U.S. Department of Health and Human Services; 2002 June. Report No.: NIH Pub. No. 02-5074.
10 Aronson N, Lefevre F, Piper M, et al. Management of chronic asthma. Evid Rep Technol Assess (Summ). 2001 Sep(44):1–10.
11 Basic Facts about Asthma. 2005 February 11, 2005 [cited 2005 September 6]; Available from: http://www.cdc.gov/asthma/faqs.htm.
12 National Asthma Control Program: Improving quality of life and reducing costs. Atlanta, GA: National Center for Environmental Health, Centers for Disease Control and Prevention; 2005 June 2005. Report No.: NCEH Pub. No. 05-0523.
13 The State of Health Care Quality: Industry Trends and Analysis. Washington D.C.: National Committee for Quality Assurance; 2004.
14 Diette GB, Skinner EA, Nguyen TT, et al. Comparison of quality of care by specialist and generalist physicians as usual source of asthma care for children. Pediatrics. Aug. 2001;108(2):432-7. [pmid: 11483811].
15 Hartert TV, Togias A, Mellen BG, et al. Underutilization of controller and rescue medications among older adults with asthma requiring hospital care. J Am Geriatr Soc. Jun. 2000;48(6):651-7. [pmid: 10855601].
16 Legorreta AP, Christian-Herman J, O'Connor RD, et al. Compliance with national asthma management guidelines and specialty care: a health maintenance organization experience. Arch Intern Med. Mar 9. 1998;158(5):457-64. [pmid: 9508223].
17 Asthma and Flu Shots. 2005 February 1, 2005 [cited 2005 September 5]; Available from: http://www.cdc.gov/asthma/flushot.htm.
18 Adams K, Corrigan JM, Medicine Io, editors. Priority Areas for National Action: Transforming Health Care Quality. Washington, D.C.: National Academies Press; 2004.
19 Shojania KG, McDonald KM, Wachter RM, et al. Closing The Quality Gap: A Critical Analysis of Quality Improvement Strategies, Volume 1-Series Overview and Methodology: Technical Review 9 (Contract No. 290-02-0017 to the Stanford University-UCSF Evidence-based Practices Center). AHRQ Publication No. 04-0051-1.; 2004 August.
20 Grimshaw JM, Shirran L, Thomas R, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. 2001;39(8 Suppl 2):I12-45.
21 Ellis P, Robinson P, Ciliska D, et al. Diffusion and dissemination of evidence-based cancer control interventions. Rockville, MD: Agency for Healthcare Research and Quality; 2003 May. Report No.: Evidence Report/Technology Assessment No. 79 (Prepared by McMaster University Evidence-based Practice Center under contract no. 290-97-0017). AHRQ Publication No. 03-E032.
22 Stone EG, Morton SC, Hulscher ME, et al. Interventions that increase use of adult immunization and cancer screening services: a meta-analysis. Ann Intern Med. 2002;136(9):641-51. [pmid: 11992299].
23 Weingarten SR, Henning JM, Badamgarav E, et al. Interventions used in disease management programmes for patients with chronic illness-which ones work? Meta-analysis of published reports. BMJ. 2002;325(7370):925. [pmid: 12399340]. [pmcid: 130055].
24 Amirav I, Goren A, Kravitz RM, et al. Physician-targeted program on inhaled therapy for childhood asthma. J Allergy Clin Immunol. Apr. 1995;95(4):818-23. [pmid: 7722161].
25 Cochrane Consumers and Communication Group Database. [cited 2005 July 15]; Available from: http://www.latrobe.edu.au/cochrance/about.html.
26 Review Manager (RevMan). Version 4.2 for Windows ed: Copenhagen: The Nordic Cochrane Centre, The Cochrane Collaboration; 2003.
27 Liu C, Feekery C. Can asthma education improve clinical outcomes? An evaluation of a pediatric asthma education program. J Asthma. 2001;38(3):269-78. [pmid: 11392367].
28 International Consensus Report on Diagnosis and Management of Asthma. International Asthma Management Project. Asthma Management Project. Allergy. 1992;47(13 Suppl):1–61.
29 Toelle BG, Ram FS. Written individualised management plans for asthma in children and adults. Cochrane Database Syst Rev. 2002(3):CD002171.
30 Toelle BG, Ram FS. Written individualised management plans for asthma in children and adults. Cochrane Database Syst Rev. 2004(2):CD002171.
31 Devine EC. Meta-analysis of the effects of psychoeducational care in adults with asthma. Res Nurs Health. Oct. 1996;19(5):367-76. [pmid: 8848621].
32 Bernard-Bonnin AC, Stachenko S, Bonin D, et al. Self-management teaching programs and morbidity of pediatric asthma: a meta-analysis. J Allergy Clin Immunol. Jan. 1995;95(1 Pt 1):34-41. [pmid: 7822662].
33 Gibson PG, Coughlan J, Wilson AJ, et al. Limited (information only) patient education programs for adults with asthma. Cochrane Database Syst Rev. 2000(2):CD001005.
34 Lefevre F, Piper M, Weiss K, et al. Do written action plans improve patient outcomes in asthma? An evidence-based analysis. J Fam Pract. Oct. 2002;51(10):842-8. [pmid: 12401152].
35 Powell H, Gibson PG. Options for self-management education for adults with asthma. Cochrane Database Syst Rev. 2003(1):CD004107.
36 Guevara JP, Wolf FM, Grum CM, et al. Effects of educational interventions for self management of asthma in children and adolescents: systematic review and meta-analysis. BMJ. Jun 14. 2003;326(7402):1308-9. [pmid: 12805167]. [pmcid: 161636].
37 Warsi A, Wang PS, LaValley MP, et al. Self-management education programs in chronic disease: a systematic review and methodological critique of the literature. Arch Intern Med. Aug 9–23. 2004;164(15):1641-9. [pmid: 15302634].
38 Wolf FM, Guevara JP, Grum CM, et al. Educational interventions for asthma in children. Cochrane Database Syst Rev. 2003(1):CD000326.
39 Gibson PG, Coughlan J, Abramson M. Self-management education for adults with asthma improves health outcomes. West J Med. May. 1999;170(5):266. [pmid: 10409081]. [pmcid: 1305580].
40 Gibson PG, Powell H. Written action plans for asthma: an evidence-based review of the key components. Thorax. Feb. 2004;59(2):94-9. [pmid: 14760143]. [pmcid: 1746945].
41 Clark NM, Nothwehr F. Self-management of asthma by adult patients. Patient Educ Couns. Dec. 1997;32(1 Suppl):S5-20. [pmid: 9516756].
42 Meijer RJ, Kerstjens HA, Postma DS. Comparison of guidelines and self-management plans in asthma. Eur Respir J. May. 1997;10(5):1163-72. [pmid: 9163663].
43 Sudre P, Jacquemet S, Uldry C, et al. Objectives, methods and content of patient education programmes for adults with asthma: systematic review of studies published between 1979 and 1998. Thorax. Aug. 1999;54(8):681-7. [pmid: 10413719]. [pmcid: 1745548].
44 Gibson PG, Powell H, Coughlan J, et al. Limited (information only) patient education programs for adults with asthma. Cochrane Database Syst Rev. 2002(2):CD001005.
45 Dosa N, Ilardi D. An opportunity for school nurses and pediatricians to collaborate. School Nurse News. Nov. 2003;20(5):16-22. [pmid: 14650894].
46 Sterk PJ, Buist SA, Woolcock AJ, et al. The message from the World Asthma Meeting. The Working Groups of the World Asthma Meeting, held in Barcelona, Spain, December 9–13, 1998. Eur Respir J. Dec. 1999;14(6):1435-53. [pmid: 10624779].
47 Partridge MR, Hill SR. Enhancing care for people with asthma: the role of communication, education, training and self-management. 1998 World Asthma Meeting Education and Delivery of Care Working Group. Eur Respir J. Aug. 2000;16(2):333-48. [pmid: 10968512].
48 Bartholomew LK, Parcel GS, Kok G, et al. Intervention Mapping: Designing Theory and Evidence-based Health Promotion Programs. New York: McGraw-Hill.
49 Kohler CL, Davies SL, Bailey WC. Self-management and other behavioral aspects of asthma. Curr Opin Pulm Med. Jan. 1996;2(1):16-22. [pmid: 9363110].
50 Wade SL, Holden G, Lynn H, et al. Cognitive-behavioral predictors of asthma morbidity in inner-city children. J Dev Behav Pediatr. Oct. 2000;21(5):340-6. [pmid: 11064961].
51 Bynum A, Hopkins D, Thomas A, et al. The effect of telepharmacy counseling on metered-dose inhaler technique among adolescents with asthma in rural Arkansas. Telemed J E Health. 2001;7(3):207-17. [pmid: 11564356].
52 Runge C, Lecheler J, Horn M, et al. Outcomes of a Web-based patient education program for asthmatic children and adolescents. Chest. Mar. 2006;129(3):581-93. [pmid: 16537855].
53 Bartholomew LK, Gold RS, Parcel GS, et al. Watch, Discover, Think, and Act: evaluation of computer-assisted instruction to improve asthma self-management in inner-city children. Patient Educ Couns. Feb. 2000;39(23):269-80. [pmid: 11040726].
54 Homer C, Susskind O, Alpert H, et al. An evaluation of an innovative multimedia educational software program for asthma management: report of a randomized, controlled trial. Pediatrics. 2000;106(1 Pt 2):210-5. [pmid: 10888694].
55 Guendelman S, Meade K, Benson M, et al. Improving asthma outcomes and self-management behaviors of inner-city children: a randomized trial of the Health Buddy interactive device and an asthma diary. Arch Pediatr Adolesc Med. Feb. 2002;156(2):114-20. [pmid: 11814370].
56 Krishna S, Francisco BD, Balas EA, et al. Internet-enabled interactive multimedia asthma education program: a randomized trial. Pediatrics. Mar. 2003;111(3):503-10. [pmid: 12612228].
57 Chan DS, Callahan CW, Sheets SJ, et al. An Internet-based store-and-forward video home telehealth system for improving asthma outcomes in children. Am J Health Syst Pharm. Oct 1. 2003;60(19):1976-81. [pmid: 14531243].
58 Shames RS, Sharek P, Mayer M, et al. Effectiveness of a multicomponent self-management program in at-risk, school-aged children with asthma. Ann Allergy Asthma Immunol. Jun. 2004;92(6):611-8. [pmid: 15237762].
59 Walders N, Kercsmar C, Schluchter M, et al. An interdisciplinary intervention for undertreated pediatric asthma. Chest. Feb. 2006;129(2):292-9. [pmid: 16478844].
60 Colland VT, van Essen-Zandvliet LE, Lans C, et al. Poor adherence to self-medication instructions in children with asthma and their parents. Patient Educ Couns. Dec. 2004;55(3):416-21. [pmid: 15582348].
61 Butz AM, Syron L, Johnson B, et al. Home-based asthma self-management education for inner city children. Public Health Nurs. May–Jun. 2005;22(3):189-99. [pmid: 15982192].
62 Lewis CE, Rachelefsky G, Lewis MA, et al. A randomized trial of A.C.T. (asthma care training) for kids. Pediatrics. Oct. 1984;74(4):478-86. [pmid: 6384911].
63 Wensley D, Silverman M. Peak flow monitoring for guided self-management in childhood asthma: a randomized controlled trial. Am J Respir Crit Care Med. Sep 15. 2004;170(6):606-12. [pmid: 15184205].
64 Charlton I, Antoniou AG, Atkinson J, et al. Asthma at the interface: bridging the gap between general practice and a district general hospital. Arch Dis Child. Apr. 1994;70(4):313-8. [pmid: 8185365]. [pmcid: 1029785].
65 Yoos HL, Kitzman H, McMullen A, et al. Symptom monitoring in childhood asthma: a randomized clinical trial comparing peak expiratory flow rate with symptom monitoring. Ann Allergy Asthma Immunol. Mar. 2002;88(3):283-91. [pmid: 11926622].
66 Perez MG, Feldman L, Caballero F. Effects of a self-management educational program for the control of childhood asthma. Patient Educ Couns. Jan. 1999;36(1):47-55. [pmid: 10036559].
67 Tieffenberg JA, Wood EI, Alonso A, et al. A randomized field trial of ACINDES: a child-centered training model for children with chronic illnesses (asthma and epilepsy). J Urban Health. Jun. 2000;77(2):280-97. [pmid: 10856009].
68 Evans D, Clark NM, Feldman CH, et al. A school health education program for children with asthma aged 8–11 years. Health Educ Q. Fall. 1987;14(3):267-79. [pmid: 3654234].
69 Velsor-Friedrich B, Pigott TD, Louloudes A. The effects of a school-based intervention on the self-care and health of African-American inner-city children with asthma. J Pediatr Nurs. Aug. 2004;19(4):247-56. [pmid: 15308974].
70 Webber MP, Hoxie AM, Odlum M, et al. Impact of asthma intervention in two elementary school-based health centers in the Bronx, New York City. Pediatr Pulmonol. Dec. 2005;40(6):487-93. [pmid: 16193475].
71 Burkhart PV, Dunbar-Jacob JM, Fireman P, et al. Children's adherence to recommended asthma self-management. Pediatr Nurs. Jul–Aug. 2002;28(4):409-14. [pmid: 12226965].
72 Ronchetti R, Indinnimeo L, Bonci E, et al. Asthma self-management programmes in a population of Italian children: a multicentric study. Italian Study Group on Asthma Self-Management Programmes. Eur Respir J. Jun. 1997;10(6):1248-53. [pmid: 9192924].
73 Morgan WJ, Crain EF, Gruchalla RS, et al. Results of a home-based environmental intervention among urban children with asthma. N Engl J Med. Sep 9. 2004;351(11):1068-80. [pmid: 15356304].
74 Evans Rr, Gergen P, Mitchell H, et al. A randomized clinical trial to reduce asthma morbidity among inner-city children: results of the National Cooperative Inner-City Asthma Study. J Pediatr. 1999;135(3):332-8. [pmid: 10484799].
75 Sullivan SD, Weiss KB, Lynn H, et al. The costeffectiveness of an inner-city asthma intervention for children. J Allergy Clin Immunol. 2002 Dec 16 2003;110(4):576.
76 MeGhan SL, Wong E, Jhangri GS, et al. Evaluation of an education program for elementary school children with asthma. J Asthma. 2003;40(5):523-33. [pmid: 14529102].
77 Cicutto L, Murphy S, Coutts D, et al. Breaking the access barrier: evaluating an asthma center's efforts to provide education to children with asthma in schools. Chest. Oct. 2005;128(4):1928-35. [pmid: 16236837].
78 La Roche MJ, Koinis-Mitchell D, Gualdron L. A culturally competent asthma management intervention: a randomized controlled pilot study. Ann Allergy Asthma Immunol. Jan. 2006;96(1):80-5. [pmid: 16440537].
79 Vazquez MI, Buceta JM. Effectiveness of self-management programmes and relaxation training in the treatment of bronchial asthma: relationships with trait anxiety and emotional attack triggers. J Psychosom Res. Jan. 1993;37(1):71-81. [pmid: 8421262].
80 McNabb WL, Wilson-Pessano SR, Hughes GW, et al. Self-management education of children with asthma: AIR WISE. Am J Public Health. Oct. 1985;75(10):1219-20. [pmid: 4037168]. [pmcid: 1646372].
81 Fireman P, Friday G, Gira C, et al. Teaching self-management skills to asthmatic children and their parents in an ambulatory care setting. Pediatrics. 1981;68(3):341-8. [pmid: 6792585].
82 Maslennikova G, Morosova ME, Salman NV, et al. Asthma education programme in Russia: educating patients. Patient Educ Couns. Feb. 1998;33(2):113-27. [pmid: 9732652].
83 Rakos RF, Grodek MV, Mack KK. The impact of a self-administered behavioral intervention program on pediatric asthma. J Psychosom Res. 1985;29(1):101-8. [pmid: 3920390].
84 Whitman N, West D, Brough FK, et al. A study of a Self-Care Rehabilitation Program in pediatric asthma. Health Educ Q. Winter. 1985;12(4):333-42. [pmid: 4077545].
85 Agrawal SK, Singh M, Mathew JL, et al. Efficacy of an individualized written home-management plan in the control of moderate persistent asthma: a randomized, controlled trial. Acta Paediatr. Dec. 2005;94(12):1742-6. [pmid: 16421033].
86 Dahl J, Gustafsson D, Melin L. Effects of a behavioral treatment program on children with asthma. J Asthma. 1990;27(1):41-6. [pmid: 1968453].
87 Persaud DI, Barnett SE, Weller SC, et al. An asthma self-management program for children, including instruction in peak flow monitoring by school nurses. J Asthma. 1996;33(1):37-43. [pmid: 8621369].
88 Toelle BG, Peat JK, Salome CM, et al. Evaluation of a community-based asthma management program in a population sample of schoolchildren. Med J Aust. Jun 7. 1993;158(11):742-6. [pmid: 8341186].
89 Vazquez MI, Buceta JM. Psychological treatment of asthma: effectiveness of a self-management program with and without relaxation training. J Asthma. 1993;30(3):171-83. [pmid: 8325826].
90 Brown JV, Bakeman R, Celano MP, et al. Home-based asthma education of young low-income children and their families. J Pediatr Psychol. Dec. 2002;27(8):677-88. [pmid: 12403858].
91 McGhan SL, Wells HM, Befus AD. The “Roaring Adventures of Puff”: a childhood asthma education program. J Pediatr Health Care. Jul–Aug. 1998;12(4):191-5. [pmid: 9832733].
92 Shah S, Peat J, Mazurski E, et al. Effect of peer led programme for asthma education in adolescents: cluster randomised controlled trial. BMJ. 2001;322(7286):583-5. [pmid: 11238152]. [pmcid: 26550].
93 Brook U, Mendelberg A, Heim M. Increasing parental knowledge of asthma decreases the hospitalization of the child: a pilot study. J Asthma. 1993;30(1):45-9. [pmid: 8428857].
94 Wilson S, Latini D, Starr N, et al. Education of parents of infants and very young children with asthma: a developmental evaluation of the Wee Wheezers program.[erratum appears in J Asthma 1997;34(3):261]. J Asthma. 1996;33(4):239-54. [pmid: 8707779].
95 Butz A, Pham L, Lewis L, et al. Rural children with asthma: impact of a parent and child asthma education program. J Asthma. Dec. 2005;42(10):813-21. [pmid: 16393717]. [pmcid: 2276310].
96 Clark NM, Feldman CH, Evans D, et al. The impact of health education on frequency and cost of health care use by low income children with asthma. J Allergy Clin Immunol. Jul. 1986;78(1 Pt 1):108-15. [pmid: 3088085].
97 Clark N, Feldman C, Evans D, et al. Managing better: children, parents, and asthma. Patient Educ Couns. 1986;8(1):27-38. [pmid: 10276475].
98 Eggleston PA, Butz A, Rand C, et al. Home environmental intervention in inner-city asthma: a randomized controlled clinical trial. Ann Allergy Asthma Immunol. Dec. 2005;95(6):518-24. [pmid: 16400889].
99 Horner SD. Effect of education on school-age children's and parents' asthma management. J Spec Pediatr Nurs. Jul–Sep. 2004;9(3):95-102. [pmid: 15553551].
100 Hung CC, Chen YC, Mao HC, et al. Effects of systematic nursing instruction of mothers on using medication and on health status of asthmatic children. J Nurs Res. Mar. 2002;10(1):22-32. [pmid: 11923898].
101 Mesters I, Meertens R, Kok G, et al. Effectiveness of a multidisciplinary education protocol in children with asthma (0–4 years) in primary health care. J Asthma. 1994;31(5):347. [pmid: 7928930].
102 Mesters I, van Nunen M, Crebolder H, et al. Education of parents about paediatric asthma: effects of a protocol on medical consumption. Patient Educ Couns. 1995 1995;25(2):131–6
103 Stevens CA, Wesseldine LJ, Couriel JM, et al. Parental education and guided self-management of asthma and wheezing in the pre-school child: a randomised controlled trial. Thorax. Jan. 2002;57(1):39-44. [pmid: 11809988]. [pmcid: 1746177].
104 Christiansen SC, Martin SB, Schleicher NC, et al. Evaluation of a school-based asthma education program for inner-city children. J Allergy Clin Immunol. Nov. 1997;100(5):613-7. [pmid: 9389290].
105 Henry RL, Gibson PG, Vimpani GV, et al. Randomized controlled trial of a teacher-led asthma education program. Pediatr Pulmonol. Dec. 2004;38(6):434-42. [pmid: 15690558].
106 Hill R, Williams J, Britton J, et al. Can morbidity associated with untreated asthma in primary school children be reduced?: a controlled intervention study. BMJ. Nov 9. 1991;303(6811):1169-74. [pmid: 1747614]. [pmcid: 1671468].
107 Lwebuga-Mukasa J, Dunn-Georgiou E. A school-based asthma intervention program in the Buffalo, New York, schools. J Sch Health. Jan. 2002;72(1):27-32. [pmid: 11871359].
108 Salisbury C, Francis C, Rogers C, et al. A randomised controlled trial of clinics in secondary schools for adolescents with asthma. Br J Gen Pract. Dec. 2002;52(485):988-96. [pmid: 12528584]. [pmcid: 1314468].
109 Cowie RL, Underwood MF, Little CB, et al. Asthma in adolescents: a randomized, controlled trial of an asthma program for adolescents and young adults with severe asthma. Can Respir J. Jul–Aug. 2002;9(4):253. [pmid: 12195271].
110 van Es SM, Nagelkerke AF, Colland VT, et al. An intervention programme using the ASE-model aimed at enhancing adherence in adolescents with asthma. Patient Educ Couns. Sep. 2001;44(3):193-203. [pmid: 11553420].
111 Alexander J, Younger R, Cohen R, et al. Effectiveness of a nurse-managed program for children with chronic asthma. J Pediatr Nurs. 1988;3(5):312-7. [pmid: 3171895].
112 Bonner S, Zimmerman BJ, Evans D, et al. An individualized intervention to improve asthma management among urban Latino and African-American families. J Asthma. Apr. 2002;39(2):167-79. [pmid: 11990232].
113 Deaves DM. An assessment of the value of health education in the prevention of childhood asthma. J Adv Nurs. Mar. 1993;18(3):354-63. [pmid: 8450129].
114 Glasgow NJ, Ponsonby AL, Yates R, et al. Proactive asthma care in childhood: general practice based randomised controlled trial. BMJ. Sep 20. 2003;327(7416):659. [pmid: 14500440]. [pmcid: 196449].
115 Gonzalez-Martin G, Joo I, Sanchez I. Evaluation of the impact of a pharmaceutical care program in children with asthma. Patient Educ Couns. Jan. 2003;49(1):13. [pmid: 12527148].
116 Hughes DM, McLeod M, Garner B, et al. Controlled trial of a home and ambulatory program for asthmatic children. Pediatrics. Jan. 1991;87(1):54-61. [pmid: 1984619].
117 Kamps AW, Brand PL, Kimpen JL, et al. Outpatient management of childhood asthma by paediatrician or asthma nurse: randomised controlled study with one year follow up. Thorax. 2003;58(11):968. [pmid: 14586050]. [pmcid: 1746504].
118 Kamps AW, Roorda RJ, Kimpen JL, et al. Impact of nurse-led outpatient management of children with asthma on healthcare resource utilisation and costs. Eur Respir J. 2004;23(2):304. [pmid: 14979508].
119 Kelly CS, Morrow AL, Shults J, et al. Outcomes evaluation of a comprehensive intervention program for asthmatic children enrolled in medicaid. Pediatrics. May. 2000;105(5):1029. [pmid: 10790458].
120 LeBaron S, Zeltzer LK, Ratner P, et al. A controlled study of education for improving compliance with cromolyn sodium (Intal): the importance of physician-patient communication. Ann Allergy. Dec. 1985;55(6):811-8. [pmid: 3935013].
121 Perrin JM, MacLean WE Jr, Gortmaker SL, et al. Improving the psychological status of children with asthma: a randomized controlled trial. J Dev Behav Pediatr. Aug. 1992;13(4):241-7. [pmid: 1506461].
122 Shields MC, Griffin KW, McNabb WL. The effect of a patient education program on emergency room use for inner-city children with asthma. Am J Public Health. Jan. 1990;80(1):36-8. [pmid: 2293801].
123 Smith NA, Seale JP, Ley P, et al. Effects of intervention on medication compliance in children with asthma. Med J Aust. Feb 3. 1986;144(3):119-22. [pmid: 3945199].
124 Weingarten MA, Goldberg J, Teperberg Y, et al. A pilot study of the multidisciplinary management of childhood asthma in a family practice. J Asthma. 1985;22(5):261. [pmid: 3902784].
125 Verver S, Poelman M, Bogels A, et al. Effects of instruction by practice assistants on inhaler technique and respiratory symptoms of patients. A controlled randomized videotaped intervention study. Fam Pract. Feb. 1996;13(1):35-40. [pmid: 8671102].
126 Charlton I, Charlton G, Broomfield J, et al. Evaluation of peak flow and symptoms only self management plans for control of asthma in general practice. BMJ. Dec 15. 1990;301(6765):1355-9. [pmid: 2148702]. [pmcid: 1664498].
127 Cowie RL, Revitt SG, Underwood MF, et al. The effect of a peak flow-based action plan in the prevention of exacerbations of asthma. Chest. Dec. 1997;112(6):1534-8. [pmid: 9404750].
128 Lopez-Vina A, del Castillo-Arevalo E. Influence of peak expiratory flow monitoring on an asthma self-management education programme. Respir Med. Aug. 2000;94(8):760-6. [pmid: 10955751].
129 Thomas M, McKinley RK, Freeman E, et al. Breathing retraining for dysfunctional breathing in asthma: a randomised controlled trial. Thorax. Feb. 2003;58(2):110-5. [pmid: 12554890]. [pmcid: 1746567].
130 Turner MO, Taylor D, Bennett R, et al. A randomized trial comparing peak expiratory flow and symptom self-management plans for patients with asthma attending a primary care clinic. Am J Respir Crit Care Med. Feb. 1998;157(2):540-6. [pmid: 9476870].
131 van der Palen J, Klein JJ, Zielhuis GA, et al. Behavioural effect of self-treatment guidelines in a self-management program for adults with asthma. Patient Educ Couns. May. 2001;43(2):161-9. [pmid: 11369149].
132 Klein JJ, van der Palen J, Uil SM, et al. Benefit from the inclusion of self-treatment guidelines to a self-management programme for adults with asthma. Eur Respir J. Mar. 2001;17(3):386-94. [pmid: 11405516].
133 Berg J, Dunbar-Jacob J, Sereika SM. An evaluation of a self-management program for adults with asthma. Clin Nurs Res. Aug. 1997;6(3):225-38. [pmid: 9281927].
134 Cowan S, Ernst P, Cartier A, et al. A population-based evaluation of a regional asthma education centre. Can Respir J. 2004;11(1):39. [pmid: 15010731].
135 Schott-Baer D, Christensen M. A pilot program to increase self-care of adult asthma patients. Medsurg Nurs. Jun. 1999;8(3):178-83. [pmid: 10661153].
136 Wilson SR, Scamagas P, German DF, et al. A controlled trial of two forms of self-management education for adults with asthma. Am J Med. Jun. 1993;94(6):564-76. [pmid: 8506881].
137 Barbanel D, Eldridge S, Griffiths C. Can a self-management programme delivered by a community pharmacist improve asthma control? A randomised trial. Thorax. Oct. 2003;58(10):851-4. [pmid: 14514935]. [pmcid: 1746491].
138 Legorreta A, Leung K, Berkbigler D, et al. Outcomes of a population-based asthma management program: quality of life, absenteeism, and utilization. Ann Allergy Asthma Immunol. 2000 2000;85(1):28–34.
139 Grover N, Kumaraiah V, Prasadrao P, et al. Cognitive behavioural intervention in bronchial asthma. J Assoc Physicians India. 2002;50:896-900. [pmid: 12126343].
140 Adams RJ, Boath K, Homan S, et al. A randomized trial of peak-flow and symptom-based action plans in adults with moderate-to-severe asthma. Respirology. Dec. 2001;6(4):297-304. [pmid: 11844120].
141 Smith JR, Mildenhall S, Noble MJ, et al. The Coping with Asthma Study: a randomised controlled trial of a home based, nurse led psychoeducational intervention for adults at risk of adverse asthma outcomes. Thorax. Dec. 2005;60(12):1003-11. [pmid: 16055616]. [pmcid: 1747261].
142 Catov JM, Marsh GM, Youk AO, et al. Asthma home teaching: two evaluation approaches. Dis Manag. Jun. 2005;8(3):178-87. [pmid: 15966783].
143 Snyder SE, Winder JA, Creer TJ. Development and evaluation of an adult asthma self-management program: Wheezers Anonymous. J Asthma. 1987;24(3):153-8. [pmid: 3505528].
144 Kotses H, Stout C, McConnaughy K, et al. Evaluation of individualized asthma self-management programs. J Asthma. 1996;33(2):113-8. [pmid: 8609098].
145 Creer TL, Backial M, Burns KL, et al. Living with Asthma. I. Genesis and development of a self-management program for childhood asthma. J Asthma. 1988;25(6):335-62. [pmid: 3235422].
146 Hindi-Alexander M, Cropp GJ. Community and family programs for children with asthma. Ann Allergy. Mar. 1981;46(3):143-8. [pmid: 7469142].
147 Bolton MB, Tilley BC, Kuder J, et al. The cost and effectiveness of an education program for adults who have asthma. J Gen Intern Med. Sep–Oct. 1991;6(5):401-7. [pmid: 1744753].
148 Cambach W, Chadwick-Straver RV, Wagenaar RC, et al. The effects of a community-based pulmonary rehabilitation programme on exercise tolerance and quality of life: a randomized controlled trial. Eur Respir J. Jan. 1997;10(1):104-13. [pmid: 9032501].
149 Delaronde S, Peruccio DL, Bauer BJ. Improving asthma treatment in a managed care population. Am J Manag Care. Jun. 2005;11(6):361-8. [pmid: 15974555].
150 Donaghy D. The asthma specialist and patient education. Prof Nurse. Dec. 1995;11(3):160-2. [pmid: 8552685].
151 Mulloy E, Donaghy D, Quigley C, et al. A one-year prospective audit of an asthma education programme in an out-patient setting. Ir Med J. Nov–Dec. 1996;89(6):226-8. [pmid: 8996955].
152 Garrett J, Fenwick JM, Taylor G, et al. Prospective controlled evaluation of the effect of a community based asthma education centre in a multiracial working class neighbourhood. Thorax. Oct. 1994;49(10):976-83. [pmid: 7974314]. [pmcid: 475232].
153 Garrett J, Fenwick JM, Taylor G, et al. Peak expiratory flow meters (PEFMs)—who uses them and how and does education affect the pattern of utilisation?. Aust N Z J Med. Oct. 1994;24(5):521-9. [pmid: 7848156].
154 Hayward S. A randomised controlled evaluation of asthma self management in general practice. Asthma Gen Pract. 1996;4:11-13.
155 Heard AR, Richards IJ, Alpers JH, et al. Randomised controlled trial of general practice based asthma clinics. Med J Aust. Jul 19. 1999;171(2):68-71. [pmid: 10474578].
156 Janson SL, Fahy JV, Covington JK, et al. Effects of individual self-management education on clinical, biological, and adherence outcomes in asthma. Am J Med. Dec 1. 2003;115(8):620-6. [pmid: 14656614].
157 Levy ML, Robb M, Allen J, et al. A randomized controlled evaluation of specialist nurse education following accident and emergency department attendance for acute asthma. Respir Med. Sep. 2000;94(9):900-8. [pmid: 11001084].
158 Pilotto LS, Smith BJ, Heard AR, et al. Trial of nurse-run asthma clinics based in general practice versus usual medical care. Respirology. Aug. 2004;9(3):356-62. [pmid: 15363008].
159 Cordina M, McElnay JC, Hughes CM. Assessment of a community pharmacy-based program for patients with asthma. Pharmacotherapy. Oct. 2001;21(10):1196-203. [pmid: 11601666].
160 Herborg H, Soendergaard B, Froekjaer B, et al. Improving drug therapy for patients with asthma—part 1: Patient outcomes. see comments. J Am Pharm Assoc (Wash). Jul–Aug. 2001;41(4):539. [pmid: 11486980].
161 Kelso TM, Abou-Shala N, Heilker GM, et al. Comprehensive long-term management program for asthma: effect on outcomes in adult African-Americans. Am J Med Sci. Jun. 1996;311(6):272-80. [pmid: 8659554].
162 Kelso TM, Self TH, Rumbak MJ, et al. Educational and long-term therapeutic intervention in the ED: effect on outcomes in adult indigent minority asthmatics. Am J Emerg Med. Nov. 1995;13(6):632-7. [pmid: 7575800].
163 Knoell DL, et al. Measurement of outcomes in adults receiving pharmaceutical care in a comprehensive asthma outpatient clinic. Pharmacotherapy. 1998 Dec 16, 2003;18:1365.
164 Schulz M, Verheyen F, Muhlig S, et al. Pharmaceutical care services for asthma patients: a controlled intervention study. J Clin Pharmacol. 2001;41(6):668-76. [pmid: 11402636].
165 Allen RM, Jones MP, Oldenburg B. Randomised trial of an asthma self-management programme for adults. Thorax. Jul. 1995;50(7):731-8. [pmid: 7570406]. [pmcid: 474644].
166 Bailey WC, Richards JM Jr, Brooks CM, et al. A randomized trial to improve self-management practices of adults with asthma. Arch Intern Med. Aug. 1990;150(8):1664-8. [pmid: 2200380].
167 Windsor RA, Bailey WC, Richards JM Jr, et al. Evaluation of the efficacy and cost effectiveness of health education methods to increase medication adherence among adults with asthma. Am J Public Health. Dec. 1990;80(12):1519-21. [pmid: 2240348]. [pmcid: 1405114].
168 Bailey WC, Kohler CL, Richards JM Jr, et al. Asthma self-management: do patient education programs always have an impact?. Arch Intern Med. Nov 8. 1999;159(20):2422-8. [pmid: 10665890].
169 Couturaud F, Proust A, Frachon I, et al. Education and self-management: a one-year randomized trial in stable adult asthmatic patients. J Asthma. Sep. 2002;39(6):493-500. [pmid: 12375708].
170 De Oliveira M, Faresin S, Bruno V, et al. Evaluation of an educational programme for socially deprived asthma patients. Eur Respir J. 1999;14(4):908-14. [pmid: 10573241].
171 Feifer R, Verbrugge R, Khalid M, et al. Improvements in asthma pharmacotherapy and self-management: An example of a population-based disease management program. Disease Management & Health Outcomes. 2004;12(2):93-102.
172 Gallefoss F, Bakke PS, Rsgaard PK. Quality of life assessment after patient education in a randomized controlled study on asthma and chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Mar. 1999;159(3):812-7. [pmid: 10051255].
173 Gallefoss F, Bakke PS. How does patient education and self-management among asthmatics and patients with chronic obstructive pulmonary disease affect medication?. Am J Respir Crit Care Med. Dec. 1999;160(6):2000-5. [pmid: 10588620].
174 Gallefoss F, Bakke PS. Cost-effectiveness of self-management in asthmatics: a 1-yr follow-up randomized, controlled trial. Eur Respir J. Feb. 2001;17(2):206-13. [pmid: 11334121].
175 Gallefoss F, Bakke PS. Impact of patient education and self-management on morbidity in asthmatics and patients with chronic obstructive pulmonary disease. Respir Med. Mar. 2000;94(3):279-87. [pmid: 10783940].
176 Ghosh CS, Ravindran P, Joshi M, et al. Reductions in hospital use from self management training for chronic asthmatics. Soc Sci Med. Apr. 1998;46(8):1087-93. [pmid: 9579760].
177 Hilton S, Sibbald B, Anderson HR, et al. Controlled evaluation of the effects of patient education on asthma morbidity in general practice. Lancet. Jan 4. 1986;1(8471):26-9. [pmid: 2867269].
178 Hoskins G, Neville RG, Smith B, et al. Do self-management plans reduce morbidity in patients with asthma?. Br J Gen Pract. Mar. 1996;46(404):169-71. [pmid: 8731624]. [pmcid: 1239578].
179 Jenkinson D, Davison J, Jones S, et al. Comparison of effects of a self management booklet and audiocassette for patients with asthma. BMJ. Jul 23. 1988;297(6643):267-70. [pmid: 3416147]. [pmcid: 1833935].
180 Johnson A, Berg G, Fleegler E, et al. A matched-cohort study of selected clinical and utilization outcomes for an asthma care support program. Dis Manag. Jun. 2005;8(3):144-54. [pmid: 15966780].
181 Lahdensuo A, Haahtela T, Herrala J, et al. Randomised comparison of guided self management and traditional treatment of asthma over one year. BMJ. Mar 23. 1996;312(7033):748-52. [pmid: 8605463]. [pmcid: 2350456].
182 Lahdensuo A, Haahtela T, Herrala J, et al. Randomised comparison of cost effectiveness of guided self management and traditional treatment of asthma in Finland. BMJ. Apr 11. 1998;316(7138):1138-9. [pmid: 9552954]. [pmcid: 28518].
183 Marabini A, Brugnami G, Curradi F, et al. Short-term effectiveness of an asthma educational program: results of a randomized controlled trial. Respir Med. 2002;96(12):993-8. [pmid: 12477214].
184 Magar Y, Vervloet D, Steenhouwer F, et al. Assessment of a therapeutic education programme for asthma patients: “un souffle nouveau”. Patient Educ Couns. Jul. 2005;58(1):41-6. [pmid: 15950835].
185 Mayo PH, Richman J, Harris HW. Results of a program to reduce admissions for adult asthma see comments. Ann Intern Med. Jun 1. 1990;112(11):864. [pmid: 2344111].
186 Moldofsky H, Broder I, Davies G, et al. Videotape educational program for people with asthma. Can Med Assoc J. Mar 17. 1979;120(6):669-72. [pmid: 436049]. [pmcid: 1819150].
187 Onyirimba F, Apter A, Reisine S, et al. Direct clinician-to-patient feedback discussion of inhaled steroid use: its effect on adherence. Ann Allergy Asthma Immunol. Apr. 2003;90(4):411-5. [pmid: 12722963].
188 Perneger TV, Sudre P, Muntner P, et al. Effect of patient education on self-management skills and health status in patients with asthma: a randomized trial. Am J Med. Jul. 2002;113(1):7-14. [pmid: 12106617].
189 Put C, van den Bergh O, Lemaigre V, et al. Evaluation of an individualised asthma programme directed at behavioural change. Eur Respir J. Jan. 2003;21(1):109-15. [pmid: 12570118].
190 Rasmussen LM, Phanareth K, Nolte H, et al. Internet-based monitoring of asthma: a long-term, randomized clinical study of 300 asthmatic subjects. J Allergy Clin Immunol. Jun. 2005;115(6):1137-42. [pmid: 15940125].
191 Ringsberg KC, Wiklund I, Wilhelmsen L. Education of adult patients at an “asthma school”: effects on quality of life, knowledge and need for nursing. Eur Respir J. Jan. 1990;3(1):33-7. [pmid: 2311729].
192 Schaffer SD, Tian L. Promoting adherence: effects of theory-based asthma education. Clin Nurs Res. 2004;13(1):69. [pmid: 14768768].
193 Sundberg R, Tunsater A, Palmqvist M, et al. A randomized controlled study of a computerized limited education program among young adults with asthma. Respir Med. Mar. 2005;99(3):321-8. [pmid: 15733508].
194 Weng HC. Impacts of a government-sponsored outpatient-based disease management program for patients with asthma: a preliminary analysis of national data from Taiwan. Dis Manag. Feb. 2005;8(1):48-58. [pmid: 15722704].
195 Yilmaz A, Akkaya E. Evaluation of long-term efficacy of an asthma education programme in an out-patient clinic. Respir Med. 2002;96(7):519-24. [pmid: 12194637].
196 Zeiger RS, Heller S, Mellon MH, et al. Facilitated referral to asthma specialist reduces relapses in asthma emergency room visits. J Allergy Clin Immunol. Jun. 1991;87(6):1160-8. [pmid: 2045618].
197 Greineder DK, Loane KC, Parks P. A randomized controlled trial of a pediatric asthma outreach program. J Allergy Clin Immunol. Mar. 1999;103(3 Pt 1):436-40. [pmid: 10069877].
198 Janson-Bjerklie S, Shnell S. Effect of peak flow information on patterns of self-care in adult asthma. Heart Lung. Sep. 1988;17(5):543-9. [pmid: 3417465].
199 Schonlau M, Mangione-Smith R, Chan KS, et al. Evaluation of a quality improvement collaborative in asthma care: does it improve processes and outcomes of care?. Ann Fam Med. 2005;3:200-8. [pmid: 15928222]. [pmcid: 1466878].
200 Bheekie A, Syce JA, Weinberg EG. Peak expiratory flow rate and symptom self-monitoring of asthma initiated from community pharmacies. J Clin Pharm Ther. Aug. 2001;26(4):287-96. [pmid: 11493372].
201 Cote J, Cartier A, Robichaud P, et al. Influence of asthma education on asthma severity, quality of life and environmental control. Can Respir J. 2000;7(5):395-400. [pmid: 11058207].
202 Cote J, Bowie DM, Robichaud P, et al. Evaluation of two different educational interventions for adult patients consulting with an acute asthma exacerbation. Am J Respir Crit Care Med. May. 2001;163(6):1415-9. [pmid: 11371411].
203 Cote J, Cartier A, Robichaud P, et al. Influence on asthma morbidity of asthma education programs based on self-management plans following treatment optimization. Am J Respir Crit Care Med. May. 1997;155(5):1509-14. [pmid: 9154850].
204 Ignacio-Garcia JM, Gonzalez-Santos P. Asthma self-management education program by home monitoring of peak expiratory flow. Am J Respir Crit Care Med. Feb. 1995;151(2 Pt 1):353-9. [pmid: 7842191].
205 McLean W, Gillis J, Waller R. The BC Community Pharmacy Asthma Study: A study of clinical, economic and holistic outcomes influenced by an asthma care protocol provided by specially trained community pharmacists in British Columbia. Can Respir J. 2003;10(4):195. [pmid: 12851665].
206 Ostojic V, Cvoriscec B, Ostojic SB, et al. Improving asthma control through telemedicine: a study of short-message service. Telemed J E Health. Feb. 2005;11(1):28-35. [pmid: 15785218].
207 Yoon R, McKenzie DK, Bauman A, et al. Controlled trial evaluation of an asthma education programme for adults. Thorax. Nov. 1993;48(11):1110-6. [pmid: 8296253]. [pmcid: 464888].
208 Ayres JG, Campbell LM. A controlled assessment of an asthma self-management plan involving a budesonide dose regimen. OPTIONS Research Group. Eur Respir J. May. 1996;9(5):886-92. [pmid: 8793447].
209 Baldwin D. Outcome of asthmatics attending asthma clinics utilising self-management plans in general practice. Asthma in Gen Pract. 1997;5:31-2.
210 Drummond N, Abdalla M, Buckingham JK, et al. Integrated care for asthma: a clinical, social, and economic evaluation. BMJ. 1994;308(26 Feb):559-64. [pmid: 8148678]. [pmcid: 2539573].
211 Drummond. Effectiveness of routine self monitoring of peak flow in patients with asthma. Grampian Asthma Study of Integrated Care (GRASSIC). BMJ. Feb 26. 1994;308(6928):564-7. [pmid: 8148679]. [pmcid: 2539575].
212 Osman L, Abdalla M, Beattie J, et al. Reducing hospital admission through computer supported education for asthma patients. Grampian Asthma Study of Integrated Care (GRASSIC). [see comment]. BMJ. 1994;308(6928):568-71. [pmid: 8093148]. [pmcid: 2539560].
213 Buckingham K, Drummond N, Cameron I, et al. Costing shared care. Health Services Management. Feb. 1994;90(2):22. [pmid: 10134424].
214 Jones KP, Mullee MA, Middleton M, et al. Peak flow based asthma self-management: a randomised controlled study in general practice. British Thoracic Society Research Committee. Thorax. Aug. 1995;50(8):851-7. [pmid: 7570436]. [pmcid: 474903].
215 Kauppinen R, Sintonen H, Tukiainen H. One-year economic evaluation of intensive vs conventional patient education and supervision for self-management of new asthmatic patients. Respir Med. Feb. 1998;92(2):300-7. [pmid: 9616530].
216 Kauppinen R, Sintonen H, Vilkka V, et al. Long-term (3-year) economic evaluation of intensive patient education for self-management during the first year in new asthmatics. Respir Med. Apr. 1999;93(4):283-9. [pmid: 10464894].
217 Kauppinen R, Vilkka V, Sintonen H, et al. Long-term economic evaluation of intensive patient education during the first treatment year in newly diagnosed adult asthma. Respir Med. Jan. 2001;95(1):56-63. [pmid: 11207019].
218 Kemple T, Rogers C. A mailed personalised self-management plan improves attendance and increases patients' understanding of asthma. Prim Care Respir J. 2003;12(4):110-4.
219 Malo JL, L'Archeveque J, Trudeau C, et al. Should we monitor peak expiratory flow rates or record symptoms with a simple diary in the management of asthma?. J Allergy Clin Immunol. Mar. 1993;91(3):702-9. [pmid: 8454792].
220 Neri M, Spanevello A, Ambrosetti M, et al. Short and long-term evaluation of two structured self management programmes on asthma. Monaldi Arch Chest Dis. Jun. 2001;56(3):208-10. [pmid: 11665499].
221 Neri M, Migliori GB, Spanevello A, et al. Economic analysis of two structured treatment and teaching programs on asthma. Allergy. May. 1996;51(5):313-9. [pmid: 8836335].
222 Thapar A. Educating asthmatic patients in primary care: a pilot study of small group education. Fam Pract. Mar. 1994;11(1):39-43. [pmid: 8034151].
223 Brown R, Bratton SL, Cabana MD, et al. Physician asthma education program improves outcomes for children of low-income families. Chest. 2004;126(2):369-74. [pmid: 15302719].
224 Evans D, Mellins R, Lobach K, et al. Improving care for minority children with asthma: professional education in public health clinics see comments. Pediatrics. Feb. 1997;99(2):157. [pmid: 9024439].
225 Sullivan SD, Lee TA, Blough DK, et al. A multisite randomized trial of the effects of physician education and organizational change in chronic asthma care: cost-effectiveness analysis of the Pediatric Asthma Care Patient Outcomes Research Team II (PAC-PORT II). Arch Pediatr Adolesc Med. May. 2005;159(5):428-34. [pmid: 15867115].
226 Lozano P, Finkelstein JA, Carey VJ, et al. A multisite randomized trial of the effects of physician education and organizational change in chronic-asthma care: health outcomes of the Pediatric Asthma Care Patient Outcomes Research Team II Study. Arch Pediatr Adolesc Med. Sep. 2004;158(9):875-83. [pmid: 15351753].
227 Finkelstein JA, Lozano P, Fuhlbrigge AL, et al. Practice-level effects of interventions to improve asthma care in primary care settings: the Pediatric Asthma Care Patient Outcomes Research Team. Health Serv Res. Dec. 2005;40(6 Pt 1):1737-57. [pmid: 16336546]. [pmcid: 1361234].
228 Homer CJ, Forbes P, Horvitz L, et al. Impact of a quality improvement program on care and outcomes for children with asthma. Arch Pediatr Adolesc Med. May. 2005;159(5):464-9. [pmid: 15867121].
229 Veninga CC, Denig P, Zwaagstra R, et al. Improving drug treatment in general practice. J Clin Epidemiol. Jul. 2000;53(7):762. [pmid: 10941955].
230 Lagerlov P, Loeb M, Andrew M, et al. Improving doctors' prescribing behaviour through reflection on guidelines and prescription feedback: a randomised controlled study. Qual Health Care. Sep. 2000;9(3):159. [pmid: 10980076]. [pmcid: 1743532].
231 Lundborg CS, Wahlstrom R, Oke T, et al. Influencing prescribing for urinary tract infection and asthma in primary care in Sweden: a randomized controlled trial of an interactive educational intervention. J Clin Epidemiol. Aug. 1999;52(8):801. [pmid: 10465325].
232 Rossiter LF, Whitehurst-Cook MY, Small RE, et al. The impact of disease management on outcomes and cost of care: a study of low-income asthma patients. Inquiry. Summer. 2000;37(2):188. [pmid: 10985112].
233 Clark NM, Gong M, Schork MA, et al. Long-term effects of asthma education for physicians on patient satisfaction and use of health services. Eur Respir J. Jul. 2000;16(1):15. [pmid: 10933079].
234 Clark NM, Gong M, Schork MA, et al. Impact of education for physicians on patient outcomes. Pediatrics. May. 1998;101(5):831. [pmid: 9565410].
235 Finkelstein JA, Lozano P, Streiff KA, et al. Clinical effectiveness research in managed-care systems: lessons from the Pediatric Asthma Care PORT. Patient Outcomes Research Team. Health Serv Res. Jun. 2002;37(3):775-89. [pmid: 12132605]. [pmcid: 1434661].
236 Daniels EC, Bacon J, Denisio S, et al. Translation squared: improving asthma care for high-disparity populations through a safety net practice-based research network. J Asthma. Jul–Aug. 2005;42(6):499-505. [pmid: 16293546].
237 Gorton TA, Cranford CO, Golden WE, et al. Primary care physicians' response to dissemination of practice guidelines. Arch Fam Med. Feb. 1995;4(2):135. [pmid: 7842151].
238 Tomson Y, Hasselstrom J, Tomson G, et al. Asthma education for Swedish primary care physicians—a study on the effects of “academic detailing” on practice and patient knowledge. Eur J Clin Pharmacol. 1997;53(34):191. [pmid: 9476030].
239 Anderson ME, Freas MR, Wallace AS, et al. Successful school-based intervention for inner-city children with persistent asthma. J Asthma. Jun. 2004;41(4):445-53. [pmid: 15281330].
240 Halterman JS, Szilagyi PG, Yoos HL, et al. Benefits of a school-based asthma treatment program in the absence of secondhand smoke exposure: results of a randomized clinical trial. Arch Pediatr Adolesc Med. May. 2004;158(5):460-7. [pmid: 15123479].
241 Stergachis A, Gardner JS, Anderson MT, et al. Improving pediatric asthma outcomes in the community setting: does pharmaceutical care make a difference?. J Am Pharm Assoc (Wash). Sep–Oct. 2002;42(5):743-52. [pmid: 12269709].
242 Mangione-Smith R, Schonlau M, Chan KS, et al. Measuring the effectiveness of a collaborative for quality improvement in pediatric asthma care: does implementing the chronic care model improve processes and outcomes of care?. Ambul Pediatr. Mar–Apr. 2005;5(2):75-82. [pmid: 15780018].
243 Swanson V, Wright S, Power KG, et al. The impact of a structured programme of asthma care in general practice. Int J Clin Pract. Nov. 2000;54(9):573-80. [pmid: 11220984].
244 Jones KP, Mullee MA. Proactive, nurse-run asthma care in general practice reduces asthma morbidity: scientific fact or medical assumption?. Br J Gen Pract. Sep. 1995;45(398):497-9. [pmid: 7546875]. [pmcid: 1239375].
245 Bryce FP, Neville RG, Crombie IK, et al. Controlled trial of an audit facilitator in diagnosis and treatment of childhood asthma in general practice see comments. BMJ. Apr 1. 1995;310(6983):838. [pmid: 7711623]. [pmcid: 2549220].
246 McCowan C, Neville RG, Crombie IK, et al. The facilitator effect: results from a four-year follow-up of children with asthma. Br J Gen Pract. Mar. 1997;47(416):156. [pmid: 9167319]. [pmcid: 1312922].
247 Halterman JS, McConnochie KM, Conn KM, et al. A randomized trial of primary care provider prompting to enhance preventive asthma therapy. Arch Pediatr Adolesc Med. May. 2005;159(5):422-7. [pmid: 15867114].
248 Coleman CI, Reddy P, Laster-Bradley NM, et al. Effect of practitioner education on adherence to asthma treatment guidelines. Ann Pharmacother. 2003;37(78):956. [pmid: 12841800].
249 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. Oct 26. 2002;325(7370):941. [pmid: 12399345]. [pmcid: 130060].
250 McCowan C, Neville RG, Ricketts IW, et al. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. Jul–Sep. 2001;26(3):191. [pmid: 11706929].
251 White P, Atherton A, Hewett G, et al. Using information from asthma patients: a trial of information feedback in primary care. BMJ. Oct 21. 1995;311(7012):1065. [pmid: 7580666]. [pmcid: 2551370].
252 Baren JM, Shofer FS, Ivey B, et al. A randomized, controlled trial of a simple emergency department intervention to improve the rate of primary care follow-up for patients with acute asthma exacerbations. Ann Emerg Med. Aug. 2001;38(2):115-22. [pmid: 11468604].
253 Bender B, Milgrom H, Rand C. Nonadherence in asthmatic patients: is there a solution to the problem?. Ann Allergy Asthma Immunol. Sep. 1997;79(3):177-85. quiz 85–6. [pmid: 9305223].
254 Todd WE. New mindsets in asthma: interventions and disease management. J Care Manage. 1995;1:2-8.
255 de Asis ML, Greene R. A cost-effectiveness analysis of a peak flow-based asthma education and self-management plan in a high-cost population. J Asthma. Aug. 2004;41(5):559-65. [pmid: 15360065].
256 Liljas B, Lahdensuo A. Is asthma self-management cost-effective?. Patient Educ Couns. Dec. 1997;32(1 Suppl):S97-104. [pmid: 9516765].
257 Sullivan SD, Buxton M, Andersson LF, et al. Cost-effectiveness analysis of early intervention with budesonide in mild persistent asthma. J Allergy Clin Immunol. Dec. 2003;112(6):1229-36. [pmid: 14657888].
258 Carranza Rosenzweig JR, Edwards L, Lincourt W, et al. The relationship between health-related quality of life, lung function and daily symptoms in patients with persistent asthma. Respir Med. Dec. 2004;98(12):1157-65. [pmid: 15588035].
259 Murray AB, Morrison BJ. Passive smoking and the seasonal difference of severity of asthma in children. Chest. Oct. 1988;94(4):701-8. [pmid: 3168566].
260 Knight A, Breslin AB. Passive cigarette smoking and patients with asthma. Med J Aust. Feb 4. 1985;142(3):194-5. [pmid: 3969036].
261 Martinez FD, Cline M, Burrows B. Increased incidence of asthma in children of smoking mothers. Pediatrics. Jan. 1992;89(1):21-6. [pmid: 1728015].
262 Evans D, Levison MJ, Feldman CH, et al. The impact of passive smoking on emergency room visits of urban children with asthma. Am Rev Respir Dis. Mar. 1987;135(3):567-72. [pmid: 3826881].
263 Weiss ST. Smoking and asthma. Compr Ther. 1994;20(11):606-10. [pmid: 7851090].
264 Weitzman M, Gortmaker S, Walker DK, et al. Maternal smoking and childhood asthma. Pediatrics. Apr. 1990;85(4):505-11. [pmid: 2314963].
265 Thomson NC, Chaudhuri R, Livingston E. Asthma and cigarette smoking. Eur Respir J. Nov. 2004;24(5):822-33. [pmid: 15516679].
266 Winickoff JP, Berkowitz AB, Brooks K, et al. State-of-the-art interventions for office-based parental tobacco control. Pediatrics. Mar. 2005;115(3):750-60. [pmid: 15741382].
267 Winickoff JP, McMillen RC, Carroll BC, et al. Addressing parental smoking in pediatrics and family practice: a national survey of parents. Pediatrics. Nov. 2003;112(5):1146-51. [pmid: 14595060].
268 Young S, Le Souef PN, Geelhoed GC, et al. The influence of a family history of asthma and parental smoking on airway responsiveness in early infancy. N Engl J Med. Apr 25. 1991;324(17):1168-73. [pmid: 2011160].
269 Thomson NC, Spears M. The influence of smoking on the treatment response in patients with asthma. Curr Opin Allergy Clin Immunol. Feb. 2005;5(1):57-63. [pmid: 15643345].