# Executive Summary

## Overview

Asthma is one of the most common chronic medical conditions in the U.S. It affects 16 million adults and 6.1 million children and results in two million visits to emergency departments, 70,000 hospitalizations, and 5,000 deaths annually. The burden of asthma disproportionately affects persons of lower socioeconomic status. Because asthma can neither be prevented nor cured, current management objectives are to monitor symptoms and objective measures of lung function, to encourage the use of medications that control and prevent symptoms with the fewest adverse effects possible, to control the triggers of asthma symptoms to which a patient is sensitive (such as house dust mites, tobacco smoke, animal dander, and pollens), and to facilitate an asthma care partnership between patients and providers. Effective asthma management has been demonstrated to reduce symptoms, hospitalizations, and urgent care visits.

Despite the availability of evidence-based guidelines for the management of pediatric and adult asthma, there remains a significant gap between accepted best practices for asthma care and actual care delivered to asthma patients. The objective of this systematic review was to evaluate the evidence that quality improvement (QI) strategies can improve the processes and outcomes of outpatient care for children and adults with asthma, and to identify the most effective strategies.

## Key Questions

The two research questions addressed in this study were:

Research Question 1: What is the evidence that QI strategies improve the processes and outcomes of outpatient care for pediatric and adult populations with asthma? Specifically, which QI strategies are effective for improving processes and outcomes of asthma care for specific patient populations (e.g., adults, children, low socio-economic status (SES), racial groups, urban/rural)? Also, does the setting of the QI intervention (e.g., home, school, clinic) determine its effectiveness for improving processes and outcomes of asthma care?

Research Question 2: Are QI interventions for asthma care that incorporate multiple strategies more effective than those that employ a single strategy?

## Methodology

We sought English language evaluations of quality improvement strategies designed to improve the outpatient management of children and adults with asthma. We defined QI strategies as interventions aimed at reducing the quality gap (the difference between health care processes or outcomes observed in practice and evidence-based practices potentially obtainable on the basis of current professional knowledge). We included articles describing interventions with one or more of nine types of QI strategies: patient education, the promotion of self-monitoring or self-management, provider education, organizational change, audit and feedback, provider reminders, patient reminders, facilitated relay of clinical data to providers, and financial or legislative incentives.

Study Design. Because most health care is delivered in settings where continuous QI efforts and other temporal changes are occurring, evaluations of QI strategies that are not randomized or controlled may be subject to confounding from other QI programs ongoing in the facility or region. Thus, included trials were required to have one of three types of study designs: randomized controlled trials, controlled before-after trials which included contemporaneous observation periods for control and intervention groups, or interrupted time series trials that reported data at three or more time points both before and after intervention to facilitate time trend analysis.

Outcomes. Included studies had to report at least one of the four following types of primary outcomes: measures of clinical status (e.g., symptoms or symptom-free days, spirometric measures, number of asthma attacks); measures of functional status (e.g., days lost from work or school); measures of health services utilization (e.g., hospital admissions, ED visits); or measures of adherence to guidelines (e.g., number of patients given prescriptions for inhaled corticosteroids).

Literature Sources. We searched four literature sources: MEDLINE^®^ (1966 to April 2006) the Cochrane Effective Practice and Organisation of Care (EPOC) Group databases (1966 to April 2006), the Cochrane Consumers and Communication Group database (1966 to May 2006), and bibliographies of retrieved articles.

Data Abstraction. Two independent investigators reviewed the title and abstract of each article found in our search to determine if the article met inclusion criteria. All disagreements were resolved by repeated review and discussion. Articles requiring full text review were abstracted by a single investigator and then verified by a second abstracter. From each of the included studies we abstracted data about the study design, study participants, detailed descriptions of the QI intervention, and the reported outcomes.

Statistical Analysis. We performed univariate analyses to describe the patient and intervention characteristics of the included studies. For each type of intervention evaluated in a particular population (e.g., patient education strategies for children) for which 15 or more studies presented data on the same specific outcome (e.g., percent predicted FEV_1_), we calculated summary standardized and weighted mean differences between intervention and control groups at the end of the trial using a random effects model. We performed least squares regression (weighted by the sample size) to identify associations between the intervention characteristics and improvements in these outcomes. For example, for the studies of patient education interventions, we evaluated the association of the frequency of educational sessions, the type of educator (e.g., nurse, pharmacist), and the setting of the educational program with changes in FEV_1_. We performed formal assessments of heterogeneity for our summary weighted mean differences. We sought evidence of publication bias by visual inspection of funnel plots.

## Findings

Our searches yielded 3,843 potential relevant articles, of which 200 articles describing 171 studies met eligibility criteria.

Assessment for Heterogeneity. The included articles were highly heterogeneous:

Study design: 134 were randomized controlled trials, 32 were controlled before-after trials, and 5 were quasi-randomized controlled trials. Out of the total, 35 studies compared two or more interventions without a control group that did not also receive a QI intervention.

QI strategies evaluated: 94 studies described interventions that included a component of self- monitoring or self-management, 100 included a component of patient education, 18 included provider education, 27 included organizational change, five included audit and feedback, and four included provider reminders, five included facilitated relay of clinical data to providers, and two included financial incentives. The interventions took place between 1976 and 2004 and ranged in length from 4 weeks to 5 years (median: 12 months).

Target populations: 79 studies targeted children (six of which exclusively enrolled adolescents) and 92 studies targeted general asthma populations that included primarily adults.

Given the heterogeneity of the included studies, we synthesized data separately for each group of studies that evaluated the same type of QI strategy in the same population.

Assessment for Publication Bias. Overall, we found no statistically significant association between the likelihood of positive outcome with either sample size (p=0.6) or study design (p=0.4). Visual inspection of the funnel plots of the association of sample size and the likelihood of finding a statistically significant positive outcome also did not suggest substantial publication bias for most interventions and outcomes.

Self-Monitoring, Self-Management, or Patient Education. For the purposes of this report, we classified interventions as being principally “self-monitoring or self-management” if the goal of the intervention was to improve the ability of people with asthma or their caregivers to take actions that can reduce the impact of asthma on their lives. In contrast, we classified interventions as being principally patient education if the purpose was to increase asthma knowledge or improve inhaler technique without emphasizing patient decision making or changing behavior. We recognize that these are somewhat artificial distinctions and that many interventions included components of both.

We found 69 studies evaluating self-monitoring, self-management, or educational strategies for children with asthma or their caregivers.

- Of the self-monitoring, self-management, or patient education interventions for children with asthma or their caregivers, 43/69 (62%) specifically described an underlying conceptual framework or theoretical background as the basis for the intervention. Typically, these interventions relied less on lecture-based or pamphlet-based teaching methods and more on combination educational modalities that including role-playing, videos, and games to reinforce patient learning. In univariate analyses, these studies tended to be more likely to report statistically significant improvements in emergency department visits (36 studies reported both frequency of emergency department visits and described a theoretical framework for the intervention design; p=0.01).
- Twenty-one studies included educational interventions directed at parents or caregivers—13/21 (62%) of which found statistically significant improvements in processes and outcomes of care for children with asthma. We found that among all studies of pediatric asthma evaluating self-monitoring, self-management, or patient education interventions, those directed at parents or caregivers were the most likely to be associated with a statistically significant improvement in clinical outcomes such as improvements in asthma symptoms or spirometric measures (p=0.02). The educational interventions directed at young children that did not include parental involvement did not consistently find statistically significant improvements in the processes or outcomes of care for the asthmatic patients.
- None of the six patient education interventions that exclusively targeted adolescents resulted in statistically significant improvements in medication use, asthma symptoms control, or health services utilization. This included studies that relied on peer teachers or intensive educational programs from physicians or nurse educators.
- Twenty-seven self-monitoring, self-management, or patient education studies reported the mean (or median) days lost from school. The weighted mean difference in days absent between intervention and control groups was -0.11 days/month (95% CI: -0.17, -0.05; p=0.0004); however, the studies included in this analysis were highly statistically heterogeneous. The longer the intervention duration, the greater the observed reduction in asthma-related school absenteeism (p<0.0001).
- The use of video games or Web-based programs as educational or self-monitoring or self-management tools for children with asthma (eight studies) was not associated consistently with statistically significant improvements in outcomes or processes of care for children with asthma.

We identified 78 studies of self-monitoring, self-management, or patient education interventions for general populations or adults with asthma.

- Of these, 17 reported change in percent predicted FEV_1_ from which we were able to calculate individual study and a summary standardized mean difference (between intervention and control subjects at the end of the study). These studies were statistically homogeneous and produced a weighted mean difference of 2.92 percent predicted FEV_1_ (95% CI: 0.92, 4.92) favoring the intervention groups (p=0.004). The more recent the year of publication, the greater the likelihood of finding improvements in percent predicted FEV_1_ (p=0.004).
- Sixteen studies reported mean peak flow at the end of the study period. The weighted mean difference from these 16 (statistically heterogeneous) was 27.95 L/min (95% CI: 10.75, 45.15) favoring the intervention groups (p=0.01).
- The use of combinations of educational techniques including individualized interactions, group interactions, role-playing, and distribution of printed materials was associated with greater improvements in outcomes than the use of single educational techniques.
- The longest interventions were more likely to report a statistically significant reduction in emergency department visits (p=0.02).
- We did not find that the frequency of patient interactions with the provider of the educational intervention was a key factor in producing improvements for patients.

Provider Education. We found seven articles reporting interventions designed to provide training for clinicians caring for children with asthma (typically these programs reviewed asthma diagnosis and management guidelines)—all of which found statistically significant reductions in patients' use of medications (several also reported reductions in asthma symptoms and emergency department visits). We found eleven additional articles reporting on interventions with some component of provider education for adult patients with asthma—55% of these reported that providers receiving the education improved adherence to asthma management guidelines (most often, providing written asthma management plans and increasing the rate of prescription of inhaled corticosteroids). However, only 27% reported improvements in health services utilization and only 9% reported improvements in clinical outcomes. The heterogeneity among the provider education interventions limited our ability to determine which components led to the greatest benefit for patients with asthma.

Organizational Change. We found 13 studies of organizational change strategies designed specifically to benefit children with asthma.

- These studies were relatively heterogeneous and not as likely as other types of QI interventions included in this review to report improvements in outcomes for patients: three (23%) reported improvements in clinical outcomes, three (23%) reported improvements in health services utilization, and three (23%) reported improvements in functional status. The other four studies (31%) reported no improvements for patients with asthma.
- Two of the included studies evaluated the use of directly observed therapy for children with asthma (usually by a school nurse). Both studies found that far more children in the intervention groups received their inhaled corticosteroids than those who received their medications at home.

We found 14 studies of organizational change strategies for general populations or adults with asthma.

- In contrast to the organizational change interventions for children with asthma, these 14 studies reported considerably more improvements in outcomes for patients. The organizational change interventions for general populations or adults were more likely to augment providers' roles (e.g., adding a teaching role to pharmacists already providing routine pharmacy care for patients) or augment the types of providers encountered while receiving “usual care” (e.g., by adding multidisciplinary teams to routine clinical practice). This is in contrast to the addition of specialty care clinics where patients receive care that is distinctly separate from their routine health care encounters (these specialty clinics were more common for children).
- 11 of the 12 organizational change interventions that combined self-monitoring, self-management or patient education with organizational changes (such as adding pharmacists to multidisciplinary teams) resulted in improvements in the processes and outcomes of care for adults with asthma.

Other QI Interventions. We found five studies describing audit and feedback interventions, four articles describing provider reminders, five interventions that utilized the facilitated relay of clinical data for the improvement of care for children with asthma, and two articles that included financial incentives to improve care for patients with asthma. The small number of studies of these types of QI interventions limited our ability to evaluate their effectiveness for improving asthma care, but are described individually in this report.

Costs. Twenty-three studies reported cost data associated with QI interventions for children (13 studies) and for general populations or adults with asthma (ten studies).

- Nine studies described the costs associated with intervention implementation: two of these found that there was no statistically significant difference between intervention and control program direct costs. The other seven studies uniformly found that intervention program costs were higher than control program costs.
- Among the interventions for children with asthma, seven reported asthma-related healthcare cost data, five of which reported reduced costs among the intervention groups relative to control groups. Among the interventions for general populations or adults with asthma, four presented asthma-related healthcare costs, two of which found cost savings among the intervention groups.

Quality of Life. Forty-five of the included studies reported QOL data.

- They utilized a variety of both generic measures such as the SF-36 and disease-specific measures such as the Asthma Quality of Life Questionnaire and the St. George's Respiratory Questionnaire, among others.
- Thirteen of 31 (42%) of the interventions aimed at general populations or adult patients resulted in statistically significant improvement in QOL compared to controls, whereas only nine of 12 (25%) of the interventions aimed at children produced a similar result. The other studies reported no difference between control and intervention groups in terms of QOL. Overall, the pediatric QI interventions reported little effect on parent or caregiver quality of life.
- We found that improvements in QOL and clinical status (p=0.02) were correlated, as were improvements in QOL and functional status (p=0.04).

Tobacco Smoke Exposure. Twelve studies reported either post-intervention tobacco exposure rates or reported whether there was a difference at the end of the intervention between intervention and control subjects.

- The reported rate of tobacco exposure among children with asthma of lower socioeconomic groups was higher than that of higher socioeconomic groups.
- None of the included interventions resulted in statistically significant reductions in tobacco use among patients with asthma or their family members (however, only some of these interventions were designed specifically to reduce tobacco smoke exposure).
- Preliminary evidence suggests that patients with asthma not exposed to tobacco smoke may benefit to a somewhat greater extent from QI interventions than those exposed to smoke.

## Summary Answers to the Key Questions

Research Question 1: What is the evidence that QI strategies improve the processes and outcomes of outpatient care for pediatric and adult populations with asthma?

- The QI interventions with the richest evidence base are those that employ self-monitoring, self-management, or patient education strategies. Specifically, for young children—even those from lower socioeconomic groups—educational strategies targeting their caregivers or parents can contribute to statistically significant reductions in asthma symptoms. For general populations or adults with asthma, numerous educational strategies were associated with improvements for patients—however, those that include a component of organizational change (e.g., adding a pharmacist to the team caring for the patient) were consistently found to improve patient outcomes.
- Interventions that are based on a theoretical framework, use multiple educational sessions, have longer durations, and use combinations of instructional modalities (e.g., small group teaching with role-playing and handouts) are more likely to result in improvements for patients than interventions lacking these characteristics.
- Provider education strategies directed at clinicians caring for children with asthma have resulted in improvements in medication use and adherence to practice guidelines.
- We found no evidence that the types of QI strategies reviewed in this report are consistently associated with improvements in the processes or outcomes of care for adolescents. Nor did we find that the QI interventions resulted in statistically significant reductions in tobacco smoke exposure, although this was not the primary objective of the included studies.
- The use of school personnel to administer directly observed therapy has been shown to increase the rate of inhaled corticosteroid use and reductions in health services utilization among school children with asthma, particularly in those who are not exposed to second hand smoke.
- We did not find that a particular setting (or combination of settings) of the QI intervention consistently predicted its effectiveness. We did not have sufficient evidence to assess the differential benefit of asthma QI strategies in urban vs. rural groups or among groups of differing socioeconomic status.

Research Question 2: Are QI interventions for asthma care that incorporate multiple strategies more effective than those that employ a single strategy?

The majority of the included articles evaluated a single QI strategy. However, 75 studies evaluated QI interventions with two or more QI strategies (e.g., interventions that combined both patient education and organizational change), 21 studies evaluated QI interventions with more than two QI strategies. We found that the greater the number of QI strategies, the more likely a study was to report improvements in clinical status (p=0.009).

## Discussion

Our review had several key findings.

- Most of the QI interventions in this evidence report were designed to achieve a change in behavior. Thus, we reasoned that interventions specifically designed to comport with the principles of effective behavior change would be more likely to produce improved outcomes for patients. Even among the included studies that “described” a theoretical foundation for the design of their intervention (44% overall), many provided very scant information about the rationale for the specific design characteristics of the intervention. For the QI interventions for which we found large numbers of articles (namely, self-monitoring, self-management, or patient education), we found that those studies that described a theoretical framework were more likely to report statistically significant improvements in some outcomes. Given the robust literature on intervention characteristics associated with durable behavior change, future QI interventions for improving asthma care should strive to incorporate those characteristics with a history of effectiveness in similar situations.
- Children, particularly the very young, are unlikely to have either adequate asthma knowledge or the capacity to take disease modifying actions without considerable assistance from their caregivers. We found that the interventions directed at children that did not also include parental involvement were less effective, suggesting that parallel educational activities, focusing on parents as well as their children, may be needed.
- The use of school personnel to administer directly-observed therapy increased the rate of inhaled corticosteroid use and decrease health services utilization among school children with asthma, particularly those who are not exposed to second-hand smoke.
- For general populations or adults with asthma, educational interventions, particularly those that used combinations of educational modalities and that provided multiple educational sessions over longer durations, were associated with statistically significant improvements in spirometry and days lost from work. However, the clinical significance of these improvements is modest.
- We found that the greater the number of QI strategies, the more likely a study was to report improvements in clinical outcomes. In particular, we found that patient and provider education interventions that also included an element of organizational change (for example, by adding pharmacists to the clinical team or by instituting an information system that facilitates reporting of clinical information between patients and providers) were often associated with improvements in outcomes for patients.
- We found high rates of tobacco exposure among both adults and children with asthma—particularly in lower socioeconomic groups. While the rates of smoke exposure did not change as a result of the QI interventions, some subgroup analyses suggested that improvement resulting from the QI strategy were more likely to occur in the groups not exposed to tobacco smoke. Given the association between smoke exposure and socioeconomic status, it is not clear whether the smoke exposure or other factors associated with patient demographics contributed to this trend.

## Future Research

- None of the six studies of educational interventions that specifically targeted adolescents with asthma, even those that relied on peer teachers or intensive educational programs from physicians or nurse educators, resulted in statistically significant durable improvements in medication use, asthma symptoms control, or health services utilization. However, positive effects were seen in studies that included (but did not specifically target) adolescents. Clearly, identification of interventions that result in effective behavior change for this vulnerable population requires further investigation.
- Many types of QI interventions have not been adequately studied (e.g., audit and feedback, provider reminders, facilitated relay). Since some of the studies showed promising results, interventions of these types should be studied in rigorously designed clinical trials.
- Relatively few of the included studies reported on the costs associated with their interventions. Thus, the extent to which expenditures change with QI interventions for asthma has not been well documented. A critical gap in this literature that prevents an understanding of the cost-effectiveness of QI programs is that there is not a common effectiveness variable such as symptom-free days gained or episode-free days gained. Also, since many studies only include the costs and benefits accrued during the first year after an intervention, it is difficult to estimate the long-term cost-effectiveness of these programs. Given the enormity of the costs associated with asthma care, these are critically important areas for future research.