# Acknowledgments

We thank Jessie McGowan of the Cochrane Effective Practice and Organisation of Care (EPOC) group and Shirley Ward of the Cochrane Consumers and Communication Group for their help with the literature searches. Thanks also to Corinna Haberland for help with data abstractions and Cristina Galvin for administrative assistance with this report. We also acknowledge with much gratitude our expert advisors and peer reviewers who are listed in Appendix D *.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/asthmagaptp.htm