# Discussion

This systematic review of 171 QI interventions for asthma care had several key findings. First, we note that most of the QI interventions in this the evidence report were designed to achieve a change in behavior—on the part of patients with asthma, or their parents or caregivers, or their healthcare providers. Our results confirmed what has been demonstrated in the literature of fields such as psychology and organizational theory: Some behaviors (such as adopting a practice of measuring one's peak flow when asthma symptoms start to flare up) are easier to change than others (such as stopping smoking). Given that an objective of the QI interventions was to change behavior, we reasoned that interventions specifically designed on the principles of effective behavior change would be more likely to produce improved outcomes for patients. For example, evaluations of behavior change interventions have demonstrated that a key component of successful interventions is understanding the barriers to providing high quality care. The included studies rarely described even basic information about underlying reasons for gaps in care that their interventions were trying to address. Even among the included studies that described a theoretical foundation for the design of their intervention (44% overall), many provided very scant information about the rationale for the specific design characteristics of the intervention. For the QI interventions for which we found large numbers of articles (namely, self-monitoring, self-management, or patient education), we did find that those studies that described a theoretical framework were more likely to report statistically significant improvements in some outcomes. Given the robust literature on intervention characteristics associated with durable behavior change, future QI interventions for asthma care should strive to incorporate those characteristics with a history of effectiveness in similar situations.

Second, children, particularly the very young, are unlikely to have either adequate asthma knowledge or the capacity to take disease modifying actions without considerable assistance from their caregivers. Not surprisingly, we found that the interventions directed at children that did not also include parental involvement were less effective, suggesting that parallel educational activities, focusing on parents as well as their children, may be needed. Also, the use of school personnel to administer directly-observed therapy may increase the rate of inhaled corticosteroid use and decrease health services utilization among school children with asthma, particularly those who are not exposed to second-hand smoke. These findings are congruent with the theoretical framework set out by several authors on behavior change for asthma. Namely, that the successful management of asthma requires both knowledge about the disease, its prevention, and treatment and also the capacity to take action to modify exposure to triggers and change medication use in response to changes in disease status.

Third, we were interested in evaluating whether interventions that combined multiple QI strategies would be more likely to benefit patients with asthma than those that utilized a single strategy. We found that the greater the number of QI strategies, the more likely a study was to report improvements in clinical outcomes. In particular, we found that patient and provider education interventions that also included an element of organizational change (for example, by adding pharmacists to the clinical team or by instituting an information system that facilitates reporting of clinical information between patients and providers) were often associated with improvements in outcomes for patients.

Finally, we set out to identify and catalog a broad array of studies that might inform the design and implementation of future asthma QI interventions. By assembling the information on these studies, we are able to generate hypotheses about the comparative advantage of different QI strategies for improving asthma care. The QI strategies with the greatest body of evidence of effectiveness include the self-monitoring, self-management, or patient education interventions. Other strategies worked well in specific circumstances. There is not sufficient evidence to determine definitively which strategy or strategies work best for a given situation. However, the strength of our approach is that we describe the range of QI interventions that have been evaluated under numerous clinical circumstances so that others may review the evidence relevant to their particular constraints.

## Limitations

This review has several limitations. First, the included articles were highly heterogeneous with respect to the rigor of the QI strategies implemented, the quality of their study designs, and the details provided about each. We had hoped to be able to identify specific intervention characteristics associated with the greatest improvements for patients with asthma. However, we were limited by the lack of detailed information about the interventions or baseline data for the outcomes of interest. Absence of specific information about the intervention's design limits reproducibility and understanding of the extent to which interventions may be relevant for use in other populations or other settings.

Second, we were limited in our ability to detect benefits for those QI strategies for which there have only been a small number of published studies that met our inclusion criteria. Similarly, because too few studies reported the same specific outcomes (e.g., improvement in FEV_1_ or hospitalizations within a given time frame), we used a composite outcome for some of our analysis (namely, any statistically significant result reported for one or more of the four outcomes of interest: clinical status, functional status, health services utilization, or guideline adherence). The use of this composite outcome limited our ability to delineate which QI strategies were more likely to be associated with improvements in each of the four outcomes of interest.

Third, for some of the outcomes reported by the included articles, it is difficult to evaluate their clinical relevance. For example, some studies reported that the intervention group was found to have improvements in inhaler technique relative to the control group; however, we could not evaluate the clinical relevance of this finding—was the incremental improvement in technique of sufficient magnitude that patients would likely have fewer symptoms or require fewer hospitalizations?

Finally, for studies that reported outcomes at multiple time points during and after the intervention, we only abstracted information about the longest period of follow up. Therefore, we may have missed initial improvements in outcomes if they were not durable over time.

## Future Research

Our results suggest that QI interventions that specifically target adolescents require additional evaluations. None of the six studies of educational interventions that exclusively enrolled adolescents with asthma resulted in statistically significant durable improvements in medication use, asthma symptoms control, or health services utilization. However, some of the other interventions that included adolescents in their populations did find improvement—the extent to which they resulted in improvements specifically for adolescents is unknown. Clearly, identification of interventions that result in effective behavior change for this vulnerable population requires further investigation.

Additionally, some authors found that improvements from QI interventions were more likely to occur among patients who were not exposed to tobacco smoke. A potentially confounding factor is that tobacco use was more common in lower socioeconomic groups. These findings suggest the need for additional research to evaluate whether the differential response to QI interventions is related to smoke exposure, socioeconomic status, or other factors.

For some QI strategies, we found a statistically significant association between the year that the intervention was performed and improvements in patient outcomes. However, we did not identify why more recent interventions might produce incrementally better outcomes for subjects relative to controls. This is an area for further investigation.

A number of QI interventions have not been adequately studied (e.g., audit and feedback, provider reminders, facilitated relay). Interventions of these types should be studied in rigorously designed clinical trials.

Relatively few of the included studies reported on the costs associated with their interventions. Thus, the extent to which savings may be obtained from QI interventions for asthma has not been well documented. A critical gap in this literature that prevents an understanding of the cost-effectiveness of QI programs is that there is not a common effectiveness variable such as symptom-free days gained or episode-free days gained. Also, since many studies only include the costs and benefits accrued during the first year after an intervention, it is difficult to estimate the long-term cost-effectiveness of these programs. Given the enormity of the costs associated with asthma care, these are critically important areas for future research.

## Conclusions

A wide variety of types of QI interventions have been found to improve the outcomes and processes of care for children and adults with asthma. The QI interventions with the richest evidence base are those that employ self-monitoring, self-management, or patient education strategies. Young children with asthma benefit most from QI strategies that also include their caregivers/parents. In general, interventions that are based on a theoretical framework, use multiple educational sessions, have longer durations, and use combinations of instructional modalities are more likely to result in improvements for patients than interventions lacking these characteristics.