# Results

## Results of Literature Search and Article Review Process

Figure 2 presents the results of our search strategy and article review process. Our searches yielded 3843 potentially relevant articles of which 530 articles merited full-text review. A total of 200 articles reporting on 171 unique populations met our inclusion criteria. Appendix C * provides the citations of articles excluded after the full text review, along with the reason for exclusion.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/asthmagaptp.htm

Figure 2. Search results

## Summary of Included Studies

### General Characteristics of Included Studies

The 171 included studies were highly heterogeneous with respect to study design, the types of QI strategies evaluated, the populations of interest, and types of outcomes reported. In this section, we describe these characteristics (Table 2).

Table 2 Design attributes of the included studies

Design Attribute | Number of studies reporting this attribute/Total number eligible to have this attribute
All studies (n=171)
If the unit of analysis differed from the unit of treatment allocation (i.e., the trial was “clustered” by provider or clinic) the authors acknowledged this issue or made appropriate adjustments | 14/30
Reported obtaining informed consent | 107/171
Described basing the intervention design on a theoretic or empiric foundation | 76/171
Controlled Before-After Trials (n=32)
It was specifically reported that measurements in the control group were performed at the same time in the intervention group | 30/32
The criteria used for selecting control sites were explained | 31/32
The control site was comparable to the experimental site in terms of patient and provider characteristics | 30/32

Study Design. Of the included articles, 134 (78%) were RCTs, five (3%) were quasi-RCTs and 32 (19%) were controlled before-after trials. Of these, 35 (21%) studies compared two or more interventions without a control group that did not also receive a QI intervention. (Studies of this design all evaluated either self-monitoring, self-management, or patient education interventions.)

RCTs were much less likely to report statistically significant improvements in the processes and outcomes of care for patients with asthma than were studies of other designs (Table 3).

Table 3 Association of study design and patient outcomes

Study Design | Number of Studies | Reported improvements in clinical status | Reported improvements in guideline adherence | Reported improvements in functional status | Reported improvements in health services utilization
Controlled before-after trial | 32 | 15 (47%) | 16 (50%) | 2 (6%) | 8(25%)
RCT | 134 | 44 (33%) | 32 (24%) | 19 (14%) | 23 (17%)
Quasi-RCT | 5 | 4 (80%) | 1 (20%) | 1 (20%) | 4 (80%)
p value* | - | 0.04 | 0.012 | 0.4 | 0.002

* Chi squared test of study design × improvement in each type of outcome. We note that not all of the studies were designed to evaluate all types of outcomes.

Sample Size. The median sample size was 109 (Interquartile range: 54, 205). Many of the included studies were small: 78 (46%) had total sample sizes of 100 subjects or less (Table 4). We did not find an association between sample size and the likelihood that a study reported statistically significant outcomes (Table 4).

Table 4 Association of sample size and patient outcomes

Sample Size | Number of Studies^§^ | Reported improvements in clinical status | Reported improvements in guideline adherence | Reported improvements in functional status | Reported improvements in health services utilization
Up to 100 subjects | 78 | 28 (36%) | 24 (31%) | 7 (9%) | 16 (21%)
More than 100 subject | 86 | 34 (40%) | 23 (27%) | 15 (17%) | 17 (20%)
Odds Ratio*(95% CI) | - | 0.8 (0.4, 1.5) | 0.8 (0.4, 1.6) | 2.1 (0.82,5.6) | 1.0 (0.4,2.1)

* Mantel-Haenszel Odds Ratio between the smaller and larger studies;

§ 7 studies did not report sample size. We note that not all of the studies were designed to evaluate all types of outcomes.

When interpreting the results of the included studies, it is important to consider that few presented power calculations and those that did were often underpowered to find small effects. This may be particularly relevant for interventions directed at patients with mild asthma where the outcomes of interest are relatively rare events such as annual hospitalizations. Additionally, many of the included studies evaluated numerous outcomes and did not make adjustments for multiple comparisons. Because nearly all of the included studies used the sample size that completed the intervention or follow up period in their calculations of effect size (i.e., did not perform intention-to-treat analysis), in the evidence tables, we report the number of subjects in the intervention and control groups at the end of the trial. For those few studies that did perform an intention-to-treat analysis, we present the sample size at the time of randomization or treatment allocation.

Intervention Characteristics. Articles often did not report detailed information about the interventions. For example, for educational interventions, we were interested in key aspects of the interventions such as the teaching modalities used, number of sessions subjects received, number of students in the “small groups,” the specific content of the curriculum, the training of the instructor, etc. However, the included articles often presented at most a few sentences describing the intervention. In the evidence tables in the sections that follow, we present the abstracted information on each included study and for those studies with detailed intervention descriptions, we noted this.

From each of the included articles, we abstracted whether the investigators cited previous literature or a theoretical framework to describe the evidence base for their proposed intervention. The included articles often provided scant information about whether the design of the QI intervention had a theoretical basis (e.g., the mechanism by which the chosen intervention might influence individual behavior or organizational culture and structure). In other words, numerous studies provided little or no answer to the question of why a particular QI strategy was selected to address a given problem. Only 76 (44%) of the included studies in our report specifically described a theoretical framework for their intervention. When we consider all of the included studies (combining across all types of QI strategies), we did not find that the studies reporting a theoretical framework were more likely to find improvements in outcomes for patients with asthma (Table 5).

Table 5 Association of specifying a theoretical framework and patient outcomes

Theoretical Framework Specified | Number of Studies | Reported improvements in clinical status | Reported improvements in guideline adherence | Reported improvements in functional status | Reported improvements in health services utilization
Yes | 62 | 26 (42%) | 25 (40%) | 14 (22%) | 20 (32%)
No | 87 | 37 (43%) | 24 (28%) | 8 (9%) | 15 (17%)
Odds Ratio*(95% CI) | | 0.8 (0.4, 1.5) | 1.5 (0.75, 2.8) | 2.5 (0.97,6.2) | 1.9 (0.90,4.0)

* Mantel-Haenszel Odds Ratio. We note that not all of the studies were designed to evaluate all types of outcomes.

Subject Characteristics. Studies varied with respect to their target populations of interest. For example, 79 studies targeted children exclusively, whereas 92 studies targeted general asthma populations that included primarily adults. Throughout this report, we present the interventions designed specifically for children separately from those that were for general, primarily adult, populations. Six of the 79 studies exclusively enrolled adolescents—they differed in terms of their definitions of adolescents (e.g., 12 to 16 years old). In 20 studies, providers (i.e., physicians, nurses, or pharmacists) were the target of the intervention (typically, provider education or provider reminder interventions). The other interventions were primarily directed at patients with asthma or their caregivers.

We were interested in abstracting data for subjects' baseline asthma severity (as measured by number of medications, number of annual physician and emergency department visits, and spirometric values); however, these data were reported sufficiently infrequently and in highly heterogeneous manner. To the extent possible, we present asthma severity information on each of the included articles in the evidence tables.

The included articles studied asthma patients from around the world: 73 were from the U.S., 27 from the U.K., 11 from Australia, 11 from Canada, eight from the Netherlands, five from Sweden, 23 from elsewhere in Europe, four from South America, and three from India, among others. In the evidence tables, we describe the location where the intervention took place.

QI Intervention Characteristics. The interventions occurred between 1976 and 2004 and ranged in length from 4 weeks to 5 years (median: 12 months) (Figure 3). For those studies that reported data at multiple post-intervention intervals, we abstracted data from the longest period of follow up.

Figure 3. Intervention duration

Intervention duration. We found that studies with longer interventions were more likely to report improvements in health services utilization (p=0.011) (Table 6). This may be because visits to the emergency department or urgent care or hospitalizations are relatively rare events (especially among patients with less severe asthma) and reductions in these events accrue only over longer follow up periods. We did not find that longer interventions were associated with improvements in clinical status or other outcomes of interest. This may be in part due to some initial effects of the intervention waning with longer follow up periods.

Table 6 Association of study duration and patient outcomes

Duration (months) | Number of Studies* | Reported improvements in clinical status | Reported improvements in guideline adherence | Reported improvements in functional status | Reported improvements in health services utilization
0–5 | 33 | 12 (36%) | 12 (36%) | 3 (9%) | 3 (9%)
6–10 | 43 | 16 (37%) | 11 (26%) | 6 (14%) | 5 (12%)
12–60 | 92 | 35 (38%) | 26 (28%) | 13 (14%) | 27 (29%) ^§^

* Note: 3 studies did not report their duration of follow up.

§ Chi squared test, p=0.011.

We note that not all of the studies were designed to evaluate all types of outcomes.

Intervention settings. The interventions took place in various settings including outpatient clinics, home, and school (Figure 4). Most of the interventions in schools and patients' homes were directed at children with asthma or their parents or caregivers.

Figure 4. Intervention settings

Types of QI strategies. Table 7 presents the distribution of type of QI strategies implemented in the included articles. Most of the included articles described self-monitoring, self-management, or patient education interventions. None of the included articles described patient reminder systems.

Table 7 Distribution of included studies by type of QI strategy

QI Strategy | Pediatric Studies* | General Population or Adult Studies | Total
Self-monitoring or self-management | 35 | 59 | 94
Patient or caregiver education | 54 | 46 | 100
Provider education | 7 | 11 | 18
Organizational change | 13 | 14 | 27
Audit and feedback | 0 | 5 | 5
Provider reminders | 1 | 3 | 4
Patient reminders | 0 | 0 | 0
Facilitated relay of clinical data to providers | 3 | 2 | 5
Financial, regulatory, or legislative incentives | 1 | 1 | 2

* Note: The pediatric studies described here included only children. The general population or adult studies typically included adults only; however, some of these were of general populations of patients with asthma that included both children and adults.

Combinations of QI strategies. Most of the included articles evaluated a single QI strategy. However, 75 studies evaluated QI interventions with two or more QI strategies (e.g., interventions that combined both patient education and organizational change) (Table 8). We found 21 studies of interventions of more than two QI strategies. Among those interventions with more than one QI strategy, the most common was the combination of self-monitoring, self-management, and patient education. We note that these are overlapping educational classifications and can be considered a single, broad-based educational strategy. For those interventions including other strategies, organizational change was the next mostly likely to be included (e.g., self-monitoring, self-management, or patient education with organizational change). We found that the greater the number of QI strategies, the more likely a study was to report improvements in clinical status (p=0.009) (but not the other primary outcomes of interest) (Table 8).

Table 8 Association of combinations of QI strategies and patient outcomes

Number of QI Strategies in the Intervention | Number of Studies | Reported improvements in clinical status | Reported improvements in guideline adherence | Reported improvements in functional status | Reported improvements in health services utilization
1 | 96 | 28 (29%) | 27 (28%) | 12 (13%) | 19 (20%)
2 | 54 | 22 (41%) | 18 (33%) | 6 (11%) | 11 (20%)
3 | 17 | 9 (53%) | 4 (24%) | 3 (18%) | 4 (24%)
4 | 4 | 4 (100%) | - | 1 (25%) | 1 (25%)
p value* | - | 0.009 | 0.5 | 0.8 | 0.9

* Chi squared test of number of QI strategies × improvement in each type of outcome. We note that not all of the studies were designed to evaluate all types of outcomes.

Outcomes Evaluated. We abstracted data on four primary outcomes (measures of clinical status, measures of functional status, measures of health services utilization, and measures of adherence to guidelines) and three secondary outcomes (health-related quality of life, exposure to environmental triggers such as tobacco smoke, and costs). Table 9 presents the distribution of the types of outcomes commonly reported in the included studies.

Table 9 Number of studies reporting each outcome

Outcomes | Pediatric Studies | Adult Studies
Clinical status measures | 54 | 75
Asthma symptoms | 33 | 44
Symptom-free days | 16 | 10
Amount of medication used or prescribed | 23 | 45
Number of asthma attacks | 15 | 9
Pulmonary function: peak flow, FEV_1_, or other spirometric measures | 21 | 42
Functional status measures | 39 | 36
Activity restriction | 12 | 13
Days lost from school/work | 33 | 26
Health services utilization | 53 | 51
ED or urgent care visits | 43 | 35
Hospitalizations | 28 | 39
Office visits | 23 | 14
Guideline adherence | 44 | 47
Adherence with peak flow monitoring | 14 | 15
Use of self-monitoring or self-management or action plans | 14 | 16
Inhaler technique | 9 | 16
Appropriate use of asthma medications | 12 | 21
Cost | 10 | 13
Quality of Life | 14 | 31
Tobacco Exposure Reduction | 6 | 6

Assessment for Publication Bias. We sought evidence for potential sources of publication bias. We found no statistically significant association between sample size and the study reporting a positive outcome (p=0.55). This finding was corroborated by visual inspection of the plots of the association of sample size and the likelihood of finding a statistically significant positive outcome (we present these funnel plots in the sections describing those outcomes).

Given the heterogeneity of the included studies, we synthesized data separately from each group of studies that evaluated the same type of QI strategy in the same population. In the sections that follow, we first present the evidence on the effectiveness of each type of QI strategy for children and adults with asthma from those studies that compared an intervention group receiving the QI strategy compared to a control group receiving usual care. We then present the results from those studies that compared more than one intervention group without including a control group that did not receive some QI intervention. Finally, we present the results synthesizing the outcomes across intervention types.

## Results by QI Intervention

### Self-Monitoring, Self-Management, or Patient Education Interventions

Inadequate asthma knowledge is an important factor in poor asthma management. ^27^ Asthma patients play a key role in their own care by identifying and reducing exposures to factors that may worsen their asthma and by adjusting medications to prevent asthma exacerbations. The International Consensus Report on the Diagnosis and Treatment of Asthma describes asthma management as having six parts, the first of which is “to educate patients to develop a partnership in asthma management.” ^28^ The purpose of patient education is defined as “a continual process designed to provide the asthma patient and the patient's family with suitable information and training, so that the patient can keep well and adjust treatment according to a medication plan developed with the clinician.” ^28^ Clearly, considerable overlap exists between patient education and self-monitoring or self-management interventions.

For the purposes of this report, we classified interventions as being principally self-monitoring or self-management if the goal of the intervention was to improve the ability of people with asthma or their caregivers to take action to reduce the impact of the disease on their lives, often through better monitoring of their symptoms and physiologic metrics. In contrast, we classified interventions as being principally patient education if the purpose was to increase asthma knowledge or improve inhaler technique without emphasizing patient decision making or changing behavior. We recognize that these are somewhat artificial distinctions and that many of the interventions include components of both. Accordingly, we present the evidence from self-monitoring, self-management, or patient education interventions in this single section.

We first briefly describe the results of systematic reviews of self-monitoring or self-management interventions. We then present the general characteristics of the self-monitoring, self-management, and patient education interventions encountered in the primary literature. Next, we present the results of the individual self-monitoring, self-management, and patient education intervention studies separately. However, for those studies that include both types of interventions together, we include them in both the self-monitoring, self-management, and patient education presentations. Finally we present the results of our synthesis of these studies—evaluating the components of the self-monitoring, self-management, or patient education interventions most associated with improvement in outcomes for patients with asthma. We first present the evidence from the interventions directed at children with asthma and their caregivers and then present the evidence from the interventions directed at general populations with asthma.

#### Systematic Reviews of Asthma Self-Monitoring, Self-Management, or Patient Education

There have been numerous systematic reviews of asthma self-monitoring, self-management or patient education—many of which have been methodologically rigorous. ^10,^ ^29^ – ^45^ We direct interested readers to these reviews for detailed descriptions of their results. In general, the results of these systematic reviews highlight the heterogeneity of these literatures, including disparities in the relevant information reported about the interventions and the content and educational approaches evaluated. A common finding was that interventions directed at improving patient knowledge, typically through non-interactive formats (e.g., lecture, video, print) do not necessarily improve health outcomes. In contrast, interventions that focus on improving self-monitoring or self-management skills through behavior change techniques, often result in reductions in health services utilization and asthma symptoms and improve functional status. The authors of the systematic reviews described the common methodological weaknesses in the evidence base: small sample sizes, lack of long-term follow up, and use of interventions without strong theoretical or empirical foundations.

The research question addressed by many of these reviews was whether written action plans improve the outcomes of care for patients with asthma. ^10,^ ^29,^ ^30,^ ^34,^ ^35,^ ^40^ For example, the 2001 AHRQ funded Evidence Report entitled, “Management of Chronic Asthma” ^10^ (which was used to inform the recommendations of the 2002 NHLBI asthma guideline) evaluated whether written asthma action plans improve asthma outcomes and, specifically, whether peak flow monitor-based plans are superior to symptom-based plans. They synthesized the evidence from 36 controlled trials of the efficacy of written asthma action plans to improve outcomes for pediatric and adult populations with asthma. The authors found that most study designs were confounded by multiple asthma management interventions—only nine studies with a total of 1501 patients evaluated self-management programs in isolation. ^10^ Of the five trials comparing a peak flow-based action plan to no action plan, only one found a statistically significant result—a reduction in emergency department visits for the peak flow-based action plan group. None of these five trials reported any other statistically significant difference in any other measure of clinical status or health services utilization. The authors note that most studies were underpowered to find statistically significant results. ^10^ They concluded that there was insufficient evidence to demonstrate an association between the use of written asthma action plans and improved asthma outcomes. ^10^ Moreover, they found that there was insufficient evidence to support the hypothesis that peak flow monitoring-based plans were superior to symptom-based plans. ^10^

The 2004 Cochrane review by Toelle and Ram was designed to assess whether the provision of a written individualized management plan increased adherence with self-monitoring or self-management behaviors. ^30^ Toelle and Ram concluded that there was insufficient evidence to recommend for or against the use of written management plans for asthma. Toelle and Ram commented that the failure to demonstrate any difference in health outcomes between written individualized plan groups and control groups may be because the provision of a written plan does not lead to any change in behavior or that enrollment in a study may lead to similar improvements in both control and intervention groups. ^30^

Additionally, although not systematic reviews, the Working Group Reports from the 1998 World Asthma Meeting are notable for providing succinct descriptions of key trials of a variety of self-management and patient education interventions and discussions of important gaps in the literature. ^46,^ ^47^ In particular, the article by Partridge and colleagues details the list of self-management skills (including self-monitoring) that are widely accepted as required for effective self care and reviews a number of interventions and international efforts to improve patient-provider communication, provider education, and policy-level interventions for asthma care. ^47^

In summary, prior systematic reviews found that non-interactive educational interventions were not effective, and that there was insufficient evidence to determine the value of written self-management plans.

To avoid duplicating the work done in prior reviews, we did not evaluate the comparative effectiveness of symptom-based versus peak flow-based self-monitoring or self-management interventions. Instead, our aim was to evaluate specific intervention characteristic (e.g., setting, teaching strategy, intensity of the intervention) and population characteristics (e.g., adolescents, country of residence) associated with improvements in outcomes of care for children and adults with asthma.

#### General Characteristics of Self-Monitoring, Self-Management, or Patient Education Interventions for Children With Asthma

Study Design Characteristics. Among the included articles, 69 had some component of self-monitoring, self-management, or education for children with asthma or their caregivers. The median duration of the follow up period was 12 months (S.D., 5.8 months). The median sample size of these interventions was 90 subjects (Interquartile range: 43, 181). Fifty-nine were RCTs, three were quasi-RCTs, and ten were controlled before-after trials. In univariate analysis, the longest studies were more likely to have the largest number of subjects (p=0.005). Eleven were primarily self-monitoring or self-management, 36 were primarily patient or caregiver education, and 13 included both.

Intervention Characteristics. The included interventions were highly heterogeneous in terms of educational materials provided, setting, frequency and duration of contact with asthma patients and their caregivers, among other key characteristics.

Forty-three (62%) specifically described an underlying conceptual framework or theoretical background as the basis for the intervention. We direct interested readers elsewhere for discussions of the theoretic foundations of asthma educational and self-monitoring or self-management interventions which include theories of empowerment, social ecology, self-regulation, and self-efficacy. ^48^ – ^50^ In univariate analyses, these studies tended to be more likely to report statistically significant improvements in emergency department visits (36 studies reported both emergency department visits and described a conceptual framework; p=0.014) but not the other outcomes of interest.

Nineteen of the self-monitoring, self-management, or patient education interventions were performed in outpatient primary care and most were taught by either physicians or nurses/nurse practitioners (Figure 5).

Figure 5. Intervention characteristics: setting and educator type

Thirty-two (46%) of the self-monitoring, self-management, or patient education interventions provided 2 to 5 educational sessions to the children or their caregivers. Twenty-six interventions principally provided individualized instruction, six principally used interactive group teaching sessions, and 23 used combinations of teaching modalities (Figure 6)

Figure 6. Number of educational sessions provided by educational strategy

Eight studies used video games or Web-based programs as educational or self-monitoring or self-management tools for children with asthma. ^51^ – ^58^ For example, “Bronkie's Asthma Adventure” (Click Health, Inc, Mountain View, CA) is a Nintendo^®^-based game that has been designed to teach children self-monitoring or self-management strategies and provide feedback (in English or Spanish language) on their performance. ^58^ Similarly, the “Asthma Control” video game features a superhero named “Spacer” whom the player has to lead through six game levels, accumulating points by avoiding both indoor and outdoor triggers/allergens and using controller medications. ^54^ The use of video games or Web-based teaching modalities was not associated consistently with statistically significant improvements in outcomes or processes of care for children with asthma.

Outcomes Reported. The 69 self-monitoring, self-management, or patient education studies reported on a variety of outcomes. The most frequently reported outcomes were asthma symptoms, days lost from school or work, urgent care or emergency department visits, and hospitalizations due to asthma. Relatively few studies reported on guideline adherence including adherence to self-monitoring or self-management plans. Table 10 presents a summary of the number of studies reporting each of the primary outcomes of interest. Thirty-one studies reported on asthma symptoms; however, these were measured in highly heterogeneous ways (e.g., self reported symptoms from children's diaries, physicians' ratings of asthma symptoms, multiple different asthma symptom questionnaires). Thirty studies reported on days lost from school or work due to asthma. Some authors adjusted days lost from school on the basis of expected seasonal variation in absenteeism, but most reported school days lost in the intervention group compared to the control group.

Table 10 Outcomes reported by the pediatric self-monitoring, self-management, or patient education studies

Outcomes | Number of studies reporting no difference between intervention and control subjects (%) | Number of studies reporting improvement among intervention compared with control subjects*(%) | Number of studies reporting this outcome
Clinical status measures^§^ | 21 (44) | 27 (56) | 48
Asthma symptoms | 13 (42) | 18 (58) | 31
Symptom-free days | 8 (57) | 6 (43) | 14
Amount of medication used or prescribed | 12 (67) | 6 (33) | 18
Number of asthma attacks | 9 (69) | 4 (31) | 13
Pulmonary function from peak flow, FEV_1_, or other spirometric measures | 13 (65) | 7 (35) | 20
Functional status measures | 21 (62) | 13 (38) | 34
Activity restriction | 5 (50) | 5 (50) | 10
Days lost from school/work | 21 (70) | 9 (30) | 30
Health services utilization | 27 (63) | 16 (37) | 43
ED or urgent care visits | 23 (64) | 13 (36) | 36
Hospitalizations | 19 (83) | 4 (17) | 23
Office visits | 14 (78) | 4 (22) | 18
Guideline adherence | 12 (44) | 15 (56) | 27
Adherence with PF monitoring | 3 (100) | 0 (0) | 3
Use of self-monitoring or self-management or action plans | 7 (64) | 4 (36) | 11
Inhaler technique | 3 (43) | 4 (57) | 7
Appropriate use of asthma medications | 4 (40) | 6 (60) | 10

* Note: In this table, we present data from all studies of pediatric self-monitoring, self-management, or patient education. These include those in which the intervention subjects were compared to control subjects who typically received “usual care” and the studies which compared two or more groups without a control arm that did not also receive a QI strategy.

§ For each of the categories of outcomes highlighted in bold (e.g., clinical status measures, functional status measures), we recorded whether the study reported one or more statistically significant changes between the intervention and control group at the end of the study period in any of the individual metrics associated with that outcome category.

#### Self-Monitoring or Self-Management Interventions for Children With Asthma

Background. The International Consensus Report on Asthma suggests that peak flows of 80 to 100% of the individual's best are satisfactory and necessitate only routine treatment. ^28^ Peak flows of 50 to 80% of personal best peak flow should stimulate a treatment change (e.g., increasing bronchodilators or anti-inflammatory medications). ^28^ Peak flows below 50% of personal best should lead the patient to use their urgent medications (e.g., start oral steroids) and seek medical attention. ^28^ Most of the self-monitoring or self-management interventions for children with asthma utilize a written, often color-coded plan in which instructions and medications are labeled (green) for routine care, (yellow) for caution/early treatment, and (red) for urgent treatment. The purpose of this section is to present the characteristics of the individual self-monitoring or self-management interventions.

Results. We found 35 interventions designed principally for the improvement of self-monitoring or self-management of asthma symptoms by children with asthma and their caregivers (24 of these studies are presented in Table 11). Nine of the pediatric self-monitoring or self-management studies compared two self-monitoring or self-management interventions without including a control group that did not also receive a self-monitoring or self-management intervention. ^55,^ ^56,^ ^59^ – ^65^ Studies with this design are described in detail in a subsequent section of the report (Table 21).

Table 11 Summary of self-monitoring or self-management interventions directed at children with asthma

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Agrawal et al. ^85^ | To evaluate the effects of adding a individualized written asthma home-management plan to standard asthma care. | 60 children aged 5–12 years with moderate persistent asthma in India. | RCT | 32 children completed the self-management program that included an individualized home-management plan (trained to perform PF measurement, use a PF and symptom diary, and given specific instructions for home medication management based on symptoms and PF measurement). 28 children completed the usual care arm. All subjects were followed weekly for 4 weeks then monthly for 3 additional months (7 visits). | 4 months after the intervention, children in the intervention group had fewer acute asthma events (p=0.02), fewer days missed from school (p=0.015), fewer nocturnal awakenings (p=0.001), and fewer symptoms (p=0.0006). ^85^
Bartholomew et al. ^53^ | To evaluate whether a computer-based asthma self-management tool would increase process and clinical outcomes of care for inner-city children with moderate to several asthma in Houston. | 133 children aged 6–17 with asthma. | RCT | 70 children used the Watch, Discover, Think, and Act multimedia CD-ROM program for variable amounts of time after their scheduled office visits. The program presents an “adventure game” in which the player makes choices to manage the game character's asthma (the game's character is matched with the subject on gender and ethnicity). Within the game, children can learn new skills, identify symptoms, reduce environmental triggers, and take preventative actions. 63 children received usual care with telephone reminders before their scheduled office visits. | 7.9 months after enrollment in the intervention, there were no differences between groups in the number of ED visits, hospitalizations, or symptoms. ^53^
Burkhart et al. ^71^ | To determine the effects of interventions that combine education and behavioral techniques in managing asthma at home. | 42 English-speaking children aged 7–11 years with persistent asthma in Kentucky; N_int_=21; N_con_=21. | RCT | Patients received asthma education and instructions on how to use an electronic PF meter twice daily and record data in an asthma diary. Patients received three 1-hour individual sessions with a nurse, a contingency management intervention, which consisted of a contingency contract, reinforcement, tailoring, and reminders. The contract outlined requested behaviors (PF monitoring, diary self-reporting) and associated rewards. (We describe the rewards used in the section on financial incentives.) A nurse educator also contacted patients weekly to reinforce teachings. The control group received the teaching sessions but no contingency contract and no follow up calls from nurses. | At 5 weeks, they found no difference in adherence with PF monitoring between the intervention and the usual-care (control group) children. ^71^
Cicutto et al. ^77^ | To evaluate whether an interactive childhood asthma education program improved asthma-related morbidity among elementary school children in Toronto, Canada. | 256 children with asthma in grades 2 to 5 (aged 6–11 years) and their parents. N_int_=132, N_con_=124. | RCT | The “Roaring Adventures of Puff (RAP)” consists of 6 sessions of 50–60minutes held once a week for 6 consecutive weeks. Sessions cover use of PF meters, diary monitoring, trigger identification and control, use of inhalers and medications, symptom recognition and action plan use, and managing asthma exacerbations. Parents are invited to the last session in which children showcase their learning and new skills. The strategies utilized included games, puppetry, and model building to teach about trigger identification, medication use, symptom recognition, sharing information with teachers and parents. | 12 months after the intervention, RAP attendees had 32% fewer urgent health visits (p<0.01), less asthma-related school absenteeism (p<0.05), and less activity limitation due to asthma (p<0.01) than control children. ^77^
Dahl et al. ^86^ | To evaluate the effects of a behavioral treatment program when superimposed on medical treatment. | 19 children in Sweden with severe asthma using continual β-agonist therapy. N_con_=10, N_int_=9. | RCT | All patients underwent a 4-week baseline period during which a behavioral analysis was made for each child and daily asthma charts were kept. Patients in the intervention group underwent a 4-week intervention period, during which they received four 1-hour individualized behavior therapy treatment sessions in their home or school focusing on discrimination training of asthma signals, self-management techniques for breathlessness, counter-conditioning any learned fear response, contingency management of asthma-related behavior, and compliance training. The control group received usual care. | All data were presented as comparisons of change from baseline. After 4 weeks of follow up, patients in the intervention group had a significantly larger reduction in “as needed” spray doses of β-agonist and a significantly larger reduction in days of school absenteeism compared to patients in the control group. There was no difference between the groups in PF values. ^86^
Evans et al. ^68^ | To evaluate whether a school-based self-management program would increase children's asthma management skills and other process and clinical outcomes for low income 3^rd^–5^th^ graders in public schools in New York. | 204 low income 3^rd^–5^th^ graders in public schools in New York, aged 8 to 11 with asthma. | CBA | 93 children attended the Open Airways program's six 1-hour small group sessions (over a 3 week period) in which children learned basic information about asthma, recognizing and responding to symptoms, using medications and when to seek help, keeping physically active, identifying and controlling triggers, and handling problems related to school. 87 control children received no additional self-management training. | 1 year after the program, experimental children reduced the annual frequency (p=0.024) and duration (p=0.007) of asthma episodes, and annual days with symptoms (p=0.004), and they increased their self-management index score compared to controls (p=0.05). There were no differences between the groups in terms of school attendance and number of episodes requiring a physician visit. ^68^
Fireman et al. ^81^ | To determine whether a nurse teaching self-management skills to children and their caregivers would improve their disease outcomes. | 26 children aged 2–14 with asthma in Pittsburgh | Sequentially assigned (not randomly) controlled trial | 13 children and their caregivers received 4 individualized sessions with a trained nurse on the use of symptom and medication diaries, two 2-hour group sessions for discussion of asthma management, and phone follow up every 3 months by the nurse. 13 children received usual care. | 13 months after enrollment, the intervention group had fewer asthma attacks (1.5 vs. 6 per child) (p<0.01) and less school absenteeism (0.5 vs. 4.6 days per child) (p<0.05). The authors reported fewer hospitalizations and ED visits for the intervention group but no statistical test for the difference between the groups. There was no difference in wheezing days per month. ^81^
Homer et al. ^54^ | To assess the effectiveness of multimedia educational software program about asthma for inner-city children. | Children aged 3 to 12 with asthma living in inner-city Boston. N_int_=57; N_con_=49. | RCT | “Asthma Control” is an interactive educational computer game designed to teach children about asthma and its management. The object of the game is to help the main character, Spacer, a superhero with asthma complete all 6 game levels (3 home and 3 outdoor levels). The player uses his or her knowledge of asthma to help Spacer eliminate common indoor allergens and to avoid outdoor allergens. If Spacer's condition worsens, the program producing coughing and wheezing sounds and he may not be about to jump or run. If the player does not eliminate allergens or use preventive medications, Spacer's mother blocks his/her exit from home. Study patients were asked to return to the study site 3 times to use the educational computer program. | During the one year study period, there were no differences between intervention and control children in terms of ED visits, acute office visits, asthma severity, exposure to environmental triggers, use of PF meters, or asthma management behaviors.
| | | | | Note: 40% of children enrolled in the study had exposure to a least one smoker at home. ^54^
LaRoche et al. ^78^ | To evaluate a multifamily asthma group self management program designed to be culturally relevant and encouraged group cohesiveness among the attending families. | 24 African American and Hispanic families living in Boston with children aged 7–13 with asthma. | RCT | The 24 experimental families were randomized to receive three 1-hour sessions that emphasized collaborative asthma management among patients, parents, and physicians and provided training on asthma symptoms and skills for self management. Half of the experimental families received encouragement to work as a group to share experiences and learn from each other. The 11 control families received no intervention. | During the year after the intervention, the experimental children from families that shared group experiences had fewer ED visits (0.7±0.9) than either the experimental children with standard self-management teaching (1.2±1.7) or controls (1.4±2.4) (p=0.04). There were no differences in self-management scores. The intervention program costs were approximately $2,295 (per 11 patients) and the savings from reduced ED visits was $4,675 (per 11 patients). ^78^
Maslennikova et al. ^82^ | To assess the effects of a adapting a U.S. self-management educational intervention on asthma outcomes for children in Moscow. | 122 children with asthma and their families living in Moscow. N_int_=60; N_con_=62. | RCT | The authors adapted “Open Airways” (developed for low literacy children aged 4–7 years) and “Air Power” (developed for average literacy children aged 8–14 years) for similar populations in Moscow. Intervention subjects also received asthma care from clinicians who had been trained “according to the U.S. guidelines for the diagnosis and management of asthma and use of modern asthma medications.” Intervention subjects participated in 4 weekly 1hr sessions. Control subjects received usual care from clinicians who received no additional training. | 1 year after the intervention, the % of children in the education group who were on inhaled anti-inflammatory medications increased by 46% compared to only 8% for the control group (p<0.05). Intervention children's PF measures also improved more than for control children (p<0.05). There was no difference in terms of the change in the percent of children using theophylline or β-agonists or days missed from school.
McGhan et al. ^76^ | To determine whether the asthma education program “Roaring Adventures of Puff (RAP),” improved asthma management behaviors and health status in elementary school children in Edmonton, Canada. | 136 children with asthma aged 7–12 years. N_int_=65; N_con_=71. | RCT | Parent and teacher asthma awareness events were held within the school setting. The intervention provided recommendations for school asthma guidelines and six educational group sessions for children with asthma described above. ^77^ | 9 months post-intervention, experimental children had “more appropriate use of preventive medication” (p<0.001), improvement in asthma-related limitations in play, (p<0.001) but there were no differences between groups in medication use, possession of an action plan, ED visits, unscheduled doctor visits, asthma symptoms, or days lost from school. 26% of the children had regular smoking in the home. ^76^
McNabb et al. ^80^ | To evaluate whether children with asthma who had not been compliant with standard medical management would benefit from self-management education that could be tailored to their educational and behavioral needs. | 14 children aged 9 to 13 with asthma in northern California. | RCT | Experimental subjects (N=7) received a 30 minute diagnostic interview followed by four 45-minute individually tailored weekly sessions with a nurse educator on asthma self-management. Control subjects (N=7) received usual care. | In the 12 months after the intervention, the experimental group averaged 1.9 emergency treatments compared to 7.4 for the control group (no p value provided). There were no differences in non-emergency visits or drug use between groups. They estimated a program related $507 per child savings on the basis of the reduced emergency visits. ^80^
Morgan et al., ^73^ Evans et al., ^74^ , and Sullivan et al. ^75^ | To evaluate whether a home-based intervention for inner-city children designed to teach caregivers to reduce environmental asthma triggers specific to that child would result in improvements in asthma-related outcomes. (The National Cooperative Inner-City Asthma Study.) | 1,023 families of children aged 5 to 11 with asthma from 8 major U.S. cities. N_int_=515, N_con_=518. | RCT | During the 12 month intervention, 2 research assistants visited each home 5 to 7 times. Each visit was followed by a phone call to address any barriers to implement the plan. Caregivers were taught about the role of allergens in asthma, mattress covers were installed, families were given a vacuum cleaner with HEPA filter and a HEPA air purifier was set up in the child's bedroom. Professional pest control was provided. | Two years after enrollment, intervention children had more symptom free days (565.1 vs. 538.5), fewer asthma symptoms (p<0.001), days lost from school (p<0.009), and allergen levels. ^73^ There were no differences in spirometry or PF measurements or unscheduled visits to the ED, clinic or hospital between the two groups. ^73^ – ^75^ The cost of the intervention was $337 per child for 2 years resulting in an estimate incremental cost-effectiveness ration of $9.20 per symptom-free day gained (95% CI: -$12.56 to $55.29 per symptom free day gained). ^75^
Pérez et al. ^66^ | To evaluate the effectiveness of a self-management program based on social learning models and self management programs with demonstrated effectiveness on asthma morbidity. | 29 children with asthma aged 6–14 years in Venezuela. | RCT | 17 children and their parents were randomized to receive asthma education. Parents received two 90 minute sessions on asthma pathophysiology, treatment and psychological factors associated with the disease. Children received six 60-minute self-management training sessions that included modeling, positive reinforcement, group dynamics, behavioral practice, role-playing, and feedback. | 6 months after the intervention, children reported fewer asthma crises, and their physicians reported less severe asthma than control patients (p<0.05). ^66^
Persaud et al. ^87^ | To evaluate the effects of a school-nurse based self management program for school children in Texas. | 36 children aged 8 – 12 years with moderate to severe asthma. | RCT | All children had a visit with a primary care provider at the time of enrollment during which time they were all given written guidelines for medication use, asthma control and prevention, PF meters, and asthma diaries. Intervention children (N=18) also received 8 individualized, weekly, 20 minute sessions with a school nurse to review asthma symptoms and medication and PF meter use. Control children (N=18) visited the school nurse sporadically, on their own initiation. | 20 weeks after enrollment, the percentage of children visiting the ED for asthma was higher in the control group (50%) than in the intervention group (22%, p<0.05); however, there were no differences in number of ED visits per child or days lost from school between groups. ^87^
Rakos et al. ^83^ | To evaluate the effectiveness of a self-administered self-management program for pediatric asthma. | 43 children aged 7–12 years with moderate to severe asthma in Cleveland. | RCT | 20 children and their caregivers received a “Superstuff” kit in the mail. This program, developed by the American Lung Association, includes a Parent's Magazine containing 29 articles on asthma pathophysiology, triggers, relaxation techniques, and personal control and decision making. The Children's Kit includes riddles about asthma facts, “breathe easy” board game, puzzles and dolls with self-care messages, comic strip about relaxation exercises, mystery house to discover allergens, phone book to advise when to call the doctor and record emergency numbers, and asthma-related door signs, posters, stickers, records, and paper cutouts. 23 children received usual care. | 12 months after receiving the intervention, parental reports suggest a significant decrease in “interruptions due to asthma” (p<0.04). No difference in school absenteeism between groups. The cost of the kits was $7. ^83^
Ronchetti et al. ^72^ | To compare the Open Airways program to Living With Asthma program among Italian children with asthma. | 209 children with asthma from 12 centers across Italy. | CBA | 58 children received either the original version of Open Airways or a 4 session abbreviated version, 56 children received either the original version of Living with Asthma or a 4 session abbreviated version (see text for intervention description). 95 children received usual care. | One year after participation, patients in the Open Airways but not the Living With Asthma groups has fewer emergency treatments for asthma than controls (p<0.03). ^72^
Runge et al ^52^ | To evaluate whether an internet-based education program as an add-on to a standard patient education program improved health outcomes and reduced costs of children with asthma in Germany. | 178 children with asthma aged 8–16. | CBA | 48 children in the control group received no education until after the trial. 86 children received the self-management program of five 2hr sessions in which they used role-playing and small group sessions to teach inhaler use, trigger avoidance, medication management, PF monitoring, and decision making. 44 children received this self-management program plus self-selected to also use the interactive internet adventure game incorporating virtual asthma-related situations in need of management and also provides access to online chats with asthma experts, an online PF protocol that can be maintained by the patient, and chat rooms for other users and healthcare providers. | 6 months after enrollment, the self-management plus internet (SMI) education group had a mean of 0 emergency visits compared to 0.2 for the control group (CG) and 0.3 for the self-management (SM) alone group (p=0.03). The SM group had significantly (p<0.05) fewer physician visits (-44%) and emergency treatments (-67%) than CG. PF improved in all groups, no difference among groups. Significant improvements were seen in 3 of 8 QOL domains in both intervention groups but not in the CG. It cost 585€ to deliver the SMI intervention which reduced asthma costs by 461€. Adjusting for benefits in the CG, 0.79€ were saved for every 1€ spent on the SMI intervention during the 1^st^ year. (1 year follow up data available for the two intervention groups but not the CG.) ^52^
Tieffenberg et al. ^67^ | To evaluate a chronic disease self management program based on behavioral change and learning theory directed at increasing autonomy on the part of children. | 188 children with moderate to severe asthma aged 6 to 15 in Argentina. | RCT | 65 children were randomized to receive 5 weekly 2-hour meetings with a reinforcement meeting 2–6 months later. The curriculum included identifying early warning signs and symptoms of an attack, identifying triggers, understanding therapies, and decision making skills through games, drawings, stories, videos, and role-playing. 52 children received usual care. | 12 months after the intervention, experimental subjects had fewer regular visits for asthma (p=0.048), asthma crises (p=0.36), and less school absenteeism (p=0.006 for fall/winter and p=0.029 for spring semesters) but no difference in emergency visits compared to controls. ^67^
Toelle et al. ^88^ | To evaluate whether a community-based asthma management program could reduce asthma symptoms and lung function among school children in Sydney, Australia. | 132 school children aged 8 to 11 with asthma and all the adults who influence their care including parents, doctors, pharmacists, community nurses and school teachers. | CBA | Children in the intervention group and their parents (N_int_=72) were invited to attend 2 education session each 2 hours, 1 week apart with a curriculum on asthma triggers, medication use, inhalation technique, use of written self-management plan. These children's physicians and pharmacists were invited to attend evening workshops during which asthma management guidelines were reviewed. Community nurses and school teachers in the intervention community received an in-service education session at their workplace. All families, children, physicians, and pharmacists who did not attend the intervention sessions were mailed the materials. 60 children received usual care. | 147 teachers and community nurses, 53 families (74%), 15 pharmacists (21%), and 11 physicians (20%) attended intervention sessions. 6 months after the intervention, both FEV_1_ and dose-response ratios improved in the intervention group but not the control group (p<0.001). The number of children with wheeze and symptoms that limit activity did not change but night cough decreased significantly in the intervention group (p<0.001). There was no significant difference in physician or ED visits or days absent from school. ^88^
Vazquez and Buceta ^79,^ ^89^ | To evaluate the effects of adding relaxation training to asthma self-management education to improve the care of children with asthma in Spain. | 27 children with “light or moderate” asthma aged 8 to 13 years. | CBA | 9 children in the control group received usual care; 9 children received six 1-hr weekly sessions with their parents on asthma pathophysiology, use of medication, identification of triggers, and breathing exercises; and 9 children received the self-management instruction plus additional training on relaxation techniques at the end of each self-management session. | At 12 months after the intervention, both intervention groups had better scores on the adherence with self-management behaviors scale used by this study compared to the control group but there were no differences among groups in terms of attack frequency or duration, PF, emergency medical consultations or school absenteeism. ^79,^ ^89^
Velsor-Friedrich et al. ^69^ | To examine the effects of a school-based intervention program on self care abilities, practices and health outcomes of children with asthma. | 102 African American 8–13 year old children with asthma recruited from 8 inner-city public schools in Chicago. | QRCT* | The Open Airways educational program utilized an interactive teaching approach applying group discussions, stories, games and role-playing to promote children's active involvement in the learning process. In six 45-minute sessions offered once a week, small groups of children learned new asthma management skills. N_int_=40, N_con_=62. | 5 months after completion of the program, the treatment group had significantly more improvement in PF measurements (7.5% vs. 2.9% improvement, p=0.046), reduction in number of days with symptoms (p=0.047), and number of urgent medical visits (p=0.01). No differences in terms of reported medication use or school absences. ^69^
Webber et al. ^70^ | To evaluated whether the Open Airways program would reduce asthma morbidity and health services utilization among inner-city children with asthma in the Bronx. | 599 3rd to 5th graders in the Bronx with asthma. | CBA | 599 children in schools with school-based health centers were scheduled to attend the Open Airways program (as described in the two prior studies). They were compared with students in schools with school-based health centers that did not offer the Open Airways program (N not specified) and children in control schools without school-based health centers (N not specified). | Approximately 15 months after enrollment, there were declines in office visits for children attending schools with school-based health centers (with and without the Open Airways program) but not for control school children (for whom there was a (9% increase in office visits) (p=0.01). ED use and hospitalizations declined for all children (no difference among groups). ^70^
Whitman et al. ^84^ | To evaluate the effects of a self-management curriculum on asthma knowledge, skills, and “asthma experiences.” | 38 children aged 6 to 14 in Utah. | RCT | 19 children received eight 90-minute classes for children and caregivers given twice a week for a month included education on breathing control skills, body relaxations skills, bronchial hygiene silks, and physical conditioning. Additionally, intervention subjects received the “Superstuff” kit described in Rakos. ^83^ 19 children received no training. | Three months after the intervention, there was no difference in number of asthma episodes or days without asthma between groups. Participants' knowledge (p=0.02) and asthma skills (p<0.01) improved compared to controls. ^84^

Note: Eight studies compared two self-management interventions without including a control group that did not also receive a self-management intervention. ^55,^ ^56,^ ^59^ – ^64^ Studies of this design are described in detail in a subsequent section of the report (Table 21).

* QRCT=quasi-randomized controlled trials. ED=emergency department. PF=peak flow. QOL=quality of life. CBA=controlled before-after trial.

Table 21 Trials comparing two or more intervention groups without a control group that did not also receive an intervention

Reference | Study Purpose | Target population | Study Design | Type of interventions | Results
Pediatric Interventions
Butz et al. ^61^ | To evaluate the effects of a home-based self management intervention that emphasized symptom recognition and nebulizer use for inner city children with asthma. | 210 children aged 2 to 8 years living in inner city Baltimore with asthma. | RCT | Group A. 105 children received 3 home visits to help establish primary care for the children and teach basics of asthma management including PF meter use. Group B. 105 children received 6 home visits to teach symptom identification, and the appropriate treatment of these with a home nebulizer. This intervention was based on several previously recognized successful educational programs. | 6 months after enrollment, both groups improved in terms of self-management skills (e.g., parents giving asthma medications when children have asthma symptoms). There were not significant differences between the groups in terms of adherence with self-management skills. ^61^
Chan ^57^ | To develop and evaluate an Internet-based store-and-forward video monitoring system for children with asthma. | 10 children aged 6 to 17 years with asthma in Hawaii. | RCT | All patients received a home computer system, video camera, microphone, and cable access to the internet. They used the camera and computer to demonstrate inhaler technique, record PF measurements and send in twice weekly symptoms diaries. Case managers (pharmacists) reviewed these data twice a week and sent back feedback via email. Group A. 5 patients received asthma education online. Group B. 5 patients received asthma education in the office. These patients used written (rather than electronic) symptom diaries. | There were no differences between the groups at the end of 180 days for any of the outcomes evaluated (e.g., amount of corticosteroids or β-agonists used, PF measurements, symptom control, QOL, or patient satisfaction). Inhaler technique improved for both groups (p<0.05) whereas compliance with PF meter use and symptom diary use declined over the study period for both groups. Asthma knowledge was good before the study and did not change significantly for either group after the study. ^57^
Charlton et al. ^64^ | To assess a nurse run asthma clinic in a department of pediatrics. | 79 children aged 3–16 who either required an admission or outpatient visit for asthma in Australia. | RCT | Group A. 42 children received a 45 minute standardized interview from an asthma nurse with explanations of mechanisms of disease, a self-management plan, PF meter and diary card. Every 3 months they received a notice to have their asthma reviewed by either the asthma nurse or their general practitioner. Group B. 37 children received a 15 minute standardized interview, a diary card and a PF meter but no reminders for follow up. | 12 months after enrollment, Group A patients were less like to report restricted activity (p<0.05) but there were no differences in day or nighttime wheezing or nasal symptoms. There were no differences in several spirometric measures but Group A patients spent less time with lung function less than 30% of personal best (p<0.05). There were no differences in medication use between groups, days lost from school, or number of office visits. ^64^
Colland et al. ^60^ | To evaluate the feasibility of teaching patients and their caregivers to recognize prodromal signs and the adherence to a treatment plan that includes doubling inhaled corticosteroids if prodromal signs occur. | 29 children with moderate asthma in the Netherlands. | RCT | Group A (N=15). Both groups of children received individual information from a pediatrician on asthma symptoms, prevention measures, medication and exacerbations during 2 one-hour sessions. Patients' kept PF, medication, and symptom diaries. They were seen every 2 months for one year. Group B. 14 children received additional information about individual prodromal signs identified by both the patient and caregiver; they were advised to double the daily dose of inhaled corticosteroid for 1 week when these signs occurred. | There were no differences between the groups in terms of number of asthma exacerbations, reported asthma-related disabilities, or child absence from school or parental absence from work at 1-year post intervention. FEV_1_ levels increased in both groups but no difference between the groups. Even in Group B, the recognition of prodromal symptoms was poor. ^60^
Greineder et al. ^197^ | To evaluate the economic effects of an asthma outreach program that included an allergy nurse, allergy nurse practitioner, and allergist. | 57 children (aged 1–15 yrs) with asthma in Boston. | RCT | Group A. 28 patients had a single visit “typically lasting several hours” with an allergy nurse who provided individual asthma education on asthma, triggers, medications, inhaler and PF meter use, environmental control and a written asthma action plan. Group B. 29 patients received the same education as in Group A and then continue to have “regular” follow up by the nurse—mostly over the phone but with in person visits “as needed.” | At the end of the 2 year study period, both groups experienced reductions in ED visits, hospitalizations, and health care costs. Group B patients improved significantly more compared to Group A patients: 57% greater reduction in ED visits (p=0.0002), 75% fewer hospitalizations (p<0.05), and 71% fewer out-of-plan costs (p<0.001). ^197^
Guendelman et al. ^55^ | To compare the effectiveness of an interactive device for children to report asthma symptoms with an asthma symptom diary. | Inner-city children aged 8 to 16 years in Oakland with persistent asthma. | RCT | All children received a standardized teaching session by a nurse during which they received a PF meter and educated on its use, and the appropriate use of asthma medications. Group A. 66 children were randomized to receive the Health Buddy device which they used to answer questions from a nurse about their asthma symptoms and send to the answers to a remote, secure server. Group B. 68 children recorded their symptoms in an asthma diary. | 12 weeks after enrollment, both groups reported a decrease in asthma symptoms and a decrease in PF readings in the yellow or red zone. Group A children were less likely to report activity-limiting symptoms (p=0.03) than diary-based patients. There were no differences between groups in terms of school absenteeism, ED visits, or hospitalizations. ^55^
Krishna et al. ^56^ | To evaluate whether the addition of a multimedia asthma education program to a standard education program improves outcomes for children with asthma. | 246 children aged <18 with asthma in Missouri and their caregivers. | RCT | Group A. 121 children received 1.5 hours of asthma education over 3 visits by a nurse using instructional sheets from the “Caring for Kids With Asthma” series—each of which describes specific aspects of care for asthma such as medication use. Then at each subsequent visit they received 15 minutes of additional individualized training on use of devices and medication and a detailed written self management plan. Group B. 107 children received this printed and verbal teaching and also used the 1h 20min Interactive Multimedia Program for Asthma Control and Tracking (IMPACT) for additional reinforcement of asthma skills and knowledge by taking the subject through 4 clinical vignettes. | 12 months after enrollment, both groups improved their asthma knowledge over baseline but was significantly greater among Group B (p<0.01). Both groups had improvements in asthma symptoms, medication use, sleep disturbance, urgent visits to physicians and the ED over baseline (p<0.05). However, Group B had significantly greater decreases in days with asthma symptoms (81 vs. 51/year) (p<0.01) and number of annual ED visits (1.93 vs. 0.62) (p<0.01) than the control group. There were no differences in between groups in terms of activity limitation, nights of sleep disturbance, urgent visits to the physician, hospitalizations or school absenteeism. ^56^
Lewis et al. ^62^ | To compare the ACT (Asthma Care Training) program with conventional patient education. | Children with severe asthma aged 7–12 yrs in Los Angeles. | RCT | Group A. 28 patients received three 1.5 hour sessions consisting of a lecture with discussion in groups of 12–25 people with demonstrations of relaxation and breathing exercises designed to give the child more responsibility for his/her care. Group B. 48 patients received the ACT program: five 1-hour session at weekly intervals (some taught by school teachers, others by a physician). Children and parents are taught the same content but in separate sessions. A detailed description of this curriculum is presented in ^62^ . | ACT recipients (group B) had significantly fewer ED visits (2.3 vs. 3.7) compared to Group A patients. There were no differences in terms of number of hospitalizations; however, the ACT group tended to have shorter hospital stays (0.67 vs. 1.54 days/child/yr). Parents in both groups rated their child's health as significantly better one year after the program and “trouble with asthma” ratings decreased significantly in Group B. The costs of the program were estimated at $125/ACT recipient and $37.50 per Group A recipient. Given the lower hospital costs in the ACT group, the authors estimate a $180 annual cost savings per child for the sponsoring institution. ^62^
Walders et al. ^59^ | To assess the effects of an interdisciplinary intervention on asthma symptoms and health care utilization. | 175 children aged 4–12 years with asthma in Cleveland. | RCT | Group A. 86 children were evaluated by a pediatric pulmonologist who developed a written asthma treatment plan for each child who also received a spacer, PF meter, and prescription for a 1-month supply of medications. Group B. 89 children received everything that Group A received and also received a 1hr educational session with a nurse or social worker on asthma pathophysiology, triggers, and treatment; an additional individualized problem-solving visit with a psychologist; and access to a nurse telephone hotline. | 12 months after enrollment, there was no difference between groups in terms of number of symptom days or symptom scores, hospitalizations, or QOL (both groups improved over baseline). ^59^
Wensley and Silverman ^63^ | To evaluate the incremental effectiveness of adding routine PF monitoring to symptom-based guided self-management. | 90 children aged 7–14yrs with physician diagnosed asthma in the U.K. | RCT | Group A. 44 children and their caregivers were given training in spirometry and symptom recording in a 30–90 min session. A color-coded plan was provided with instructions for medication adjustment on the basis of both symptoms and PF measurements. Written symptom diary completed daily. Children were visited every 4 weeks for 3 months to update the self management plan. Group B. 46 children and their caregivers received a symptom diary and self-management plan based on symptoms but no PF meters or instructions on their use. | Compliance with written diary data deteriorated over time in both groups from 90% at month 1 to 79% at month 3. There was no difference between groups in daily symptom scores, number of symptom-free days, any lung function parameter (including PF), child or caregiver QOL, hospital or general practitioner visits, emergency prescriptions, or days lost from school. ^63^
Yoos et al. ^65^ | To evaluate the incremental benefit of PF meter use as an adjunction to symptom recognition and self-management of asthma. | 168 patients aged 6–19 years with asthma from 11 primary care settings in the U.S. and their families. At enrollment, N_Group A_=56, N_Group B_=55, N_Group C_=57; however, at 1-year, 32 patients did not complete the final post-exit interview. It is not clear which groups these patients belonged to. | RCT | Patients in all groups received asthma education during a home visit from a nurse regarding asthma pathophysiology, symptom recognition, triggers, medications, and treatment goals and were given written materials with personal action plan for symptom management to reinforce this information. Group A. 56 patents received training in subjective asthma symptom recognition. Group B. 55 patients received subjective asthma symptom recognition and PF meter training with instructions to use PF meter at the time of increased symptoms. Group C. 57 patients received subjective asthma symptom recognition training and PF meter training with instructions to do both routine twice daily PF monitoring and at the time of increases in asthma symptoms. Each group had a practice period of 2 weeks, after which they were followed up. All patients kept asthma diaries. | All outcomes were assessed between groups in terms of change from baseline to final measurement. After 3 months, there were no significant differences among the groups in change in spirometry (FEV_1_% predicted). There was also no significant difference between Groups A and C or Groups B and C in change in symptom-days; however, there was a more significant improvement in Group B compared to Group A in symptom-days (p=0.01). At 12 months, there were no significant differences among the groups in change in asthma severity, hospitalizations, ED visits, and acute illness visits. However, the average reduction in health care charges due to reduced healthcare utilization was $82 per child for Group A children, $162 per child for Group B children, and $61 per child for Group C children. ^65^
General Population or Adult Interventions
Adams et al. ^140^ | To compare symptom vs. PF monitoring for detecting asthma flares. | 134 adults with moderate to severe asthma who are not poor perceivers of broncho-constriction in Australia. | RCT | Group A. 61 patients were given a written, self-management action plan based on symptom monitoring. Group B. 73 patients were given a written, self-management action plan based on PF monitoring. All patients were called monthly for monitoring and reinforcement of the use of the action plans. | There were no differences in ED visits, hospitalizations, or days lost from work or school between the groups at 1 year post-intervention. (Compared with the year prior to the intervention, both groups had significant decreased in all three of these outcomes). There were no differences between groups in FEV_1_. 85% of the symptom and 86% of the PF groups were reported to have appropriate use of action plans. ^140^
Ayres and Campbell ^208^ | To assess the efficacy of an asthma self-management plan based on PF measurements compared to a standard dose regimen. | 125 adults in the U.K. with asthma over the age of 17 with nocturnal symptoms. N_con_=64, N_int_=61. | RCT | Group A. 64 patients in the “doctor-managed regimen” group made 4 visits to the clinic at 6-week intervals as well, and they had their medication adjusted by the investigator based on their diary card data. Group B. 61 patients in the “self-management regimen” received a written personalized self-management plan based on PF monitoring at initial assessment and continued to make 4 visits to the clinic at 6-week intervals to have lung function and asthma severity measured. Patients also completed diary cards twice a day and PF charts. | After 6 months, no significant differences were found between the intervention and control group in sleep disturbance, activity scores, lung function, hospitalizations, or medication usage. ^208^
Baldwin et al. ^209^ | To compare the effectiveness of verbal vs. written instructions for asthma self-management. | 50 adults with asthma in the U.K. | RCT | All patients were instructed in the use of PF meters, asked to record daily PF measurements, given hand-outs on asthma. Patients returned to the asthma clinic for 3 visits, 3 months apart. Group A. 25 patients received verbal instructions on asthma management. Group B. 25 patients received written instructions on asthma management. | Significant differences between the groups at randomization complicates the interpretation of the results (Group A had more severe asthma than Group B). However, both groups showed significant improvements in multiple parameters over the course of the study. ^209^
Bheekie et al. ^200^ | To compare the use of patient-performed PF and symptom monitoring as asthma self-management in a program run by community pharmacists. | 61 patients ≥6 years old with asthma from 5 community pharmacies in South Africa. N_Group A_=21, N_Group B_=40 | RCT | Group A. 21 patients were taught how to score their symptoms and received personalized self-management plans based on symptom monitoring. Group B. 40 patients were taught how to monitor their PF and received personalized self-management plans based on PF readings, which these patients were instructed to monitor twice-daily before the use of bronchodilators. All patients kept diary cards to monitor their asthma. | After 2 months, Group B subjects were significantly more likely than Group A subjects to use their self-management action plans appropriately (p<0.006) and to use medication as indicated in their self-management plan (p<0.05). However, there was no difference between the groups in rates of seeking medical consultation when considered appropriate by the self-management plan. ^200^
Charlton et al. ^126^ | To compare a PF self management plan for asthma with a symptoms only plan. | 115 patients in a U.K. general practice nurse run clinic (46 children and 69 adults) with asthma randomized to PF (N=51) verses symptom only (N=64) group. | RCT | All patients met individually with a nurse for an initial 45 minute interview with a 15 minute session 1 week later for spirometry and a check of inhaler technique. All patients had follow up visits at least every 8 weeks where topics such as smoking, holidays, provoking factors, and emergency treatments were discussed. Group A. 64 patients were given self-management plans based on symptoms. Group B. 51 patients were given self-management plans based on PF readings. One week later, there was a 15 minute follow up. Patients were followed-up thereafter every eight weeks. | After 12 months, there were no observed significant differences between the PF and symptom only group with regards to symptoms, medication usage or the need to consult a physician for asthma. When stratified by adult verses children, again no significant difference between interventions was observed. ^126^
Côté et al. ^201^ – ^203^ | To compare the effectiveness of asthma education with an action plan based on symptom monitoring with an action plan based on PF monitoring. | 149 adults with moderate to severe asthma in Québec. | RCT | Group A. 54 patients received only instructions from their “respirologist” regarding medication use, asthma triggers, and use of asthma symptom diary. Group B. 45 patients received the Group A intervention plus 1 hour individual counseling with a “specialized educator.” They were asked to record their asthma symptom score daily and adjust medications according to a symptom-based action plan. Group C. 50 patients received the Group A intervention plus 1 hour individual counseling with a “specialized educator.” They were asked to measure their PFs twice daily and adjust medications according to a PF-based action plan. | At 12 months, when comparing the action plan patients (Group B and Group C) with “control” patients (Group A), action plan patients' asthma symptoms scores decreased (p=0.006) and the number of days per month without daily asthma symptoms increased (p=0.03). ^201^ QOL scores improved for all groups but were significantly more improved among action plan patients than controls. ^201,^ ^202^ Action plan patients were significantly more likely to take measures to reduce household dust mites than the control group (p<0.001), but no more likely to reduce exposure to domestic animals. ^201^ The use of an action plan and PF values were significantly higher in Group C compared to Group B (p=0.01 and p=0.03, respectively). ^202^ No significant differences were found among groups in compliance with treatment, ^201,^ ^202^ hospitalizations, ED visits, courses of oral prednisone or days lost from work or school. ^203^ All groups had significant improvements in airway responsiveness after the study. ^201^
Cowie et al. ^127^ | To evaluate the effects of a symptom-based versus a PF-based action plan in preventing acute exacerbations in subjects with poorly controlled asthma. | 139 adult and adolescent patients who had attended an ED or clinic in Calgary for urgent treatment of asthma in the previous 12 months. | RCT | Patients in all groups received a 30 to 60 minute baseline interview, spirometry assessment, and an individual education session provided by a nurse covering asthma, asthma triggers, medication, and inhalation devices. Inhaler technique was checked and corrected if necessary. Group A. 48 patients received no further intervention (no action plan group). Group B. 45 patients were given written four-step action plans detailing different response actions based on symptom-monitoring. Group C. 46 patients were given written four-step action plans based on PF readings. Patients in Groups A and B also received prescriptions for prednisone for use in the third step of the self-management plan. | After six months, there were significantly fewer ED visits in Group C compared to Groups A and B (p=0.002). There were no significant differences among the groups in terms of hospitalizations, β-agonist utilization, self-rating of asthma severity, night waking with asthma, daily dose of inhaled corticosteroid, or number of courses of prednisone taken. ^127^
Drummond et al., ^210^ ^211^ Osman et al., ^212^ and Buckingham et al. ^213^ | To evaluate a personalized computer supported education program for asthma patients (Group 1A/B). To evaluate the use of a PF meter based self-management intervention. | 801 adults with asthma in Scotland. | RCT with 3×3×3 design | Group 1A. 349 patients received “conventional oral education at outpatient visits.” Group 1B. 363 patients took part in an enhanced education program (4 personalized booklets, sent by mail). Group 2A. 251 patients received no self-management advice. Group 2B. 254 received a PF meter, shown how to use it, and individually tailored self-management guidelines to follow when they identified changes in PF. | 12 months after the intervention, there were no difference between groups in any clinical outcomes including days of restricted activity, sleep disturbance, prescription of bronchodilators or inhaled steroids, use of oral steroids, or number of general practitioner consultations for asthma. ^210^ – ^212^ Total cost of integrated care for asthma was estimated to be £40.11/patient/annum compared to £62.12/patient/annum for conventional care. ^213^
Ignacio-Garcia and Gonzales-Santos ^204^ | To determine the usefulness of an objective measure of lung function in association with an educational program and a medication self-management plan in reducing morbidity in adult patients with asthma. | 70 patients with asthma ages 14–65 from an outpatient asthma clinic in Spain. N_con_=35, N_int_=35. | RCT | During an initial assessment, all patients were given individualized therapeutic schedules and taught proper inhaler technique and how to use a PF meter they were given. Group A. 35 patients used symptoms only and spirometric data for following physicians' treatment plans. Group B. 35 patients monitored themselves using PF readings, which were the basis for their therapeutic plan. This was coupled with educational intervention—a 30-min session regarding the role of asthma medication and symptom management. All patients were followed up at 3, 5, and 6 months where their inhaler technique, compliance with PF measurement, and diary cards were checked and spirometry was performed. | After 6 months, significant improvements in the intervention group compared to the control group were found in days lost from work (p<0.008), acute asthma exacerbations (p<0.05), ED visits (p<0.05), physician consultations (p<0.001), and nocturnal wakening (p<0.001). Significant improvements were also found in mean PF (p<0.002), FVC_1_ (p<0.004) and the use of inhaled fenterol and prednisone in asthma exacerbation (p<0.008). An observed decrease in the number of hospital admissions for asthma with the intervention did not reach statistical significance. ^204^
Janson-Bjerklie and Shnell ^198^ | To identify self-care strategies used to control asthma symptoms and to determine the effect of PF information on selection of self-care strategies. | 28 adult patients with asthma in the U.S. N_A_=15, N_B_=13. | RCT | All patients participated in an interview during which they gave information about their asthma history, frequency of symptoms, and strategies to control their asthma. All patients were then instructed on how to use and Asthma Care Log to record information about their symptom episodes. Group B. 13 patients were told to also record PF 3 times at the beginning and end of each episode, and told high numbers meant good flow and open airways. | After 3 months, there was no difference between the groups in symptom scores or in compliance with medication. However, patients in the intervention group used bronchodilators significantly less than patients in the control group (p<0.05). ^198^
Jones et al. ^214^ | To compare asthma self-management program using home-based PF measurement with a program of planned clinic visits for asthma management. | 90 practices with patients aged 15–40 years with asthma requiring daily inhaled corticosteroids in the U.K. were invited to participate. | RCT | All patients had 5 visits over 6 months and were taught to use symptom diaries. Group A. 33 patients assigned to the self management group received a PF meter, instructed in its use, and given written instructions for how to change their medication regimen in response to PF measurements. Group B. 39 patients assigned to the planned visit group had their medications changed by providers in clinic on the basis of their symptom diaries. | No difference between the groups in FEV_1_, FVC, or PF; days lows from work or school, outpatient visits, hospitalizations, nighttime awakening, or QOL at 6 months after the intervention. Compared to baseline, Group A reported significant decreases in asthma interference with daily life and improved QOL. Group B had significant improvements in PF rates, FEV and FCV between visits 1 and 2, but the differences between visits 1 and 5 were not significant. ^214^
Kauppinen et al. ^215^ – ^217^ | To evaluate the effects of an intensive self-management education program on adults with asthma. | 134 newly diagnosed adults with asthma in Finland. | RCT | Group A. 70 patients received training in use of inhaled medications and PF meters (which they were issued), they received verbal information and were shown a video (two visits). Group B. 64 patients also received every three months for a year additional training with “repetition of self-management instructions, principles of asthma treatment and use of drugs.” Additionally, they received two 2-hr educational visits at 6 and 9 months by a nurse and physiotherapist on “social affairs” and “rehabilitation.” | There was no significant difference between the groups at 5 years for lung function, bronchial hyper-responsiveness, days lost from work, QOL, or total costs attributed to asthma care. ^217^
Kemple and Rogers ^218^ | To evaluate postal prompts to increase patients' understanding and use of self-management plans. | 545 patients with asthma over age 16 in the U.K. N_GroupA_=197, N_GroupB_=187, N_GroupC_=161. | RCT | Group A. 197 patients were mailed an invitation to have a medical review of their asthma symptoms, treatments, and asthma action plans. Group B. 187 patients were mailed a similar invitation for medical review with a blank asthma self-management plan. Group C. 161 received the invitation for the medical review with a partially-completed personalized action plan to be completed at the time of the review with their health care practitioner. | Overall, there was a low response rate: 38% of Group A, 45% of Group B, and 51% of Group C patients attended the medical review. 12 months after the intervention, there were no significant differences among the in symptom scores, ED visits, or hospitalizations. ^218^
López-Viña and del Castillo-Arévalo ^128^ | To compare self-management education program alone to one that includes PF monitoring. | 100 adults with asthma in Spain. | RCT | Group A. 44 patients received personalized self-management plan with nurse provided education on asthma management and medication information. Group B. 56 patients received this same education and they also received and color-coded self management and diary cards to record symptoms, medications, and PFs. For all patients, follow up visits were scheduled at 15 and 30 days after enrollment and every 3 months thereafter until 1 year after enrollment. | At 12 months, Group B subjects were more adherent to their treatment plans (83% vs. 52%, p=0.05) and had higher mean FVC (99 vs. 94, p 0.03) than Group A subjects. However, there were no differences between groups in days with symptoms, reported asthma exacerbations, school/work absenteeism, visits to the ED or hospital admissions, correct use of inhalers, or FEV_1_ although many of these parameters improved from baseline in both groups. ^128^
Malo et al. ^219^ | To compare symptom vs. PF monitoring for detecting asthma flares. | 60 adults with moderate to severe asthma in Canada. | RCT with Cross-over of arms | Group A. Recorded PFs twice a day for six months first then recorded symptoms twice a day for six months. 40 subjects finished the first six month, 20 finished both. Group B. Recorded symptoms twice a day for six months first then recorded PFs twice a day for six months. 40 subjects finished the first six month, 20 finished both. | 19 (61%) of the total 31 asthma exacerbations were reported while patients were using symptom diaries and 12 (39%) were reported while patients were using PF meters. ^219^
McLean et al. ^205^ | To evaluate the effects of two levels of asthma care by pharmacists on clinical, economic, and QOL outcomes. | 20 pharmacists caring for patients with poorly controlled asthma in British Columbia. | Quasi-RCT | Group A. Patients were taught inhaler technique, completed monthly asthma diaries of PFs, symptoms, medication use, ED visits, and days off from work/school. Patients encouraged to come once a month for new diaries or at least quarterly. Group B. Patients received everything that Group A received plus intensive asthma education and instruction on the use of PF meters and spacer devices. They received private 1hr counseling sessions every 2–3wks for at least 3 wks, then every 3 months for at least 9 months. | Both groups experienced significant improvements over baseline. The intensive education group reported significantly greater improvement than the other patients at 1 year: 11% improvement in PFs (p=0.0002), 50% overall decrease in asthma symptoms (p<0.01 for most symptoms evaluated), higher QOL (p<0.05) and decrease in medical visits (but not ED visits or hospital visits). ^205^
Neri et al. ^220,^ ^221^ | To evaluate the effects of patient education on pulmonary function and inhaler technique among adults with asthma. | 35 adults with asthma in Italy. | RCT | Group A. 17 patients received a medical exam every two months for 1 year. Group B. 18 patients also received six 1-hour lessons “based on the content of an educational booklet on asthma.” | At 1 year, there was no difference between the groups in terms of number of asthma attacks, number of work days lost, or hospital admissions. ^221^ There were no differences between the two groups at 1 or 3 years for FEV_1_, asthma knowledge, or number of correct steps during inhaler use evaluation. ^220^ The program cost per patient was $713 for Group B and $670 for Group A. ^221^ Compared to baseline, there were significant improvements in FEV, knowledge and inhaler technique in both groups. ^220^
Ostojic et al. ^206^ | To assess the feasibility and reliability of GSM SMS as a tool of asthma monitoring and to ascertain its effects on control of asthma. | 16 patients with moderate persistent asthma from a single clinic in Croatia N_con_=8, N_int_=8. | RCT | All patients had a 1-hour asthma self-management education session with a specialist at the clinic and were given a self-management plan and a PF monitor. Patients noted PF measurements, medication use and symptoms in a diary. Group A. 8 patients were seen in the office at the end of the study to review their asthma diaries. Group B. 8 patients sent their PF results daily to physicians via a short-message service (SMS) that used Asthma Center 0.90 Software to compute maximal, minimal, and mean PF, PF variability, and compliance. They then received weekly instructions by SMS from an asthma specialist on therapy adjustments and recommended follow up. | After 4 months, no significant differences between the intervention and the control groups were found in mean PF, FEV_1_, compliance with PF measurement, daily use of inhaled steroids or β-agonists, wheezing, or limitation of activity. However, when compared to the control group, the intervention group had significantly less coughing (p<0.05) and night symptoms (p<0.05). The additional cost of SMS per patient, per week was 1.67€ ($1.3 per 1 Euro). ^206^
Schonlau et al. ^199^ | To examine whether a collaborative to improve asthma care influenced processes and outcomes of care for adults with asthma. | 6 healthcare organizations from across the U.S. and Puerto Rico sent teams of 3–4 participants for collaborative learning. | CBA | The intervention group (6 sites, 123 patients) sent 3–4 person teams to 3 2-day learning sessions to promote changes in asthma care based on best practices and continuous quality improvement (the curriculum was not described in detail). 2 of 3 control sites (62 patients) had active quality improvement programs for asthma (also not described in any detail). | At 12 months after the intervention, patients in the intervention group were more likely than controls to attend educations sessions (p=0.03). However, there were no differences between groups in terms of having a written asthma action plan, goal setting, PF monitoring, use of controller medications, QOL, or asthma knowledge. ^199^
Thapar ^222^ | To compare individual vs. group asthma education sessions. | 69 adults with asthma in Wales. | RCT | Group A. 34 patients received 20 minute individualized asthma education by a physician with a 5–10 minute follow up session at 3–4months. Group B. 34 patients received a 35 minute group asthma education program by the same physician (4–6 patients per group) with a 10–15 minute follow up session at 3–4 months. | At 4–5 months after the initial educational session, there was no difference in asthma knowledge or self-rated “wheeziness scores” between groups. Knowledge increased significantly in both groups compared to baseline. ^222^
Thomas et al. ^129^ | To compare patient education by an asthma nurse with breathing retraining by a physiotherapist. | 33 adults with asthma in the U.K. | RCT | Group A. 16 adults were given a 60 minute group education session by an asthma nurse on asthma. Group B. 17 adults were trained by a physiotherapist in a small group session for 45 minutes followed by 15 minute individual sessions 1 and 2 weeks later (total time 75 minutes) in proper breathing techniques. | There was no difference in asthma medication use between the two groups at 6 months after the intervention. There was a slight improvement in one domain of QOL in the breathing retraining group compared to the nurse educator group (p<0.05). ^129^
Turner et al. ^130^ | To compare the effectiveness of action plans using either PF monitoring or symptoms to guide self-management. | 92 patients with moderate to severe asthma using inhaled corticosteroids from a primary care clinic in Vancouver N_Group A_=48,N_Group B_=44. | RCT | All patients were given individualized asthma education by a registered nurse, and self-management plans were reviewed in detail. The initial visit consisted of thirty minutes of asthma education and discussion, and follow up visits were scheduled monthly for six months. Patients also kept daily diary cards. Group A. 48 patients' self-management plans were based on symptoms Group B. 44 patients' self-management plans were based on PF. Therefore, patients with self-management plans based on PF were also instructed in the use of a PF meter. | After 6 months, no significant differences were found between the groups in FEV_1_, PF, QOL, symptom scores, the use of β-agonists or inhaled steroids, number of days missed for work/school, ED visits, or hospitalization rates. ^130^
Van der Palen et al. ^131^ and Klein et al. ^132^ | To assess whether including an action plan in a self-management education program improves asthma outcomes. | 245 adults with stable moderate-severe asthma in the Netherlands. | RCT | Group A. 122 patients received self-management training and education by an asthma nurse in three 90-min small group sessions. Content included asthma pathophysiology, medication use and side-effects, asthma triggers, symptom identification, PF meter and inhaler technique. Group B. 123 patients also received instructions on how to use an action plan to treat exacerbations. | At 1 year, there were no differences between the groups in adherence to medication or the use of action plans. ^131^ At 2 years, there were no differences between groups in any outcomes including PF, frequency of exacerbations, symptom-free days or nights, outpatient visits, or hospitalizations. ^132^ Both groups improved in their inhaler technique (p=0.041), knowledge, ^131^ and QOL. ^132^
Yoon et al. ^207^ | To evaluate the effectiveness of a brief (3hour) patient education program to decrease readmission rates. | 76 Australian adults recently discharged after an admission for a severe asthma exacerbation. | RCT | All patients received a PF meter and were shown how to use it and record values from it. Group B. 28 intervention subjects also received a single 3hr educational session that emphasized improved inhaler and PF monitor use and self adjustment of the dosage of phrophylactic meds according to a PFs and a treatment plan. Included interactive lecture, videotape, individual training, and a practice session. | 10 months after the intervention 1 of 28 intervention patients and 7 of 28 “control” patients were readmitted for asthma (p<0.001). 3 intervention and 7 control patients had ED visits for asthma (p<0.01). No difference in missed work or school between groups, use of inhaled steroids, or reported symptoms. ^207^

Note: ED=emergency department; PF=peak flow; QOL=quality of life; CBA=controlled before-after trial.

The studies of pediatric self-monitoring or self-management interventions are notable among all the types of studies synthesized for this report, in two ways. First, many of these studies reported statistically significant improvements in subjects receiving the intervention—specifically, 29 (83%) of the pediatric self-monitoring or self-management studies reported at least one statistically significant outcome for the recipients of the self-monitoring or self-management intervention compared with the control group. We explore the intervention factors associated with improvements in outcomes and processes of care for children with asthma at the end of this section (Table 13 through Table 16).

Table 13 Association of pediatric self-monitoring, self-management, or patient education intervention characteristics and significant clinical outcomes

Predictor variables | Regression Coefficients (SE) | P value
Intervention duration in months (continuous variable) | 0.03 (0.08) | 0.7
Interventions that targeted parents or caregivers vs. children | -2.70 (1.16) | 0.02
Studies that specified a theoretical/conceptual framework vs. those that did not | -0.06 (0.76) | 0.9
Year of publication (continuous variable) | -0.05 (0.06) | 0.4
Number of educational meetings with the subjects (continuous variable) | -0.28 (0.62) | 0.7
Model Constant | 99.68 (114.42) | 0.4

2 Model details: Method: Logistic regression. Dependent variable: Any statistically significant clinical outcome. R=0.3. The predictor variables that were entered as continuous variables are so noted in the table. The 38 studies of self-monitoring, self-management, or patient education interventions reporting data for each of the variables in this regression were included in this analysis. This analysis was not weighted by sample size.

Table 16 Association of pediatric self-monitoring, self-management, or patient education intervention characteristics and reductions in asthma-related hospitalizations

Predictor Variables | Regression Coefficients (SE) | P value
Model Constant | 4.0 (2.13) | 0.1
Intervention duration in months (continuous variable) | 0.0004 (0.08) | 0.9
Country of intervention (categorical variable) | 0.67 (0.47) | 0.2
Studies that specified a theoretical/conceptual framework vs. those that did not | 0.79 (1.10) | 0.5
Number of educational meetings with the students (continuous variable) | -2.05 (0.63) | 0.01
Setting in which the intervention took place (categorical variable) | -0.31 (0.26) | 0.3

2 Model details: Weighted least squares regression (weighted by the sample size). Dependent variable: standardized mean difference effect size for monthly hospital days. R=0.64. 13 studies were included in this analysis (because they reported data for each of the variables included in this regression

Second, among the included studies, the reports of self-monitoring or self-management interventions were most likely to have described their efforts to design interventions that were well-grounded in theoretical frameworks such as social learning theory, cognitive development, and behavior change. Twenty-two (63%) of the included pediatric self-monitoring or self-management studies described such a theoretical rationale for either the content of the program or the selection of teaching methods employed. ^52^ – ^54,^ ^61,^ ^64,^ ^66^ – ^81^ Typically, these interventions relied less on lecture-based or pamphlet-based teaching methods and utilized multiple educational modalities including role-playing, videotapes, and games to reinforce patient learning.

The 35 interventions were heterogeneous with respect to the specific content and delivery methods of the self-monitoring or self-management program. However, two programs, Open Airways and “Superstuff” are worthy of specific mention because they were the subject of multiple evaluations. Five studies evaluated a school-based self-monitoring or self-management program utilizing multiple educational components called Open Airways. ^68^ – ^70,^ ^72,^ ^82^ This program consists of six 40–60 minute group sessions for inner-city third to fifth graders to increase their ability to care for their asthma on a daily basis. It includes information about asthma pathophysiology, recognizing and responding to asthma symptoms, using asthma medications and deciding about when to seek care, staying active, identifying and controlling asthma triggers, and managing asthma-related school problems. Interactive teaching methods used in Open Airways include group discussions, storytelling, games, and role-playing. Each of these studies found important clinical improvements in asthma outcomes for the participants of this self-monitoring or self-management program (Table 11). The study by Ronchetti and colleagues of children receiving asthma care in 12 Italian centers compared the outcomes of three groups: subjects receiving Open Airways, subjects receiving another self-monitoring or self-management program called Living with Asthma, and control subjects receiving usual care. ^72^ The content of the Living with Asthma program is similar to Open Airways and it also uses a group format; however, it makes more extensive use of written diaries for developing asthma management skills and does not rely as heavily as Open Airways on encouraging group members to share problems and develop solutions together. One year after enrollment, patients in the Open Airways but not the Living With Asthma groups had fewer emergency treatments for asthma than controls (p<0.03). ^72^

Three studies reported evaluations of self-monitoring or self-management programs that utilized the “Superstuff” pediatric self-monitoring or self-management kits produced by the American Lung Association (or materials developed from “Superstuff”). ^66,^ ^83,^ ^84^ “Superstuff” kits include a Parent's Magazine containing 29 articles on asthma pathophysiology, triggers, relaxation techniques, and personal control and decision making. The Children's Kit includes riddles about asthma facts, the “Breathe Easy” board game, puzzles and dolls with self-care messages, a comic strip about relaxation exercises, a mystery house for games about discovering allergens, a phone book with advice about when to call the doctor and to record emergency numbers, and assorted asthma-related door signs, posters, stickers, records, and paper cut-outs. In the study by Rakos and colleagues, 20 children with moderate to severe asthma received the “Superstuff” kit in the mail with instructions on its self-administration while 23 children received usual care. ^83^ One year after receiving the intervention, parental reports suggested a statistically significant decrease in “interruptions due to asthma” (p<0.04) but there was no difference in school absenteeism between groups. The study by Whitman and colleagues ^84^ provided the “Superstuff” kit in addition to eight teaching sessions to 19 children and found that three months after the intervention, there was no difference in number of asthma episodes or days without asthma between recipients and controls (N=19); however, participant's knowledge (p=0.02) and asthma skills (p<0.01) improved compared to controls. Also, the intervention evaluated by Pérez and colleagues for Venezuelan children with asthma was based on a self-monitoring or self-management packaged adapted from Superstuff and Living with Asthma—they found that intervention subjects reported fewer asthma crises and their physicians reported less severe asthma than among control subjects (Table 11). ^66^

Of the other studies, numerous reported statistically significantly greater improvements in outcomes for the intervention group over the control group. However, often these statistically significant findings (e.g., improvement in percent predicted FEV_1_ of less than five percent) are of only modest clinical significance.

Conclusions. The 35 self-monitoring or self-management interventions, although heterogeneous in terms of content delivered and method of instruction, tended to be associated with statistically significant improvements in outcomes for children with asthma. Additionally, they tended to be grounded in established theoretical or behavioral frameworks. The interventions with well-established theoretic foundations typically utilized multiple educational modalities including role-playing, videos, and games to reinforce patient learning. Overall, many of the reported improvements were of only modest clinical significance.

#### Patient Education Interventions for Children With Asthma

Background. In general, pediatric patient education strategies for asthma are based on imparting knowledge about asthma pathophysiology to patients and their parents or caregivers and encouraging the appropriate use of peak flow meters and inhaled medications.

Results. We found 54 evaluations of interventions designed primarily to educate children or parents or caregivers of children with asthma (Table 12). The included studies were highly heterogeneous with respect to the target of the intervention (e.g., patients versus their parents or caregivers), the setting of the intervention (e.g., home, school, clinic), and the information being provided (e.g., asthma pathophysiology, allergen reduction). Thirty-seven (69%) studies demonstrated at least one statistically significant improvement in clinical outcomes, functional status, health services utilization, or guideline adherence. The studies reporting decreases in health services utilization tended to have described a theoretical basis for their intervention (p=0.048). Half of the pediatric patient education interventions (N=27) were based on a conceptual or theoretical framework (compared to 63% of the self-monitoring or self-management interventions).

Table 12a Summary of patient education interventions directed at the parents or caregivers of children with asthma

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Brook et al. ^93^ | To compare the parents' knowledge about asthma after an educational seminar and to compare rates of hospitalization of children with asthma whose parents had participated in the seminar with those of children in the control group. | Parents of 54 children with asthma treated in the pediatric respiratory service of Wolfson Hospital in Tel Hashomer, Israel. N_int_=26, N_con_=28. | RCT | Intervention parents were invited to participate in an educational project, which included 1-hour weekly meetings over a four-month period where they received lectures and explanations about various aspects of asthma. Lectures were given by pediatric respiratory therapists, allergists, psychiatrists, social workers, and physiotherapists. Additionally, parents received written information about the chronic disease. | During 12 months after the intervention, intervention children had fewer hospitalizations (a decline from 3.6 to 1.3 hospitalizations per year per child than control children (3.6 to 3.1, p<0.05). ^93^
Brown et al. ^90^ ^§^ | To evaluate whether home-based asthma education of low-income parents and their pre-school children with asthma would be feasible and result in reductions in asthma morbidity, caregiver QOL, and asthma management behaviors. | 95 low income children with asthma between 1 and 6.99 years of age in the metropolitan areas of Atlanta, GA and Palo Alto, CA. N_int_=49, N_con_=46. | RCT | The Wee Wheezers at Home program (was an adaptation of the Wee Wheezers program ^94^ ) included eight 90-minute sessions at weekly intervals in families' homes. Families also received printed materials and homework at each session and videotapes at some sessions. | At 12 months after the intervention, the education group experiences fewer asthma symptoms, more symptom-free days, and better caregiver QOL among those children aged 1–3 but not those children aged 4–6. There was no difference between treatment and control groups for caregiver asthma management behavior or acute care utilization. ^90^
Butz et al. ^95^ | To evaluate the effectiveness of a parent and child asthma education program for rural families in Maryland. | 201 children aged 6–12 years with asthma. N_int_=112, N_con_=89. | RCT | The intervention parents received a 1hr education session on asthma management, use of asthma action plan, and early warning signs; a quarterly newsletter, and a resources guide to asthma management that included locations for allergy testing and information about tobacco cessation. The intervention children received two 2-hr interactive sessions on asthma symptoms, use of PF meters and inhalers; a PF meter; a spacer; and a copy of the “My Asthma Coloring Book.” Control group received usual care. | 10 months after enrollment, the intervention group parents reported less shortness of breath (p=0.007) and nighttime wheezing (p=0.02). There were no differences in the number of parents with an asthma action plan, number of ED visits, hospitalizations, or office visits or caregiver or child QOL. ^95^
Clark et al. ^96,^ ^97^ | To determine whether health education would increase the ability of parents and children to manage asthma and reduce the use of health services. | 290 families of 310 children aged 4–17 years with asthma recruited from clinics serving low income families in New York City. | RCT | 207 control group children received regular care. 103 experimental group children received regular care plus six 1-hour small group sessions offered monthly on managing asthma attacks, taking medication, communicating with physicians, improving school performance, maintaining a healthy home environment, and establishing guidelines for the child's physical activities. 5 sessions were taught separately for parents and children, 1 was jointly attended. | 1 year after the intervention, there was no statistically significant difference in hospitalizations or ED use between groups. However, among those children with one or more pre-intervention hospitalizations, there were significant reductions in ED visits in the experimental group compared to the control (p=0.04). Intervention parents and their children had greater adherence to self-management plans than control children (p<0.05). The cost of delivering the program exceeded the healthcare savings realized (for every $1 spent, $0.62 were saved). However, the program saved $11.22 for ever $1 spent for children with 1 or more pre-intervention hospitalizations. ^96,^ ^97^
Eggleston et al. ^98^ | To conduct and evaluate a home-based environmental intervention for inner city children in Baltimore (based on the findings of the National Cooperative Inner-City Asthma Study). | 100 children with asthma aged 6–12 years with asthma. N_int_=50, N_con_=50. | RCT | Intervention families received comprehensive home-based evaluations of environmental triggers and were given air filters, pillow covers, and cockroach extermination as needed. Additionally, they received 3 home visits and a telephone follow up to review allergen reduction principals. | 1 year after the intervention, the intervention children had fewer daytime asthma symptoms (p=0.02) but there were no difference in nighttime symptoms, exercise-related symptoms, exercise-limiting symptoms, acute visits for asthma, FEV_1_, or QOL scores. 69% of home contained at least one smoker. After the intervention, 2 parents stopped smoking (did not report group assignment of these parents). ^98^
Horner ^99^ | To evaluate the effects of a school-based education program for children combined with a home-based program for their parents on children with asthma. | 44 families of children with asthma aged 8–12 years in the U.S. participated (not clear how many in the intervention group and the control group). | RCT | Children in the intervention group participated in nine 15-minute sessions covering asthma physiology and symptoms, asthma triggers, management decisions using stories, games, posters, and PF meters. Parents received a booklet on asthma pathophysiology, triggers, medication management, use of inhalers and PF meters. | 12 months after the intervention, there was no difference in school absenteeism home management by parents or self management by children between intervention and control groups. ^99^
Hung et al. ^100^ | To determine the effects of nursing instruction on the mother's knowledge of asthma medications, inhaler use technique, and her child's health status. | 82 children aged 5 to 12 years old with asthma attending the pediatric allergy clinic of a medical center in Taipei. N_int_=41, N_con_=41. | QRCT* | The intervention group received a one time individual asthma educational session by a nurse specialist during which they were taught about the objectives of medical treatment, side effects, inhaler use, and the assessment of symptom severity. | Two months after the education, intervention mothers were significantly more likely to have improvements in inhaler technique (p<0.05) and their children were less likely to report respiratory symptoms (p<0.05). ^100^
LaRoche et al. ^78^ | To evaluate the efficacy of a multifamily asthma group self management program designed to be culturally relevant and encouraged group cohesiveness among the attending families. | 24 African American and Hispanic families living in Boston with children aged 7–13 with asthma. | RCT | The 24 experimental families were randomized to receive three 1-hour sessions that emphasized collaborative asthma management among patients, parents, and physicians and provided training on asthma symptoms and skills for self management. Half of the experimental families received encouragement to work as a group to share experiences and learn from each other. The 11 control families received no intervention. | During the year after the intervention, the experimental children from families that shared group experiences had the fewer ED visits (0.7±0.9) than either the experimental children with standard self-management teaching (1.2±1.7) or controls (1.4±2.4) (p=0.04). There were no differences in self-management scores. The intervention program cost approximately $2,295 per 11 patients and the savings from reduced ED visits was $4,675 per 11 patients. ^78^
Liu and Feekery ^27^ | To evaluate whether attendance at an asthma education clinic would enhance parents' understanding of asthma, lead to reductions in their children's asthma severity and to evaluate whether the effectiveness of the intervention is related to its delivery. | 158 families of attending the Asthma Education Clinic and Royal Children's Hospital in Melbourne, Australia. The control group was recruited from a nearby hospital without an education clinic. | RCT | 3 different types of educational sessions with a pediatrician were studied: an individual session with a prior needs assessment; an individual session without prior needs assessment; and a small group session (with 4 or 5 families). | 12 months after the intervention, there was a reduction in asthma severity and morbidity scores among the children of parents in the individualized groups. ^27^
Maslennikova et al. ^82^ | To assess the effects of a adapting a U.S. self-management educational intervention on asthma outcomes for children in Moscow. | 122 children with asthma and their families living in Moscow. N_int_=60; N_con_=62 | RCT | The authors adapted “Open Airways” (developed for low literacy children aged 4–7 years) and “Air Power” (developed for average literacy children aged 8–14 years) for similar populations in Moscow. Intervention subjects also received asthma care from clinicians who had been trained “according to the U.S. guidelines for the diagnosis and management of asthma and use of modern asthma medications.” Intervention subjects participated in 4 weekly 1hr sessions. Control subjects received usual care from clinicians who received no additional training. | 1 year after the intervention, the % of children in the education group who were on inhaled anti-inflammatory medications increased by 46% compared to only 8% for the control group (p<0.05). Intervention children's PF measures also improved more than for control children (p<0.05). There was no difference in terms of the change in the percentage of children using theophylline or β-agonists or days missed from school.
Mesters et al. ^101,^ ^102^ | To evaluate the effects of a caregiver education program for young children in the Netherlands. | 63 general practitioners (GPs) were randomized to provide an educational manual to the caregivers of children aged 0 to 4 with asthma. N_int_=31, N_con_=32. | RCT | GPs were given a notebook containing 16 modules of information on topics related to asthma pathophysiology, medication use, symptom recognition, and trigger identification and reduction. GPs distributed some or all of the modules to the caregivers of patients with asthma. Caregivers differed in terms of the number of modules received and the number of follow up visits with the provider. | At 12 months after the intervention, the treatment group of patients had fewer emergency and non-emergency visits with the GP than control patients (p=0.01 for both). No difference in hospital admissions between the groups. ^101,^ ^102^
Morgan et al., ^73^ Evans et al., ^74^ , and Sullivan et al. ^75^ | To evaluate whether a home-based intervention for inner-city children designed to teach caregivers to reduce environmental asthma triggers specific to that child (as determined through skin testing) would result in improvements in asthma-related outcomes. (The National Cooperative Inner-City Asthma Study.) | 1023 families of children aged 5 to 11 with asthma in 8 major U.S. cities N_int_=515, N_con_=518. | RCT | During the 12 month intervention, 2 research assistants visited each home 5 to 7 times. Each visit was followed by a phone call to address any barriers to implement the plan. Caregivers were taught about the role of allergens in asthma, mattress covers were installed, families were given a vacuum cleaner with HEPA filter and a HEPA air purifier was set up in the child's bedroom. Professional pest control was provided. | Two years after enrollment, intervention children had more symptom free days (565.1 vs. 538.5), fewer asthma symptoms (p<0.001), days lost from school (p<0.009), and allergen levels. ^73^ There was no difference in spirometry or PF measurements or unscheduled visits to the ED, clinic or hospital between the two groups. ^73^ – ^75^ The cost of the intervention was $337 per child for 2 years resulting in an estimate incremental cost-effectiveness ration of $9.20 per symptom-free day gained (95% CI: -$12.56 to $55.29 per symptom free day gained). ^75^
Pérez et al. ^66^ | To evaluate the effectiveness of a self-management program based on social learning models and self management programs with demonstrated effectiveness on asthma morbidity. | 29 children with asthma aged 6–14 years in Venezuela. | RCT | 17 children and their parents were randomized to receive asthma education. Parents received two 90 minute sessions on asthma pathophysiology, treatment and psychological factors associated with the disease. Children received six 60-minute self-management training sessions that included modeling, positive reinforcement, group dynamics, behavioral practice, role-playing, and feedback. | 6 months after the intervention, children reported fewer asthma crises, and their physicians reported less severe asthma than control patients (p<0.05). ^66^
Stevens et al. ^103^ | To examine the effects of providing an asthma education and written self-management plan to the parents of pre-school children on asthma morbidity. | 177 children aged 18 months to 5 years at the time of admission to the hospital or attendance at the ED for asthma in the U.K. N_int_=87, N_con_=90. | RCT | The parents and children in the intervention group received a general education booklet about asthma, a written guided self-management plan, and two 2-hour educational sessions given on a one-to-one basis by a specialist nurse in the outpatient clinic. The education sessions focused on personalization of the self-management plan, parental techniques for administering medication, and asthma triggers and symptoms. Children in the control group received usual care. | After 12 months, there was no significant difference between the groups in hospital admissions, ED visits, number of prescriptions for asthma medications, symptoms scores, or parental/caregiver QOL. ^103^
Tieffenberg et al. ^67^ | To evaluate a chronic disease self management program based on behavioral change and learning theory directed at increasing autonomy on the part of children. | 188 children with moderate to severe asthma aged 6 to 15 in Argentina. | RCT | 65 families were randomized to receive 5 weekly 2-hour meetings with a reinforcement meeting 2–6 months later. The curriculum included identifying early warning signs and symptoms of an attack, identifying triggers, understanding therapies, and decision making skills through games, drawings, stories, videos, and role-playing. 52 children received usual care. | 12 months after the intervention, experimental subjects had fewer regular visits for asthma (p=0.048), asthma crises (p=0.36), and less school absenteeism (p=0.006 for fall/winter and p=0.029 for spring semesters) but no difference in emergency visits compared to controls. ^67^
Toelle et al. ^88^ | To evaluate whether a community-based asthma management program could reduce asthma symptoms and lung function among school children in Sydney, Australia. | 132 school children aged 8 to 11 with asthma and all the adults who influence their care including parents, doctors, pharmacists, community nurses and school teachers. N_int_=72; N_con_=60. | CBA | Parents and children in the intervention group were invited to attend two 2-hr educational session, 1 week apart on asthma triggers, medication use, inhalation technique, and use of written self-management plan. These children's physicians and pharmacists were invited to attend evening workshops which reviewed asthma management guidelines. Community nurses and school teachers in the intervention community received an in-service education session. All families, children, physicians, and pharmacists who did not attend the intervention sessions were mailed the materials. | 147 teachers and community nurses, 53 families (74%), 15 pharmacists (21%), and 11 physicians (20%) attended intervention sessions. 6 months after the intervention, both FEV_1_ and dose-response ratios improved in the intervention group but not the control group (p<0.001). The number of children with wheeze and symptoms that limit activity did not change but night cough decreased significantly in the intervention group (p<0.001). There was no significant difference in physician or ED visits or days absent from school. ^88^
Wilson et al. ^94^ ^§^ | Overall goals are that parents gain the knowledge, skills and motivation to prevent asthma symptoms; appropriately manage symptoms when they occur; utilize medical, educational and interpersonal resources appropriately for asthma care; communicate effectively with all adults responsible for the child's care; and promote the psychosocial well-being of the family unit. | 64 families of children between 6 months and 6.5 years old with asthma in the U.S. completed the trial. N_int_=33; N_con_=31. | RCT | The Wee Wheezers intervention involved 4 small group sessions (2 hours each) at one-week intervals conducted by experienced asthma nurses. Parents of children 0–3 years and 4–6 years met in separate groups. For the 4–6 years group, the initial 45 minutes involved direct instruction to the children, which included videos and lectures, asthma action plans, inhaler use, and information recognition of early signs and triggers. Parents develop a written Asthma Action Plan for use of routine medications and at-home management of acute exacerbations. | Treatment children had significantly less increase in asthma morbidity than control children at the end of the intervention (at 3 months). The mean number of symptom-free days in the treatment group increased (8.5 to 10.2 in prior 2 weeks) but decreased in the control group (11.9 to 9.3) (p<0.01). Intervention children were more likely to adhere to their treatment regimen than control children (p<0.01). 16% of all enrolled children had at least 1 smoker in the home and there was no evidence that anyone stopped smoking in either group. ^94^

Note: N_int_=number of patients in the intervention group at the end of the study. N_con_=number of patients in the control group at the end of the study.

* QRCT=quasi-randomized controlled trials.

§ We direct interested readers to the detailed description of the Wee Wheezers program in the article by Wilson et al. ^94^ and the Wee Wheezers at Home program in the Brown et al. ^90^ ED=emergency department; PF=peak flow; QOL=quality of life. CBA=controlled before-after trial.

In this section (Table 12), we describe the included studies in groups according to these key characteristics. (Note: The number of studies described in Table 12 is greater than 54 because there is overlap between the school-based interventions and other types of interventions so those studies are presented more than once). At the end of this section, we present the results of our synthesis of the association between intervention characteristics and likelihood of finding statistically significant improvements in the outcomes of interest for patient education or self-monitoring or self-management interventions. ^‡^

‡ Many of the included patient education interventions evaluated changes in asthma knowledge among intervention and control participants. Asthma knowledge was not one of our key outcomes of interest; however, we abstracted information about this outcome and present it, where available, in Table. Often the asthma knowledge in both groups increased, occasionally, it increased to a greater extent in the intervention arm.

Parent or caregiver education programs. Whereas most school-age children are typically considered to be sufficiently mature to benefit from asthma education offered outside the context of their families, preschool children learn new skills best within the context of their families, and parents are the primary target of the education of the youngest children with asthma (less than seven years). ^90^ Among the included articles, we found 21 that included educational interventions directed at parents or caregivers (Table 12a)—13 (62%) of which found statistically significant improvements in processes and outcomes of care for children with asthma. In particular, this type of study was likely to report improvements in clinical outcomes (13 studies found improvements in asthma symptoms and other clinical outcomes among the 15 studies reporting these types of outcomes). Four studies compared two or more parent or caregiver education programs with each other but did not include a control group that did not also receive an educational intervention—these are described in Table 21. ^60,^ ^62,^ ^64,^ ^65^

Notable for its size and methodological rigor, the National Cooperative Inner-City Asthma Study (NCICAS) evaluated the effectiveness of a multifaceted, home-based intervention for 1,033 inner city children aged 5 to 11 years with asthma from seven U.S. cities living in census tracts in which at least 20% of households had income levels below the federal poverty level. ^73^ – ^75^ The NCICAS evaluated an educational intervention designed to teach caregivers about asthma management and to reduce those environmental asthma triggers to which their children had positive skin tests. ^73^ Intervention families were given training on asthma triggers, environmental controls, and asthma physiology by social workers and were given tools to reduce environmental allergens such as vacuum cleaners, pillow covers, and air filters. Two years after enrollment, intervention children had more symptom free days (565.1 versus 538.5 days), fewer asthma symptoms (p<0.001), days lost from school (0.54 versus 0.71 days per two weeks, p<0.009), and lower allergen levels. ^73^ There were no differences in hospitalization rates, physician visits, or emergency department between intervention and control groups. ^74,^ ^75^ The cost of the intervention was $337 per child for 2 years resulting in an estimated incremental cost-effectiveness ratio of $9.20 per symptom-free day gained (95% CI: -$12.56 to $55.29 per symptom free day gained). ^75^ We cannot assess the extent to which it was the educational component or the reduction in environmental allergens that resulted in improvements for intervention subjects.

The study by Toelle and colleagues ^88^ differed from the others in this section in that it was an educational program directed broadly at children with asthma and all the adults who influence their care including parents, physicians, teachers, pharmacists, community nurses, and school teachers. Six months after the intervention, pulmonary function (FEV_1_(L) was 2.13 at six months vs. 1.78 at baseline) improved in the intervention group but not the control group (p<0.001). The number of children with wheeze and symptoms that limited their activity did not change but night cough decreased a statistically significant amount in the intervention group (37.3% at six months vs. 68.3% at baseline; p<0.001). There was no statistically significant difference in physician or emergency department visits or days absent from school.

School-based education programs. Sixteen of the studies of pediatric QI studies delivered some portion of their intervention in schools—13 of these were patient education programs (Table 12b). Eleven school-based programs (69%) reported statistically significant improvements in processes and outcomes of care for children with asthma. Although these interventions all occurred in schools, they were highly heterogeneous in terms of the curriculum delivered, training of the person(s) delivering the curriculum, intensity of the program, and target audience. Two studies used the same 6 session educational program called “The Roaring Adventures of Puff.” McGhan and colleagues ^91^ studied the effects of this program in 7 to 12 year old children in Edmonton and Cicutto and colleagues evaluated this program in 6 to 11 year olds in Toronto. ^77^ In both studies, this program—which is based on asthma practice guidelines, social cognitive theory, and self-regulation theory and utilizes numerous teaching modalities including puppetry, games, role playing, model building, discussions, and asthma diary recordings—found reductions in asthma-related limitations in activity (McGhan et al. reported that in the intervention group, 41.5% of children at baseline vs. 29.2% children post-intervention were limited in their kinds of play; Cicutto et al. reported 6.2 versus 9.1 days of limited activity in the intervention compared to the control group). ^77,^ ^91^

Table 12b Summary of school-based patient education interventions directed at children with asthma

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Christiansen et al. ^104^ | To evaluate the effects of a school-based program for Hispanic children with asthma. | 42 children in the 4^th^ grade (aged 9 to 12 years) in Southeast San Diego with asthma. N_int_=27; N_con_=15. | CBA | Intervention children attended five 20-min sessions at school led by a school nurse practitioner on asthma information, identification of symptoms, reduction of asthma triggers, use of inhalers and PF meters and the development of an action plan. | After 6 months, the asthma symptoms scores were lower in the intervention group than in the control group (p=0.019). There were no differences in PF, school absenteeism, ED visits, or hospitalizations. ^104^
Cicutto et al. ^77^ | To evaluate whether an interactive childhood asthma education program “Roaring Adventures of Puff (RAP),” improved asthma-related morbidity among elementary school children in Toronto, Canada. | 256 children with asthma in grades 2 to 5 (aged 6 to 11) and their parents. N_int_=132; N_con_=124. | RCT | RAP consists of 6 sessions of 50–60minutes held once a week for 6 consecutive weeks. Sessions cover use of PF meters, diary monitoring, trigger identification and control, use of inhalers and medications, symptom recognition and action plan use, and managing asthma exacerbations. Parents are invited to the last session in which children showcase their learning and new skills. The strategies utilized included games, puppetry, and model building to teach about trigger identification, medication use, symptom recognition, sharing information with teachers and parents. | 12 months after the intervention, RAP attendees had 32% fewer urgent health visits (p<0.01), less asthma-related school absenteeism (p<0.05), and less activity limitation due to asthma (p<0.01) than control children. ^77^
Evans et al. ^68^ | To evaluate whether a school-based self-management program would increase children's asthma management skills and other process and clinical outcomes for low income 3^rd^–5^th^ graders in public schools in New York. | 204 children aged 8 to 11 with asthma. | CBA | 93 children attended the Open Airways program which consisted of six 1-hour small group sessions (over a 3 week period) in which children learned basic information about asthma, recognizing and responding to symptoms, using medications and when to seek help, keeping physically active, identifying and controlling triggers, and handling problems related to school. 87 control children received no additional self-management training. | 1 year after the program, experimental children reduced the annual frequency (p=0.024) and duration (p=0.007) of asthma episodes, and annual days with symptoms (p=0.004), and they increased their self-management index score compared to controls (p=0.05). There was no difference between the groups in terms of school attendance or number of episodes requiring a physician visit. ^68^
Henry et al. ^105^ | To evaluate whether a 3 lesson package about asthma delivered by school teachers to improve symptoms and QOL for children with asthma. | Year 8 students (aged 13–14 years) in 17 intervention and 15 control schools in New South Wales Australia. N_int_=299; N_con_=234. | RCT | Each intervention school was invited to send 1 teacher to a 1-day training seminar to learn to provide a 3 lesson asthma education package designed to be taught within the health/physical education curriculum. | 6 months after the intervention, there was no significant difference in asthma symptoms. Compared with control students, intervention students has small but significant improvements in total QOL (p=0.003). ^105^
Hill et al. ^106^ | To determine whether an intervention program based on existing school and community resources can reduce school absences and improve participation in sport in children with unrecognized, under-treated asthma. | Children aged 5–10 years in Newcastle with relatively poorly controlled asthma. N_int_=149; N_con_=147. | RCT | Parents of the children with asthma were sent letters asking them to take their children for assessment by a general practitioner. The GPs reviewed treatment guidelines and use of PF meters. School nurses were given teaching materials on asthma and asked to hold teaching sessions to review with teachers how to review students' inhaler techniques. | Over the next academic year (~9mos), there was no difference in school absences, participation in school activities, or use of asthma medications. ^106^
Horner ^99^ | To evaluate the effects of a school-based education program for children combined with a home-based program for their parents on children with asthma. | 44 families of children with asthma aged 8–12 years in the U.S. participated (not clear how many in the intervention group and the control group). | RCT | Children in the intervention group participated in nine 15-minute session covering asthma physiology and symptoms, asthma triggers, management decisions using stories, games, posters, and PF meters. Parents received a booklet on asthma pathophysiology, triggers, medication management, use of inhalers and PF meters. | 12 months after the intervention, there was no difference in school absenteeism home management by parents or self management by children between intervention and control groups. ^99^
Lwebuga-Mukasa and Dunn-Georgiou ^107^ | To evaluate the feasibility and effectiveness of a school asthma program in reducing asthma exacerbations among school children. | Children with asthma aged 4–13 attending 5 elementary school in Buffalo, NY. | CBA | Intervention schools implemented a policy requiring that children with diagnosed asthma who have needed daily medications for the condition in the past 12 months, have a health care provider written asthma care plan available at school for home room teachers and the school asthma health team to access. The children, and their parents or guardians and school personnel received a 2-hour educational session on early signs of an asthma attack, medications, how to monitor a response, and when to seek for additional help. They also were educated on recognizing and removing asthma triggers. | There was a greater reduction in rescue treatments in intervention schools (79.6%) compared to control schools (28.6%) in the Spring of 1998 compared to the Fall of 1996. ^107^
McGhan et al. ^76^ | To determine whether the asthma education program “Roaring Adventures of Puff (RAP),” improved asthma management behaviors and health status in elementary school children in Edmonton, Canada. | 136 children with asthma aged 7–12 years. N_int_=65; N_con_=71. | RCT | Parent and teacher asthma awareness events were held within the school setting. The intervention provided recommendations for school asthma guidelines and six educational group sessions for children with asthma described above. ^77^ | 9 months post-intervention, experimental children had “more appropriate use of preventive medication” (p<0.001), improvement in asthma-related limitations in play, (p<0.001) but there were no differences between groups for use of reliever medications, proportions of children on inhaled steroids or bronchodilators, having an action plan, ED visits, unscheduled doctor visits, asthma symptoms, or days lost from school. 26% of the children had regular smoking in the home. ^76^
Persaud et al. ^87^ | To evaluate the effects of a school-nurse based self management program for school children in Texas. | 36 children aged 8 to 12 with moderate to severe asthma. | RCT | All children had a visit with a primary care provider at the time of enrollment during which time they were all given written guidelines for medication use, asthma control and prevention, PF meters, and asthma diaries. Intervention children (N=18) also received 8 individualized, weekly, 20 minute sessions with a school nurse to review asthma symptoms and medication and PF meter use. Control children (N=18) visited the school nurse sporadically, on their own initiation. | 20 weeks after enrollment, the percentage of children visiting the ED for asthma was higher in the control group (50%) than in the intervention group (22%, p<0.05); however, there were no differences in number of ED visits per child or days lost from school between groups. ^87^
Salisbury et al. ^108^ | To compare a nurse-led clinic in schools with general practice care for adolescents with asthma. | 382 adolescents with asthma attending secondary schools in Bristol, North Somerset, and South Gloucestershire, U.K. | RCT | Adolescents were randomized to receive either usual care with a pediatrician or to attend a nurse-run asthma clinic. The care in these school-based clinics was “similar to that offered at a nurse-led asthma clinic in general practice, but the discussion was specifically targeted at the needs and interests of adolescents.” ^108^ | At 6 months, intervention adolescents had better inhaler technique, were more like to have a PF meter, and self management plans. There was no significant difference between groups in terms of asthma symptoms, days lost from school, use of inhaled steroids, health services utilization, or health related QOL. The costs of six months asthma care for the interventions were higher than for the control patients. ^108^
Shah et al. ^92^ | To determine if a peer-based, in-school asthma education program can improve HRQL, pulmonary function, and asthma attacks in adolescents with asthma in New South Wales, Australia. | 272 students with asthma aged 12–16 years (grades 7 and 10). N_int_=113; N_con_=138. | RCT | 3-step approach: Step 1: student volunteers were trained as asthma peer leaders during a 6 hour workshop on educating their peers about asthma and its management using games, videos, worksheets, and discussions. Step 2: teams of 3–4 asthma peer leaders conducted three 45-minute health lessons for students in their schools. Leaders used teaching tools to guide students to critically analyze the barriers to asthma management. Step 3: students developed and presented key messages learned in the lessons to their peers. Presentations given by students included short acts, dramas, and songs. All students with asthma were issued a record card to be completed by their doctor. | The results for this study were not reported for all intervention students compared to all control student but were reported for intervention and control students in the 7^th^ grade and the 10^th^ grade. At 8 months, the intervention group had a significant decrease in days absent from school among the 10^th^ graders but not the 7^th^ graders (8 vs. 5days) but not the control group (5.5 vs. 4 days, p<0.05). There was no change in pulmonary function or asthma symptoms. ^92^
Velsor-Friedrich et al. ^69^ | To examine the effects of a school-based intervention program on self care abilities, practices and health outcomes of children with asthma. | 102 African American 8–13 year old children with asthma recruited from 8 inner-city public elementary schools in Chicago. N_int_=40, N_con_=62. | QRCT* | The “Open Airways” educational program utilized an interactive teaching approach applying group discussions, stories, games and role-playing to promote children's active involvement in the learning process. In six 45-minute sessions offered once a week, small groups of children learned new asthma management skills. | 5 months after completion of the program, the treatment group had significantly more improvement in PF measurements (7.5% vs. 2.9% improvement, p=0.046), reduction in number of days with symptoms (p=0.047), and number of urgent medical visits (p=0.01). No differences in terms of reported medication use or school absences. ^69^
Webber et al. ^70^ | To evaluated whether the Open Airways program would reduce asthma morbidity and health services utilization among inner-city children with asthma in the Bronx. | 599 3rd to 5th graders in the Bronx with asthma. | CBA | 599 children in schools with school-based health centers were scheduled to attend the Open Airways program (as described in the two prior studies). They were compared with students in schools with school-based health centers that did not offer the Open Airways program (N not specified) and children in control schools without school-based health centers (N not specified). | Approximately 15 months after enrollment, there were declines in office visits for children attending schools with school-based health centers (with and without the Open Airways program) but not for control school children (for whom there was a (9% increase in office visits) (p=0.01). ED use and hospitalizations declined for all children (no difference among groups). ^70^

Note: N_int_=number of patients in the intervention group at the end of the study. N_con_=number of patients in the control group at the end of the study.

* QRCT=quasi-randomized controlled trials; ED=emergency department; PF=peak flow; QOL=quality of life. CBA=controlled before-after trial.

Adolescent education programs. During adolescence, developmental behavioral changes can have adverse effects on asthma management if medication adherence declines or medical supervision becomes less consistent. ^92^ We found six studies of educational interventions that exclusively targeting adolescents with asthma (Table 12c). None of these six adolescent-targeted interventions, even those that relied on peer teachers or intensive educational programs from physicians or nurse educators, resulted in statistically significant durable improvements in inhaled bronchodilator use, asthma symptoms control, or health services utilization. We note that five of these were relatively short with interventions lasting eight months or less.

Table 12c Summary of patient education interventions directed at adolescents with asthma

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Bynum et al. ^51^ | To assess the effectiveness of pharmacists using interactive compressed video (telepharmacy) for teaching MDI technique to rural, adolescents with asthma. | 36 adolescents in grades 7–12 with asthma from junior high and high schools in rural Arkansas. N_con_=21, N_int_=15. | RCT | All patients had two 15-minute individual sessions with a pharmacist. During the 1^st^ session, intervention subjects demonstrated their MDI technique and were then counseled by a pharmacist via verbal instructions and demonstrations on any needed corrections to their MDI technique. MDI technique was immediately reassessed and measured again 2–4 weeks later (follow up). The control subjects demonstrated MDI technique, were then given written instructions for MDI technique on a package insert with a placebo inhaler, and their MDI technique was assessed again immediately and 2–4 weeks later (follow up). The sessions took place at local health clinics equipped with interactive compressed video technology. | At the 2–4 week follow up, there was no significant difference between the intervention and the control group in MDI technique. However, the intervention group did have statistically significantly more improvement in MDI technique from baseline than the control group (p<0.001). ^51^
Cowie et al. ^109^ | To determine the effects of an age-specific asthma program on the rate of hospitalizations and QOL. | 62 asthma patients aged 15–20 years old in Calgary. N_int_=29; N_con_=33. | RCT | Patients were invited to attend the Young Adult Asthma Program (YAAP) and were asked to follow up 1 year after. The program included 2–5 sessions that involved an initial questionnaire, an assessment of inhaler technique, spirometry, and asthma education delivered by a physician, or health educator. | At six months after the enrollment, there were no differences between groups in terms of disease control, hospitalizations, use of inhaled corticosteroids, symptoms, or days lost from work or school. 53% of the subjects smoked or lived with a smoker. There was no reduction in smoking after the intervention. ^109^
Henry et al. ^105^ | To evaluate whether a 3 lesson package about asthma delivered by school teachers to improve symptoms and QOL for children with asthma in New South Wales Australia. | Year 8 students (aged 13–14 years) in 17 intervention and 15 control schools. N_int_=299; N_con_=234 had asthma. | RCT | Each intervention school was invited to send 1 teacher to a 1-day training seminar to learn to provide a 3 lesson asthma education package designed to be taught within the health/physical education curriculum. | 6 months after the intervention, there was no significant difference in asthma symptoms or limitations in activity due to symptoms. Compared with control students, intervention students has small but significant improvements in total QOL (p=0.003). ^105^
Salisbury et al. ^108^ | To compare a nurse-led clinic in schools with general practice care for adolescents with asthma. | 382 adolescents with asthma attending secondary schools in Bristol, North Somerset, and South Gloucestershire, U.K. | RCT | Adolescents were randomized to receive either usual care with a pediatrician or to attend a nurse-run asthma clinic. The care in these school-based clinics was “similar to that offered at a nurse-led asthma clinic in general practice, but the discussion was specifically targeted at the needs and interests of adolescents.” ^108^ | At 6 months, intervention adolescents had better inhaler technique, were more like to have a PF meter, and self management plans. There was no significant difference between groups in terms of asthma symptoms, days lost from school, use of inhaled steroids, health services utilization, or health related QOL. The costs of six months asthma care for the intervention adolescents were higher than for the control patients. ^108^
Shah et al. ^92^ | To determine if a peer-based, in-school asthma education program can improve HRQL, pulmonary function, and asthma attacks in adolescents with asthma in New South Wales, Australia. | 272 students with asthma aged 12–16 years (grades 7 and 10). N_int_=113; N_con_=138. | RCT | Step 1: student volunteers were trained as asthma peer leaders during a 6-hr workshop on educating their peers about asthma and its management using games, videos, worksheets, and discussions. Step 2: teams of 3–4 asthma peer leaders conducted three 45-min health lessons for students in their schools. Leaders used teaching tools to guide students to critically analyze the barriers to asthma management. Step 3: students developed and presented key messages learned in the lessons to their peers. Presentations given by students included short acts, dramas, and songs. Students with asthma were issued a “record card” to be completed by their doctor. | The results for this study were reported only for intervention and control students in the 7^th^ and 10^th^ grades. At 8 months, the intervention group had a significant decrease in days absent from school among the 10^th^ graders but not the 7^th^ graders (8 vs. 5days) but not the control group (5.5 vs. 4 days, p<0.05). There was no change in pulmonary function or asthma symptoms. ^92^
van Es et al. ^110^ | To determine if a theory-based educational intervention can improve medication adherence in adolescents with asthma in the Netherlands. | 67 adolescents with asthma aged 11–18 years old and attending secondary school. N_int_=33; N_con_=34. | RCT | A treating physician and a trained asthma nurse provided intensive educational intervention, which involved 4 monthly physician visits, 4 individual visits with asthma nurse, and 3 group sessions. Patients were instructed on medication use, self management, coping skills, communication. | At 24 months after the intervention, the education group reported somewhat higher self-reported adherence (score of 7.7 vs. 6.7 on a 10 point scale in which 1=never take prophylactic medications to 10=always take prophylactic medications) p=0.05. ^110^

Note: N_int_=number of patients in the intervention group at the end of the study. N_con_=number of patients in the control group at the end of the study. ED=emergency department; PF=peak flow; QOL=quality of life

We found 24 studies of self-monitoring, self-management, or patient education of general pediatric populations with asthma that included adolescents. Of these, 18 (75%) reported at least one positive outcome. Similarly, adolescents were included in 26 of the interventions directed at general populations with asthma—18 (70%) of these reported at least one positive outcome. Among these 50 studies that included adolescents as part of their study population but were not exclusively targeting adolescents, 14 (28%) reported statistically significant improvements in asthma symptoms or disease severity compared to controls and 12 (24%) reported significantly fewer emergency department/urgent care visits compared to controls. Because none of these studies reported outcomes by age strata, the extent to which these improvements were found among adolescents is unclear.

Outpatient education programs. We found 15 additional studies of educational interventions designed for children with asthma that were coordinated from the outpatient setting, sometimes including home visits and calls (Table 12d). Several of the included studies that directed the educational intervention at children but did not include parental involvement (particularly for young children) did not find statistically significant improvements in the processes or outcomes of care for the asthmatic patients. Several authors noted that even among families with older children, parents did not always respond to the suggestions raised by their children after participation in the educational intervention. ^54^ Sometimes this was because parents could not afford or were unable to remove environmental factors such as wall-to-wall carpeting in their public housing residences. ^54^ Others who were capable of removing some allergens or irritants sometimes denied that a particular environmental exposure, such as their smoking, was harmful to the child. These observations strongly suggest that parallel educational activities focusing on parents as well as their children may be needed.

Table 12d Summary of outpatient patient education interventions directed at children with asthma

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Alexander et al. ^111^ | To evaluate whether clinical nurse specialist involvement would influence ED utilization by poorly controlled, noncompliant children with asthma. | 21 children (<14 years old) with no regular physician who had had one or more ED visits in Tennessee within the past year. N_int_=11; N_con_=10. | RCT | Patients were cared for by a CNS (Clinical Nurse Specialist) that assumed responsibility for assessment, counseling, and follow up. Education was provided in 2–5 classes or sessions. | At 1 year, there was a significant greater reduction in ED visits (2.6 to 0.6 visits per patient per year) among the study group than the control group (2.5 to 2.4) (p<0.05). ^111^
Bonner et al. ^112^ | To determine the effects of a theory-based educational intervention on asthma knowledge, adherence, symptoms, and prescription of anti-inflammatory medication in urban Latino and African American families with pediatric asthma. | 119 asthma patients treated in the general pediatric clinic or pulmonary clinic of an urban university hospital in New York. Mean age 9.5years (range: 4.2 to 19.1yrs); N_int_=56; N_con_=63. | RCT | A trained, bilingual family coordinator delivered intensive, individualized educational intervention, which consisted of 3 asthma workshops that stressed management of chronic disease, coached families about ways to improve communication with doctors, accompanied families to clinic visits to facilitate communication, monitored diaries, and stressed avoidance of triggers. The intervention also included allergy testing to help with avoidance of triggers, and home inspection for potential triggers. | At 3 months, the intervention group had an increased in prescriptions of controller medications, adherence to pharmacotherapy, prophylactic use of bronchodilators, and decreases in symptom persistence and activity restriction (p<0.05 for all comparisons). ^112^
Burkhart et al. ^71^ | To determine the effects of interventions that combine education and behavioral techniques in managing asthma at home. | 42 English-speaking children aged 7–11 years with persistent asthma in Kentucky; N_int_=21; N_con_=21. | RCT | Patients received asthma education and instructions on how to use an electronic PF meter twice daily and record data in an asthma diary. Patients received three 1-hour individual sessions with a nurse, a contingency management intervention, which consisted of a contingency contract, reinforcement, tailoring, and reminders. The contract outlined requested behaviors (PF monitoring, diary self-reporting) and associated rewards. (We describe the rewards used in the section on financial incentives.) A nurse educator also contacted patients weekly to reinforce teachings. The control group received the teaching sessions but no contingency contract and no follow up calls from nurses. | At 5 weeks, they found no difference in adherence with PF monitoring between the intervention and the usual-care (control group) children. ^71^
Deaves ^113^ | To determine the effectiveness of a health educator in improving outcomes of care for children with asthma in Staffordshire. | 63 children with asthma aged 3–16 years in one of 2 general practices N_int_=32; N_con_=31. | *QRCT | In a one-time class, children were taught to use PF meter and to keep diary records of asthma events. Parents were given an explanation of the mechanisms of asthma and action of treatment prescribed and given a package of written information | At two years, there were no differences between intervention and control groups in terms of physician-assessments of asthma severity, number of asthma attacks, or days lost from school. However, intervention children had fewer nighttime symptoms and less activity restrictions (p<0.001). ^113^
Glasgow et al. ^114^ | Train providers to use and then evaluate the feasibility and effectiveness of a general practice-based, proactive system of asthma care in children with moderate to severe asthma. | Australian children (101 intervention and 73 control) with moderate to severe asthma and a general practitioner and their physicians (12 control and 12 intervention physicians) were enrolled. | RCT | The physicians received 1-to-1 education by one of the study authors on a “3+ Visit Plan” (1^st^ visit: introduce concept of a contract for asthma care; 2^nd^ visit: assess patient's status; 3^rd^ visit: review patient's PF record, complete asthma action plan, and identify triggers; 4^th^ visit: assess progress and answer questions. | 12 months after the intervention, intervention children had increased use of written asthma action plans and pressurized metered dose inhalers with a spacer, decreased rates of speech-limiting wheezing, and were less likely to use reliever medications more than 4 days of the week. There was no difference in symptom-free days or ED visits. ^114^
González-Martin et al. ^115^ | To measure the effects of a pharmaceutical care program in children with asthma. | 21 children with stable and moderate asthma in Chile. N_int_=11; N_con_=10. | RCT | Children were assigned to either a pharmacist-led asthma program or to usual care by their pediatricians. The intervention pharmacists provided both written and verbal instructions to children and parents, information about asthma triggers, treatment alternatives, inhaler techniques, medication side effects, and what to do in the event of an acute attack. | 9 weeks after enrollment, there were no differences in spirometry or any domains of health-related QOL. ^115^
Homer et al. ^54^ | To assess the effectiveness of multimedia educational software program about asthma for inner-city children. | Children aged 3 to 12 with asthma living in inner-city Boston. N_int_=57; N_con_=49. | RCT | “Asthma Control” is an interactive educational computer program designed to teach children about asthma and its management. The object of the game is to help the main character, Spacer, a superhero with asthma complete all 6 game levels (3 home and 3 outdoor levels). The player uses his/her knowledge of asthma to help Spacer eliminated common indoor allergens (e.g., cats, smoke) and to avoid outdoor allergens. If Spacer's condition worsens, the program producing coughing and wheezing sounds and may not be about to jump or run. If the player does not eliminate allergens or use preventive medications, Spacer's mother blocks his/her exit from home. Study patients were asked to return to the study site 3 times to use the asthma control educational computer program. | During the one year study period, there were no differences between intervention and control children in terms of ED visits, acute office visits, asthma severity, exposure to environmental triggers, use of PF meters, or asthma management behaviors.
| | | | | Note: 40% of children enrolled in the study had exposure to a least one smoker at home. ^54^
Hughes et al. ^116^ | To determine if education clinic visits and home visits (a comprehensive and ambulatory program) for pediatric asthma management can improve asthma outcomes. | 89 children with asthma aged 6–16 years living in Halifax county, Canada. N_int_=44; N_con_=45. | RCT | Patients were seen by a pediatric “respiratologist” throughout study period at 3-month intervals. Families were provided a special card to be shown if they were to come to hospital ED. At each clinic visit, a physician outlined the asthma management program, which included the topics of avoidance of triggers, exercise, and medication use. Proper aerosol technique and home management of acute exacerbations were reviewed. Each family was given an education pamphlet. During home visits, potential environmental triggers were identified and discussed. If school problems related to asthma were identified, the nurse coordinator contacted the teacher for discussion. | The intervention group demonstrated improvements in asthma severity scores (p=.02), inhaler technique (p=0.008) and had fewer office visits to primary care physicians than control patients. There were no difference in symptoms (including nighttime symptoms), days missed from school for asthma, ED visits, or hospitalizations at 2 years after the intervention. 59.6% of intervention families and 57.4% of control families had at least one smoker in the home. There were reductions in smokers in both groups, no difference between groups. ^116^
Kamps et al. ^117,^ ^118^ | To establish whether there are differences between outpatient management of childhood asthma by pediatricians or by asthma nurses. | 74 children aged 2–16 with chronic persistent asthma in the Netherlands. | RCT | Children were randomly assigned to receive 1 year of asthma care by either a pediatrician or a specialist asthma nurse. The asthma nurse provided detailed education about the mechanisms of disease, use of medications, management of acute symptoms, and proper inhaler techniques. | At 1 year, there was no difference between children receiving asthma care from a pediatrician than from a nurse specialist in terms of symptom-free days, airway hyperresponsiveness, functional health status, disease-specific QOL. ^117^ There was also no difference between the groups in terms of daily dose of inhaled or oral steroids, courses of antibiotics, unscheduled outpatient visits, ED visits, hospitalizations, or overall healthcare costs. ^118^
Kelly et al. ^119^ | To examine the effects of a comprehensive education and outreach program designed to decrease ED utilization and hospitalization for Medicaid-insured children with asthma. | 78 children with asthma aged 2–16 years enrolled in Medicaid and receiving their care in Norfolk, Virginia. | RCT | Intervention children (and their caretakers) were enrolled in an education and treatment program in a pediatric allergy clinic. They received 1-on-1 education by a physician and asthma outreach nurse on topics including recognition of triggers, environmental control, early warning signs and symptoms, medication usage and side effects, proper usage of inhalers and PF meters. The nurse contacted intervention families monthly to review the patient's health status, symptoms, medications, refill prescriptions, and assist with scheduling and transportation to clinic follow up. | At the end of the study year, intervention children were less likely to have an ED visit and more likely to receive an annual influenza vaccine (95% vs. 23%; p<0.001). 47% of the intervention group and 50% of the control group reported ≥1 smoker in the home. Subgroup analysis suggested a trend toward greater effectiveness of the intervention to decrease hospitalizations among children residing in smoke-free households. ^119^
LeBaron et al. ^120^ | To assess the effects of an educational program on patient compliance with cromolyn. | 31 children aged 6–17 years with mild to moderate asthma not receiving corticosteroids from three private allergy practices in San Antonio, TX. N_con_=16, N_int_=15. | RCT | After baseline assessments, patients in the education group received 4 monthly sessions during which patients and their parent(s) received individual instruction from a registered nurse on how and when to use cromolyn. Patients in the control group also had 4 monthly follow up visits during which they were allowed to remain for a longer time in the study office than their allergy visits would have typically lasted during which time they could describe to the investigators any problems their asthma. | After 3 months, there was no significant difference between the groups in frequency or severity of attacks or physician assessment of asthma control in the patients. Comparisons were not made between the intervention and control group for cromolyn sodium compliance because of the high levels of compliance in the experiment and control group at baseline. ^120^
Perrin et al. ^121^ | To determine the effects of a controlled trial of a combined education and stress management program on the psychological status and daily activities of children. | 56 children aged 6–14 with asthma in the U.S. N_int_=29; N_con_=27. | RCT | The intervention consisted of sessions including both an education portion and a stress management exercise. 1^st^ session: physician provided education on basic lung function and anatomy and mechanisms of breathing and breathing control. 2^nd^ session: reviewed effects of asthma on other bodily functions and patients' feelings. 3^rd^ session: patients learned methods of prevention and treatment. 4^th^ session: review of previous sessions and discussion of exercise, long-term outcomes, growing up with asthma. | No difference in terms of days of school missed or other functional measures at 4 weeks. ^121^
Runge et al ^52^ | To evaluate whether an internet-based education program as an add-on to a standard patient education program improved health outcomes and reduced costs of children with asthma in Germany. | 178 children with asthma aged 8–16. | CBA | 48 children in the control group received no education until after the trial. 86 children received the self-management program of five 2hr sessions in which they used role-playing and small group sessions to teach inhaler use, trigger avoidance, medication management, PF monitoring, and decision making. 44 children received this self-management plus self-selected to also use the interactive internet adventure game incorporating virtual asthma-related situations in need of management and also access to online chats with asthma experts, an online PF protocol that can be maintained by the patient, and chat rooms for other users and healthcare providers. | 6 months after enrollment, the self-management plus internet (SMI) education group had a mean of 0 emergency visits compared to 0.2 for the control group (CG) and 0.3 for the self-management (SM) alone group (p<0.03). The SM group had significantly (p<0.05) fewer physician visits (-44%) and emergency treatments (-67%) than CG. PF improved in all groups, no difference among groups. Significant improvements were seen in 3 of 8 QOL domains in both intervention groups but not in the CG. It cost 585€ to deliver the SMI intervention which reduced asthma costs by 461€. Adjusting for benefits in the CG, 0.79€ were saved for every 1€ spent on the SMI intervention during the 1^st^ year. 1 yr follow up data available for the intervention groups but not CG.) ^52^
Shames et al. ^58^ | To determine if a multi-factorial (behavioral, educational and medical) intervention that includes the use of an asthma education video game intended to promote asthma self-management can reduce morbidity among high-risk, school-aged children. | 59 children 5 to 12 years old of low socioeconomic status (receiving or eligible for Medi-Cal) in the San Francisco and San Jose areas. N_int_=59; N_con_=60. | RCT | Case managers delivered a 3-session curriculum on asthma self-management, helped coordinate appointments, and made follow up phone calls. The intervention included a super Nintendo asthma video game designed to teach self-management strategies and provide feedback on their performance (in Spanish or English) and an 18-hour per day toll-free hotline staffed by pediatric nurses who had access to each participant's individualized asthma management plan. Patients visited a board certified pediatric allergist-immunologist. Acute and chronic asthma management plans were provided to the families, case managers, and primary care provider. | At 52 weeks, there was no significant difference between the intervention and control groups for symptom-free days, use of a rescue bronchodilator, number of asthma urgent care visits, PF, or FEV_1_. There were some improvements in health related QOL in the intervention group. ^58^
Shields et al. ^122^ | To evaluate whether an educational program for children with asthma could decrease ED use. | Patients 18 years or younger who had at least 1 ED visit or hospitalization in Chicago for asthma during the prior 4 years. N_int_=101; N_con_=104. | RCT | A nurse provided education within classes and phone calls and covered 23 instructional objectives with 4 content areas: prevention of attacks, medication management, intervention during asthma attacks, and utilization of health care resources. | At 1 year, there was no reduction in ED use, hospitalizations, or office visits between the groups. ^122^
Smith et al. ^123^ | To evaluate an educational intervention to improve medication compliance in Australia. | Patients were invited to participate in the study if they had been prescribed continuous medication, spoke English, and were intending to return to the clinic. N_int_=93; N_con_=103. | RCT | Within an outpatient specialty care setting, a physician provided patients with a one time educational session that included written drug information and behavioral strategies. | The intervention group reported better compliance with medicine regimens than controls (78% vs. 54.5%, p<0.001). ^123^
Weingarten et al. ^124^ | To evaluate the effects of multi-disciplinary non-pharmaceutical management of childhood asthma. | 21 children with asthma receiving medical care in a general practice in Israel. | RCT | Children were examined by a family physician and a physiotherapist and received information about asthma and its treatment. They also received 12 one-hour group sessions with a physiotherapist who discussed chest expansion exercises for improved lung capacity and clearance of secretions. Mothers had 10 two-hour group meetings with social workers to develop coping mechanisms for acute attacks. | At the end of 10 weeks, PF increased in the intervention group but not in the control group. ^124^

Note: *QRCT=quasi-randomized controlled trials. N_int_=number of patients in the intervention group at the end of the study. N_con_=number of patients in the control group at the end of the study. ED=emergency department; PF=peak flow; QOL=quality of life. CBA=controlled before-after trial.

Conclusions. Patient education interventions can be effective for improving the processes and outcomes of care for children with asthma. In particular, school-based programs and those directed at parents or caregivers of young children with asthma (even among lower socio-economic groups) tend to be associated with the greatest improvements in asthma outcomes. However, the effect sizes were often only of borderline clinical significance. Additionally, the few QI strategies that exclusively targeted adolescents have not resulted in much success—emphasizing the need for additional study of this key asthma population.

#### Synthesis of Evidence From Self-Monitoring, Self-Management, or Patient Education Interventions for Children With Asthma

In this section we present the results of our evaluation of the association of study design characteristics (e.g., whether the authors specified a theoretical/conceptual framework, year of study, sample size, country), intervention characteristics (e.g., whether parents or caregivers were a target of the intervention, the number of educational sessions provided to students, the setting in which the intervention took place), and improvements in the outcomes of interest for the self-monitoring, self-management, or patient education interventions. We present our analyses according to each of the primary outcome types.

Clinical Outcomes. The 48 studies of pediatric or caregiver education interventions that evaluated clinical outcomes were highly heterogeneous with respect to their reporting of asthma symptoms, spirometric measures, and asthma attacks. (For example, asthma symptoms were reported varyingly as percentage of days with wheeze, amount of daytime wheezing, self-reported severity, and change in physician reported asthma symptoms, among others.) Similarly, we were interested in the effect of these interventions on the amount of rescue medications used in contrast to routine inhaled corticosteroids; however, the heterogeneity of reporting of these outcomes limited our ability to combine them quantitatively. Thus, we evaluated the study design and intervention characteristics associated with the finding of one or more statistically significant clinical outcomes using logistic regression (Table 13). We found that among all studies of pediatric asthma evaluating self-monitoring, self-management, or patient education interventions, those directed at parents or caregivers were most likely to be associated with a statistically significant improvement in clinical outcomes (p=0.02). However, there is insufficient evidence to assess the effect of other key intervention factors such as the intensity of the intervention (i.e., number of times the educator met with the child, parents, or caregivers), the type of provider of the education (e.g., nurse, physician), setting of the educational intervention (e.g., home, school), or the type of educational materials on clinical outcomes.

Functional Status Outcomes. Twenty-seven studies reported the mean (or median) days lost from school in a manner that could be use in a summary analysis (as opposed to providing a statement indicating that there was no difference between treatment and control groups for school absenteeism or a ratio of days in attendance to days absent). For those studies that did not specifically report the timeframe over which the school absenteeism was recorded (e.g., days absent per month versus per school year); we assumed that the reported days of missed school were for the entire study duration. When interpreting these data, we note that not all authors specifically identified these data as mean days lost from school and some likely represent other parameters such as total days lost from school for the whole cohort.

Figure 8 (next page) presents the individual study and summary standardized mean difference (between intervention and control groups) for school absenteeism per month due to asthma. The weighted mean reduction in days absent was 0.11 days/month (95% CI: 0.05, 0.17; p=0.0004). This corresponds to a standardized mean reduction in days absent of 0.53 (95% CI: 0.06, 0.99; p=0.03). However, the studies included in this analysis were highly statistically heterogeneous (Figure 8). Additionally, visual inspection of the funnel plot of these data (Figure 7) suggests that there may be publication bias affecting this result because most of the published studies demonstrated less school absenteeism in the intervention group. Thus, given this heterogeneity and possibility of publication bias, we cautiously conclude that among the self-monitoring, self-management, or patient education studies reporting mean school absenteeism, there may be an overall effect toward reducing asthma-related school absenteeism. Moreover, the magnitude of the effect is relatively small.

Figure 7. Funnel plot: school absenteeism due to asthma

Figure 8. Self-monitoring, self-management, or patient education studies reporting mean number of school days missed due to asthma per month

Notes: The effect sizes presented here are the random effects standardized mean difference (SMD). For those studies that reported the total number of school days missed for asthma per group, we divided the total number of school days missed by the number of subjects in each group to approximate the mean number of days missed per student. For the 13 studies that did not report a measure of variance, we extrapolated a variance from the studies reporting both mean days absent and a variance about this mean weighted by the sample size. We divided the mean number of school days missed by the duration of the study to calculate the mean number of school days missed per month.

We sought study design and intervention characteristics associated with the greatest reductions in school absenteeism. For this analysis, we used the standardized mean difference in school absenteeism as the dependent variable in a weighted least squares regression. We found that the longer the study duration, the greater the expected reduction in asthma-related school absenteeism (p<0.0001) (Table 14).

Table 14 Association of pediatric self-monitoring, self-management, or patient education intervention characteristics and reductions in school absenteeism

Predictor Variables | Regression Coefficients (SE) | P value
Model Constant | 20.974 (95.357) | .829
Intervention duration in months (continuous variable) | -0.159 (0.035) | <0.0001
Year of publication (continuous variable) | -0.01(0.048) | 0.8
Studies that specified a theoretical/conceptual framework vs. those that did not | -1.073 (0.596) | 0.09
Number of educational meetings with the students (continuous variable) | 0.450 (0.387) | 0.3

2 Model details: Weighted least squares regression (weighted by the sample size). Dependent variable: standardized mean difference effect size for school absenteeism. R=0.68. 22 studies were included in this analysis (because they reported data for each of the variables included in this regression)

Health Services Utilization Outcomes. Among the studies reporting measures of health services utilization, 17 studies reported the mean number of asthma-related emergency department or urgent care visits and 24 studies reported mean number of hospital days in a manner that could be use in summary analyses. For those studies that did not specifically report the timeframe over which the emergency department/urgent care visits or hospitalizations were recorded; we assumed that they were for the entire study duration. For some studies, the authors did not specify whether the reported number of emergency room visits was the total for their cohort or the mean visits per group. Because we calculated standardized mean differences (as opposed to weighted mean differences which are not normalized by the variance in the reported outcome), we included both of these types of data in our analyses. Some studies only reported the percentage of patients in each group who had at least one visit to an urgent care or hospital. We did not include these data in our standardized mean difference calculations. Physician office visits were reported too heterogeneously to be combined (e.g., emergency visits to physician office for asthma, regular physician visits for asthma, total outpatient physician visits).

Asthma-related emergency department or urgent care visits. Figure 11 presents the individual study and summary standardized mean difference (between intervention and control groups) for mean asthma-related emergency department/urgent care visits per month. The weighted mean reduction was 0.01 visits per month (95% CI: 0.00, 0.02; p=0.17). The standardized mean difference was -0.12 (95% CI: -0.29, 0.05; p=0.16). Additionally, the studies included in this analysis were highly heterogeneous—which can readily be seen from the wide range of reported mean visits across the studies (Figure 11-see below). Visual inspection of the funnel plot of these data (Figure 9) does not suggest significant publication bias (there are studies demonstrating a range of effect size). We conclude that among the self-monitoring, self-management, or patient education studies reporting mean emergency visits due to asthma, we did not find a statistically significant overall effect toward reducing asthma-related visits.

Figure 9. Funnel plot: asthma-related ED/urgent care visits

Figure 11. Self-monitoring, self-management, or patient education studies reporting mean number of emergency department/urgent care visits due to asthma per month

Notes: The effect sizes presented here are the random effects standardized mean difference (SMD). For the 11 studies that did not report a measure of variance, we extrapolated a variance from the studies reporting both mean days absent and a variance about this mean weighted by the sample size. We divided the mean number of emergency department/urgent care visits by the duration of the study to calculate the mean number of visits per month.

We sought study design and intervention characteristics associated with the greatest reductions in asthma-related emergency department/urgent care visits. For this analysis, we used the standardized mean difference in visits per month as the dependent variable in a weighted least squares regression. Our analysis was limited by the small number of studies reporting this outcome. We did not find any statistically significant predictors of reductions in emergency department/urgent care visits (Table 15).

Table 15 Association of pediatric self-monitoring, self-management, or patient education intervention characteristics and reductions in asthma-related emergency department/urgent care visits

Predictor Variables | Regression Coefficients (SE) | P value
Model Constant | -1.52 (2.13) | 0.1
Intervention duration in months (continuous variable) | 0.03 (0.01) | 0.07
Number of educational meetings with the students (continuous variable) | 0.46 (0.21) | 0.08
Setting in which the intervention took place (categorical variable) | 0.07 (0.13) | 0.6

2 Model details: Weighted least squares regression (weighted by the sample size). Dependent variable: standardized mean difference effect size for emergency department/urgent care visits per month. R=0.80. 9 studies were included in this analysis (because they reported data for each of the variables included in this regression.

Asthma-related hospitalizations. Figure 12 (see below) presents the individual study and summary standardized mean difference (between intervention and control groups) for mean hospital days per month due to asthma. The weighted mean difference was a reduction of 0.09 hospital days per month (95% CI: -0.26, +0.08; p=0.3). The standardized mean difference was -0.09 (95% CI: -0.26, 0.08; p=0.3). Additionally, the studies included in this analysis were highly heterogeneous—which can readily be seen from the wide range of reported mean hospital days across the studies (Figure 12-see below). Visual inspection of the funnel plot of these data (Figure 10) also suggests that there may be publication bias affecting this result (most studies report greater reduction in mean hospital days in the intervention group). We conclude that among the self-monitoring, self-management, or patient education studies reporting mean hospital days due to asthma, there is no overall effect toward reducing asthma-related hospitalizations.

Figure 10. Funnel plot: hospitalizations due to asthma

Figure 12. Self-monitoring, self-management, or patient education studies reporting mean number of hospital days due to asthma per month

Notes: The effect sizes presented here are the random effects standardized mean difference (SMD). For those studies that reported the total number of hospital days for asthma per group, we divided the total number of hospital days by the number of subjects in each group to approximate the mean number of hospital days missed per subject. For the 19 studies that did not report a measure of variance, we extrapolated a variance from the studies reporting both mean days absent and a variance about this mean weighted by the sample size. We divided the mean number of hospital days by the duration of the study to calculate the mean number of hospital days per month.

We sought study design and intervention characteristics associated with the greatest reductions in asthma-related hospitalizations. For this analysis, we used the standardized mean difference in hospitalizations as the dependent variable in a weighted least squares regression. We found that the greater the number of educational sessions provided, the greater the expected reduction in asthma-related hospitalizations (p=0.01) (Table 16). However, in none of our exploratory analyses was the intensity of the intervention, the type of provider of the education, the setting of the educational intervention, the type of educational materials used, or the number of QI strategies used in the intervention associated with reductions in school absenteeism (not all data shown).

Guideline Adherence Outcomes. The 27 studies reporting guideline adherence outcomes were highly heterogeneous. We performed logistic regression, using any statistically significant guideline adherence outcome as the dependent variable and study/intervention characteristics as the independent variables. In none of our analyses was the study design, the use of a theoretical/conceptual framework, the duration of the intervention, the frequency of interactions with the patient, the type of provider of the education (e.g., nurse, physician), setting of the educational intervention (e.g., home, school), the type of educational materials used associated with improved outcomes (data not shown).

Conclusions. We conclude that self-monitoring, self-management, or patient education interventions may result in improvements in clinical outcomes for children with asthma—particularly interventions that include a component directed at parents or caregivers. Additionally, longer intervention duration and greater numbers of educational sessions may be associated with improvements in functional status. We note that our regression analyses were limited by the small number of studies consistently reporting similar outcomes and the significant heterogeneity among the studies (which likely reflects, in part, the heterogeneity in study populations including key characteristics such as asthma severity and socio-economic status). This relatively low statistical power limited our ability to corroborate some of the univariate associations described in the preceding sections.

#### General Characteristics of Self-Monitoring, Self-Management, or Patient Education Interventions for General Populations or Adults With Asthma

Background. As for the interventions designed specifically for children, self-monitoring or self-management interventions for general populations with asthma (typically for adults but occasionally mixed populations) generally include written instructions on how to alter medications based on information about disease status as measured either by symptoms or peak flow. It has been demonstrated that patients with asthma, regardless of age, often do not use their inhalers properly—even the reputedly easy-to-use dry powder inhalers have correct usage rates that vary widely (5 to 78%). ^125^ Because poor inhaler technique can result in decreased delivery of medication to the lungs, increased asthma symptoms, higher costs, and increased side effects, ^125^ many patient education interventions are designed to improve inhaler technique and medication adherence, and to decrease asthma symptoms and prevent asthma related co-morbidities.

Study Design Characteristics. We identified 78 studies of self-monitoring, self-management, or patient education interventions for adults—59 of these included a self-monitoring or self-management intervention and 19 focused more on patient education (Table 18). Twenty-four studies compared two or more intervention groups without a control that did not also receive a QI intervention (presented in Table 21). Most of the patient education interventions for adults included at least some minimal component of providing adults with the information that they need to make decisions about their own asthma care. Thus, the self-monitoring, self-management, or patient education interventions for adults were overlapping educational interventions. Therefore, we present them together, grouping them to the extent possible according to common characteristics.

Table 18a Summary of nurse-led self-monitoring, self-management, or patient education interventions directed at adults with asthma

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Berg et al. ^133^ | To evaluate the effects of a nurse-administered asthma self-management program for patients treated in a rural setting. | 55 patients with asthma prescribed inhaled medications over the age of 18 living in a rural area in the U.S. N_con_=24, N_int_=31. | RCT | The experimental group received 6 weekly, 2-hour, nurse led asthma self-management education sessions based on Wheezers Anonymous and kept an asthma diary. The education program was held in the community and included information about self-management behaviors and skills, asthma medications, asthma triggers, and prevention of asthma attacks. The intervention group also recorded medication taking and symptom information daily. The control group received usual care. | After 7 weeks, there were no significant differences between the intervention and control groups for average totally daily symptoms, percentage of symptom-free days, and morning or evening PF. However, the intervention group was more adherent to medication regimens than the control group (p=0.043). ^133^
Bolton et al. ^147^ | To determine whether a self-management training program decreases ED visits and reduces costs for patients with asthma. | 224 adult patients with asthma aged 18–70 years who visited one of the ED departments of two hospitals (one urban, one suburban) in the U.S. N_con_=118, N_int_=106. | RCT | The intervention consisted of three one-hour small-class interactive educational sessions on asthma that stressed compliance with medical regimens and self-care. The sessions were conducted by a specially trained RN and held at one of two hospital sites. Patients in the control group received no intervention. | After 12 months, the intervention group had significantly fewer ED visits (p=0.0005) and days of limited activity (p=0.04) than the control group. There were no significant differences between the groups in hospitalizations or physician visits. ED costs were significantly less (p<0.02) for the intervention. However, physician, hospitalization and total costs did not significantly differ between groups. ^147^
Cambach et al. ^148^ | To determine the differences in efficacy between a pulmonary rehabilitation program within local physiotherapy practices, that include drug treatment and a control condition of drug treatment only. | Adult patients with asthma aged 18–75 years old in the Netherlands. N_int-pre_=22, mean age: 40 yrs.; N_con-pre_=21, mean age: 53 yrs. | RCT | Within an outpatient specialty care setting, a nurse conducted more than 10 interactive group sessions that comprised techniques of breathing retraining and evacuation of mucus, exercise training (both for lower and upper extremities), patient education, relaxation techniques and recreational activities. | 6 months after the intervention, subjects had greater exercise tolerance and 6 minute walk times (p<0.05). There was no significant difference in QOL between the groups. ^148^
Cowan et al. ^134^ | To determine the effects of a regional asthma education center run principally by nurses on reducing asthma related morbidity and improving the quality of prescribing. | Asthma patients aged 5–45 years living in 2 regions of Quebec referred by their physicians. N_int_=8,835; N_con_=19,200. | CBA | Patients were referred to the asthma teaching program for 2 sessions in which they received teaching from a nurse on disease mechanisms, triggers and inhaler techniques. Printed or audiovisual materials were also distributed to participants. | No difference between groups in ED visits or medication use. ^134^
Delaronde et al. ^149^ | To identify and educate members of a regional managed care organization in the U.S. who were not using asthma medications as recommended by the NHLBI by means of a nurse-administered 6-month telephonic case management intervention. | 134 patients with asthma aged 13–65 years who were not using asthma medications as recommended by the NHLBI. N_con_=67, N_int_=67. | RCT | After an initial patient telephone assessment, a nurse provided monthly telephonic self-management education sessions for six months emphasizing knowledge of the disease process, having an action plan, and knowledge of national guidelines. Compliance with medication use, adherence to the physician-directed asthma management plan, PF monitoring, and trigger minimization and avoidance were assessed during these calls. Patients were also given individualized packets of educational materials. Control patients completed the Mini Asthma Quality of Life questionnaire at baseline and 12 months and were followed for the length of the study. | Six months after the intervention, no significant differences were found between the intervention and control groups in ED visits, hospitalizations, or QOL. When fully adjusted for age and pre-intervention asthma medication index, a significant improvement in dispensed medications (p=0.04) for the intervention group when compared to the control group was noted. ^149^
Donaghy et al. ^150^ and Mulloy et al. ^151^ | To assess the effectiveness of a structured asthma nurse specialist education intervention. | 46 patients with asthma aged 13–50 years in Ireland. N_int_=18, mean age: 26.2 yrs., N_con_=28, mean age: 30.7 yrs. | RCT | Within an outpatient specialty care setting, a nurse specialist interviewed patients on asthma technique, reviewed a distributed asthma booklet, and conducted an individual 1-hour asthma action program. Control subjects received usual care. | At one month after the intervention, the intervention group had somewhat better inhaler use (on 2 of 3 measures of inhaler use) than controls. There as no difference in FEV_1_ or PF. ^150,^ ^151^
Garrett et al. ^152,^ ^153^ | To determine the efficacy of establishing a community asthma education center. | 747 patients aged 2–55 years who had received asthma care in the ED in South Auckland. | CBA | 2 nurse specialists and a group of respiratory physicians established a community education center run by a nurse and 3 community health workers. The purpose of the education program provided was to educate patients in basic pathophysiology, define and teach trigger avoidance, medications use, inhaler technique and self-management skills (emphasis on PF recordings and symptom diaries), and teach how best to access medical care in response to worsening symptoms. | At nine months, the intervention group was more likely to have preventive medications, PF meters and better PF meter technique, more self-management plans, better knowledge of appropriate action to take when confronted with worsening asthma, less nocturnal awakening, and better self-reported asthma control than the control group. There was no difference between intervention and study patients in medication compliance, hospital admissions, days lost from school or work, ED visits, QOL, or smoking rates (33% for control group and 34% for the intervention group). ^152^
Hayward ^154^ | To assess whether asthma self-management and education improves patient recognition of asthma episodes resulting in improved self-treatment. | 42 ages 6–74 at a single practice in the U.K. N_con_=19, N_int_=23. | RCT | Patients in the intervention group attended a clinic run by asthma nurse or were telephoned monthly by the nurse for one year. Patients were taught danger signs of worsening asthma and how to react appropriately by increasing medication or seeking medical help. Self-management was based on PF monitoring, and inhaler technique was addressed. The control group received no training or information from the nurse. | After 12 months, the intervention group showed a significant improvement in the number of patients with successful self management (divided by number of asthma exacerbations; p<0.05) as compared to the control group. There were no significant differences between the control and intervention group in the number of episodes, symptom scores, or number of days absent from school or work. ^154^
Heard et al. ^155^ | To test whether asthma clinics (intervention) were more effective in reducing morbidity from asthma than standard medical treatment (control). | 195 asthma patients between the aged 5–64 years in Australia. | RCT | Each participating practice operated one 3-hour asthma clinic (run by trained nurses) once a week, which were. Clinic sessions involved education in asthma management strategies, written asthma management plans, spirometry and PF instruction, and an asthma diary card. Sessions ended with a consultation with the general practitioner. Patients were asked to attend 3 sessions within the 6 month study interval. | At the end of the study, patients in the intervention group were more likely to own a PF meter and to be smokers than those in the control group. Intervention patients were less likely to wake at least weekly at night due to asthma than control patients. There were no differences in reported time lost from work or school, having an action plan, use of medications, or health services utilization between intervention and control patients. Baseline smoking rates of 9% in the control group and 12% in the intervention group did not change. ^155^
Janson et al. ^156^ | To assess the effects of individual self-management education on adherence to medication, airway inflammation, and clinical outcomes. | 65 adults (age 18–55) with mild to moderate persistent asthma from clinics in the San Francisco Bay area. N_con_=32, N_int_=33. | RCT | All patients participated in a 1-week run-in to collect baseline data. Then patients were randomized. The intervention group received a 30- min individual education from an advanced practice nurse from the asthma education components provided by the National Institutes of Health guidelines. Additionally, inhaler and PF technique were assessed and corrected, and patients were given self-management plans based on PF zones. Follow up visits occurred with the study coordinator biweekly after the education session to reinforce the information covered. All patients kept asthma diaries. The control group had the same number of study visits of the same duration; however, these visits focused on collecting diaries and collecting data. | After 7 weeks, there was significantly higher adherence to inhaled corticosteroids (p=0.01), improved inhaler technique (p=0.01), and numbers of patients making positive environmental control changes (p=0.03) in the intervention group compared to the control. However, there were no between-group differences in symptom severity, the use of β-agonists, FEV_1_, morning PF, QOL, the use of inhaled steroids regularly at prescribed dose, or monitoring PF regularly. ^156^
Levy et al. ^157^ | To determine whether patient education by hospital based specialist asthma nurses using guided self-management plans could improve patient recognition and self-treatment of asthma. | Patients with asthma over age 18 years in London. N_int_=103, mean age: 43 yrs., SE: 2. N_con_=108, mean age: 40 yrs., SE: 2. | RCT | Patients were educated on recognition and self-treatment on asthma, assessed on PF meter use and inhaler technique, and provided a validated, guided self-management credit card plan. Educational intervention was provided in one 1-hour session, followed by two 30-minute sessions with a nurse specialist (either in person or on the phone) | The intervention group reported increased use of inhaled steroids during asthma attacks and had fewer visits to their physicians than control patients. No difference in asthma symptoms, days lost from work, or QOL between groups. ^157^
Pilotto et al. ^158^ | To assess the ability of nurse-run asthma clinics based in general practice compared with usual medical care to produce at least a moderate improvement in the QOL in adults with asthma | 153 patients with asthma over the age of 18 from general practices in Australia. N_con_=82, N_int_=71. | RCT | Two respiratory nurses conducted asthma clinics where baseline data was collected, a review of and instruction about inhaler technique was provided, and a packet of information was distributed to each patient. Follow up visits were scheduled at 2 weeks, 3, 6, and 9 months to review inhaler technique and answer questions. Control patients received usual care by their general practitioner. | After 9 months, no significant differences between the intervention and control groups in QOL scores, FEV_1_, ED visits, clinic visits or hospitalizations. However, significantly less people in the intervention group compared to the control missed one or more days of work (p=0.004). ^158^
Schott-Baer and Christensen ^135^ | To determine the effects of an asthma patient education program utilizing self-monitoring on patient self-care behaviors. | 36 patients with asthma aged 24–74 years from two Midwest ambulatory care clinics. N_con_=19, N_int_=17. | RCT | The intervention consisted of a 3-hour instruction program covering the disease process, daily self-monitoring, self-management techniques and daily log completion (diary). A series of 3 phone calls was made between the time of the intervention and the end of the study to reinforce use of the diary. Patients in the control group received standard care, including information and asthma, prescribed medications and instructions on how to record PF measurements. | After 6 weeks, no significant differences were found between the intervention and control groups in ED or clinic visits and no significant difference in recorded PF measurements. ^135^
Smith et al. ^141^ | To determine the effectiveness, in terms of symptom control and QOL, of a psycho-educational program compared to routine care. | 84 patients with severe asthma considered to be poorly adherent to their management program in the U.K. N_con_=42, N_int_=42. | RCT | Intervention subjects received a 6 month psycho-educational program of home visits and telephone calls from a supervised respiratory nurse specialist. For two months, this included four bi-weekly educational visits, supplemented by brief bi-weekly telephone calls between visits. For four months thereafter, this included monthly telephone calls. Control patients received usual care. | Six months after the intervention, there were no significant differences between the control and intervention groups in symptom control, physical functioning, adherence with PF monitoring, amount of medication used or QOL. When adjusted for major baseline score differences, at 12 months, asthma-specific QOL a significant improvement (p=0.03). ^141^
Wilson et al. ^136^ | To evaluate cognitive, behavioral, and clinical effects for individual and group asthma education programs. | 235 patients ages 18–50 with moderate to severe asthma from five Northern California Kaiser Medical Centers. N_con_=71, N_con-info_=75, N_group-ed_=83, N_ind-ed_=81. | RCT | There were four arms to this study. Patients enrolled in the small group education program met weekly with a nurse-educator for four 90-minute education sessions for instruction in asthma and asthma management. The intervention was designed on cognitive learning theory and utilized both verbal and printed instruction materials. Patients enrolled in the individual education program met weekly with the nurse-educator for three to five 45-minute meetings where the educator chose among 18 instructional modules (covering the same content included in the small-group program) to develop a program tailored to the needs of the individual. Intervention patients kept symptom-medication diaries. The standard control group was given no formal education. An information control group was given a workbook containing the same basic information given to the intervention groups. | At 12 months, patients in the group education program showed significant improvements in symptoms (vs. controls), symptom free days (vs. usual control), physician assessment (vs. usual control or individualized group education), physical activity (vs. usual control), bedroom environmental control practices (vs. controls) and MDI technique (vs. controls) (p<0.05 for all comparisons). The individualized group education had significant improvements in symptoms (vs. controls), symptom free days (vs. usual control), bedroom environmental control practices (vs. controls) and MDI technique (vs. controls) (p<0.05 for all comparisons). The information control (workbook) group showed significant improvement in symptom free days (vs. usual control) and physician assessment (vs. usual control or individualized group education) (p<0.05 for all comparisons). No significant difference in FEV_1_ values, hospitalizations, medication usage, smoking status or allergen reduction was noted between groups. Ad hoc pair wise testing revealed a significant reduction in acute asthma visits (p<0.05) for the group education (vs. all other conditions). ^136^

Note: ED=emergency department; PF=peak flow; QOL=quality of life; CBA=controlled before-after trial.

The median duration of the follow up period was 11 months (S.D., 9.2 months). The median sample size of these interventions was 100 subjects (Interquartile range: 51, 187). Sixty-three were RCTs, two were quasi-RCTs, and 13 were controlled before-after trials. In univariate analysis, the longest studies were more likely to report a statistically significant improvement in emergency department visits (p=0.02) but not the other outcomes.

Intervention Characteristics. These educational interventions were highly heterogeneous with respect to the content of the education, the provider of the education, the setting in which the education was provided, and the intensity of the education. Some interventions included multimedia tools, others used one-on-one formal teaching sessions, and several include instructional booklets.

Of the self-monitoring, self-management, or patient education studies, 24 (31%) specifically described an underlying conceptual framework or theoretical background as the basis for the intervention—a considerably lower proportion than for pediatric interventions of this type (62%). The controlled before-after studies were somewhat more likely to report a conceptual or theoretical foundation (38%) than RCTs (27%) (p=0.01).

Compared to the pediatric educational interventions, the educational interventions for general populations or adults were less like to be based in primary care clinics (28% versus 17%) and more likely to be based in outpatient specialty clinics (e.g., allergy or pulmonary clinics) (12% versus 30%) (Figure 5 and Figure 13). Most interventions for general populations or adults were taught by nurses/nurse practitioners or physicians (Figure 13).

Figure 13. Intervention characteristics: setting and educator type

Thirty-three (42%) of the self-monitoring, self-management, or patient education interventions provided two to five educational sessions. Twenty-seven interventions principally provided individualized instruction, three principally used interactive group teaching sessions, and 27 used combinations of teaching modalities (Figure 14). Five interventions included a computer/web-based component—the use of these technologies was not associated with statistically significant improvements in outcomes or processes of care for general populations or adults with asthma.

Figure 14. Number of educational sessions provided by educational strategy

Outcomes Reported. The 78 self-monitoring, self-management, or patient education studies' most frequently reported outcomes were asthma symptoms, urgent care or emergency department visits and hospitalizations due to asthma, and amount of asthma medications used (Table 17). The 42 studies that reported on asthma symptoms were highly heterogeneous—some presented self reported symptoms from patient diaries whereas others evaluated physicians' ratings of asthma symptoms. Similarly, the studies reporting on medication use sometime reported frequency of inhaled β-agonist use per patient whereas others reported the number of prescriptions for oral corticosteroids for the intervention group over the study interval.

Table 17 Outcomes reported by the adult self-monitoring, self-management, or patient education studies

Outcomes | Number of studies reporting no difference between intervention and control subjects (%) | Number of studies reporting improvement among intervention compared with control subjects (%)* | Number of studies reporting this outcome
Clinical status measures^§^ | 34 (52) | 31 (48) | 65
Asthma symptoms | 23 (55) | 19 (45) | 42
Symptom-free days | 6 (67) | 3 (33) | 9
Amount of medication used or prescribed | 21 (60) | 14 (40) | 35
Number of asthma attacks | 6 (86) | 1 (14) | 7
Pulmonary function from peak flow, FEV_1_, or other spirometric measures | 30 (73) | 11 (27) | 41
Functional status measures | 26 (76) | 7 (21) | 34^¶^
Activity restriction | 10 (77) | 3 (23) | 13
Days lost from school/work | 19 (79) | 4 (16) | 24^¶^
Health services utilization | 32 (71) | 13 (29) | 45
ED/urgent care visits | 21 (68) | 10 (32) | 31
Hospitalizations | 30 (83) | 6 (17) | 36
Office visits | 13 (93) | 1 (7) | 14
Guideline adherence | 14 (35) | 26 (65) | 40
Adherence with PF monitoring | 7 (70) | 3 (30) | 10
Use of self-management or action plans | 8 (62) | 5 (38) | 13
Inhaler technique | 6 (43) | 8 (57) | 14
Appropriate use of asthma medications | 9 (47) | 10 (53) | 19

Note: ED=emergency department; PF=peak flow. In this table we present data from all studies of pediatric self-monitoring or self management or patient education, including the studies which compared two or more groups without a control arm that did not also receive a QI strategy.

§ For each of the categories of outcomes highlighted in bold (e.g., clinical status measures, functional status measures), we recorded whether the study reported one or more statistically significant changes between the intervention and control group at the end of the study period in any of the individual metrics associated with that outcome category.

¶ One study reported worsened functional status (specifically increased rates of days lost from work/school) for the intervention group compared to the control group.

Interventions Led Principally by Nurses and Pharmacists. 21 interventions relied primarily on nurses to deliver the self-monitoring or self-management program (Table 18a). (Note: many other studies used a combination of physicians, nurses, and other health providers to work in concert to provide various elements of the educational materials—the interventions described in this section were led exclusively or primarily by nurses.) Six of these compared two or more intervention groups without a control that did not also receive a QI intervention (presented in Table 21). ^126^ – ^132^ Several of the nurse-led interventions lacked key characteristics that would seem predictive of being able to produce and detect statistically significant improvements for patients: only five reported basing their educational intervention on a theoretical or conceptual framework ^131^ – ^136^ and seven had sample sizes of 65 subjects or less.

Notable among the interventions in this category for its rigorous design, sample size, duration, intensity of educational program provided, duration, and reporting is the study by Wilson et al. ^136^ This RCT with four arms enrolled 235 patients aged 18–50 with moderate to severe asthma from five Northern California Kaiser Medical Centers. Patients enrolled in the small group education program (N=83) met weekly with a nurse-educator for four 90-minute education sessions for instruction in asthma and asthma management. The intervention was designed based on cognitive learning theory and utilized both verbal and printed instruction materials. Patients enrolled in the individual education program (N=81) met weekly with the nurse-educator for three to five 45-minute meetings where the educator chose among 18 instructional modules (covering the same content included in the small-group program) to develop a program tailored to the needs of the individual. Intervention patients kept symptom-medication diaries. The standard control group (N=71) was given no formal education. An information control group (N=75) was given a workbook containing the same basic information given to the intervention groups. At 12 months, patients in both the group and individualized educational programs were significantly more likely than controls to improve in multiple outcomes (p<0.05 for all comparisons) including asthma symptoms (55% and 50%, respectively compared to 25% in control group), symptom free days (49% and 51%, respectively compared to 26% in the control group), and bedroom control practices (62% and 53%, respectively compared to 32% in the control group). (See Table 18a for more details on this study.)

Table 18b presents the six education interventions led principally by pharmacists. All of these studies reported finding statistically significant improvements in processes or outcomes of care for general populations or adults with asthma. As a group, these interventions had relatively more frequent interactions with patients than other educational interventions—for example, the brief (3 month) study by Barbanel and colleagues provided patients with an initial individualized session followed by weekly calls from a pharmacist to review medications for the next three months. ^137^ Similarly, the large study (N=413) by Herborg and colleagues required monthly sessions for patients and their pharmacists for a year. Because of the small number of studies of this category, we did not have sufficient power to assess whether the frequency of patient interactions was consistently associated with the positive outcomes reported among the educational interventions led by pharmacists.

Table 18b Summary of adult self-monitoring, self-management, or patient education interventions provided by pharmacists

Reference | Study Purpose | Target Population | Study Design | Type of Intervention | Results
Barbanel et al. ^137^ | To evaluate whether a community pharmacist with basic asthma training could improve asthma control by providing self-management advice. | 23 adults aged 18–65 years with asthma living in inner city East London. N_int_=12, N_con_=11. | RCT | Intervention patients received a 45–60 minute individual session from the pharmacist on asthma pathophysiology, recognition and avoidance of triggers, inhaler technique, self-management skills including symptom and PF monitoring, actions in response to worsening symptoms, accessing emergency care, and smoking cessation, if relevant. They received written self-management plans and weekly phone calls for the next 3 months to review plans and answer questions. | 3 months after the intervention, the symptom score increased in the control group and decreased in the intervention group (p<0.001). ^137^
Cordina et al. ^159^ | To examine the effects of a community pharmacy-based education and monitoring program for patients with asthma on a range of patient-specific asthma management outcomes. | 152 patients over the age of 14 who received their asthma prescriptions at private pharmacies in Malta. | CBA | A comprehensive asthma education and monitoring program was instituted in private pharmacies in Malta for 12 months. The intervention pharmacists reviewed patients asthma symptoms, PF records, medication use, and when necessary suggested changes in treatment to the patient's physician. | There was no significant difference between treatment and control groups in terms of PF measurement, self-reported inhaler use, days lost from work or school, or health related QOL. There were fewer self-reported hospitalizations for asthma among intervention patients (0/86) than among control patients (8/66) (p<0.002) but no other differences in health services utilization. The intervention patients were less likely to report nighttime wheezing and more likely to improve their inhaler technique than control patients. ^159^
Herborg et al. ^160^ | To evaluate the effects of the “Danish Therapeutic Outcomes Monitoring” program of increased pharmaceutical care on various outcome and process measures of asthma care. | 413 patients aged of 16–60 years old with moderate-to-severe asthma in Denmark cared for in 16 intervention and 15 control pharmacies. N_int_=209, mean age: 38.8 yrs. N_con_=204, mean age: 42.4 yrs | CBA | The program consists of 7 steps for establishing a patient-pharmacist-physician relationship, collecting patient data, identifying and analyzing drug therapy problems, outlining therapeutic goals, choosing individual intervention and monitoring plan, implementing monitoring and follow up, and documenting and reporting to physician and patient. The intervention required monthly sessions with pharmacists over 1 year. | 12 months after the intervention, the intervention group had fewer “sick days,” fewer physician visits (p<0.012), and improved asthma symptoms, inhaler technique (p<0.001), health-related QOL (p<0.05), and knowledge of asthma medications (p<0.031). There was no difference in PFs. ^160^
Kelso et al. ^161,^ ^162^ | To determine if a comprehensive long-term management program, emphasizing inhaled corticosteroids and patient education would improve outcomes in African-American adults with asthma. | 39 African-Americans aged ≥18 years with moderate to severe asthma with recent ED visits or hospitalizations for asthma in Memphis. A control group comparable for all demographic variables was identified via chart review at local hospitals. N_con_=18, N_int_=21. | CBA | The intervention subjects received 1-hour individual asthma education session from a pharmacist emphasizing environmental control and PF meter and inhaler use. Patients were also given the NIH National Asthma Education Program booklet, individualized inhaled corticosteroid prescriptions, albuterol to use “as needed,” and an emergency supply of prednisone. Patients were given PF meters and taught how to use their medications in relation to their PF. The intervention utilized the strategies of role-playing and the distribution of printed or audiovisual materials. Free access to an asthma clinic was provided and an appointment was scheduled within 1 week of their ED visit. | At two years, the intervention group showed a significantly greater reduction in both ED visits (p<0.05) and (p<0.05) hospitalization compared to the control group. ^161^
Knoell et al. ^163^ | To compare an education program provided by a pharmacist with treatment by a pulmonologist to pulmonologist treatment alone. | 100 asthma patients in Ohio N_int-pre_=45, Age: 8.9% <25 yrs.; 82.2% 25–65 yrs.; 8.9% >/=65.N_con-pre_=55, Age: 14.5% <25 yrs.; 74.6% 25–65 yrs.;10.9% >/=65. | CBA | Pharmacist developed and implemented individualized education/self-management programs. Within an outpatient specialty care setting, a pharmacist spent 30–60minutes with a patient during the first visit, and had at least one more meeting with the patient over the course of 45-day study. Pharmacist also conferred and coordinated care with a pulmonologist. | The intervention group was more likely to have recorded a recent PF than control subjects. No differences in days missed from work, hospitalization, QOL, drug costs, or physician visits. ^163^
Schulz et al. ^164^ | To determine if a pharmacy-based patient education intervention can improve measures of lung function, HRQOL and self-management in asthma patients. | 164 asthma patients in Hamburg. N_int_=101 (34.6% M), mean age: 46.3 yrs., SD: 11.4. N_con_=63 (57.4% M), mean age: 45.9 yrs., SD: 12.5. | CBA | Pharmacists and patients met at 6-week intervals for a total of 9 meetings in 12 months. The study pharmacists were trained to detect and teach patients about inhaler technique, adverse drug reactions, adherence, drug interactions, and the need for additional therapy. | At 12 months post-intervention, there was no difference in FEV_1_ or physician rated asthma severity, although patient-rated asthma symptoms were improved in experimental subjects compared to controls. The intervention group had significantly higher overall QOL scores (p=0.02), but there was no difference between the groups in SF-36 mental summary score. 23% of the total population were current smokers and an additional 25% were ex-smokers. No change in smoking rates. ^164^

Note: ED=emergency department; PF=peak flow; QOL=quality of life; CBA=controlled before-after trial.

Other General Population or Adult Self-Monitoring, Self-Management, or Patient Education Interventions. The 33 studies in Table 18c evaluated a broad range of interventions. Among these, the factor most consistently associated with improvements in outcomes for patients was the use of combinations of educational techniques and materials including individualized interactions, group interactions, role-playing, and printed materials among others. Twenty-three of the 27 (85%) self-monitoring, self-management, or patient education interventions for adults that utilized combinations of educational modalities found statistically significant improvements in processes and outcomes of care for patients. In contrast, the interventions that utilized principally a single educational modality were less likely to report statistically significant outcomes: 70% (19/27) of the interventions that exclusively used individualized education, 66% (2/3) of interventions that exclusively used lectures, 33% (2/6) of interventions that exclusively used printed materials, and 33% (1/3) of interventions that exclusively used interactive groups found improvements for patients.

Table 18c Summary of other self-monitoring, self-management, or patient education interventions directed at adults with asthma

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Allen et al. ^165^ | To assess the effects on morbidity and medication compliance of a self-management asthma education program for adults. | 113 patients aged 18–65 years with moderate to severe asthma in Australia. N_con_=57, N_int_=56. | RCT | Intervention consisted of four 2.5-hour weekly self-management small group education sessions led by asthma educators supplemented by audiovisual, lectures, and written materials. The program focused on improving patient self-management through understanding of asthma physiology, identification and control of triggers, recognition of symptoms and symptom severity, medications, lifestyle and psychosocial factors, inhaler and PF meter use. Patients in the control group kept daily diary records for four weeks corresponding to the period of the education program for the intervention group. | After 12 months, significantly more patients were found to be compliant with their medication (p=0.02) in the intervention group when compared to the control group. No significant differences were found between the two groups in number of days of activity restriction, percentage of days or nights with asthma symptoms, percentage reporting PFR <70% expected, or FEV_1_/FVC. ^165^
Bailey et al. ^166^ ; Windsor et al. ^167^ | To investigate the effects of an asthma intervention program on poor self-management practices. | 225 patients over the age of 18 with mild to severe asthma recruited from the UAB Pulmonary Medicine Clinic. N_con_=101, N_int_=124. | RCT | The “UAB Asthma Self-management Program” consisted of a skill-oriented self-help workbook, an individualized counseling session with a self-help educator that lasted approximately 1 hour and focused on the use of the self-care workbook, proper use of medications, self-monitoring and self-evaluation techniques, early detection of attacks including the use of a PF meter, and attack management. Patients also participated in a small group support group and were followed-up via telephone every 2–4 weeks. Patients in the control group received usual care that included a standard set of asthma pamphlets. | After 12 months, there were no significant differences in outcomes between the intervention and control groups. However, when data were fully adjusted to account for baseline scores, there were improvements in inhaler use, symptoms, and ED visits, hospitalizations ^166^ , and medication adherence. ^167^ At baseline, 11.5% of the asthma patients smoked. No report of change in tobacco use. ^167^ The intervention program cost $32.03 per patient versus the control program, which cost $3.61 per patient. ^167^
Bailey et al. ^168^ | To develop and evaluate the effectiveness of less-resource-intensive self-management programs that may be more appropriate for non-academic healthcare settings. | 232 patients with moderate to severe asthma from a single pulmonary clinic in Alabama. N_con_=78, N_ASMP_=78, N_core-element_=76. | RCT | The “UAB Asthma Self-management Program,” patients were given the same program as described above. Patients also received two follow up calls to discuss any problems and letters encouraging follow up were mailed at 1, 2, and 4 weeks post counseling session. The “UAB Core-Elements Program” group was given a revised, shortened workbook which was reviewed during a brief 15–20 minute one-on-one counseling session. Patients in this group were also trained in the use of inhalers and PF meters. A follow up telephone counseling session was conducted one week later to review the patient's medication regimen and inhaler and PF meter skills. Patients were sent a follow up letter two weeks later. The usual-care group received standard treatment from their physician and were given a standardized set of pamphlets. | After 24 months, there were no significant differences in either intervention group when compared to the control group in medication or inhaler adherence, asthma symptoms, functional impairment or the need for health-care services including ED visits or hospitalizations. ^168^
Catov et al. ^142^ | To evaluate the effects of a home-based teaching on reducing asthma admissions and ED visits. | 381 Medicaid-insured patients in Pennsylvania aged 2–56 years with one or more hospitalizations or three or more ED visits with a primary diagnosis of asthma N_con_=290, N_int_=91. | CBA | Patients in the intervention group received at least 3 home visits over 2 months by a respiratory therapist who assessed the home environment for asthma triggers, conducted intensive education about asthma and self-management, including the use of a PF meter, and worked with the patient's physician to complete an asthma action plan. Patients who were eligible for home visits, but who declined or were unable to be located served as the control group. | Two study designs were used: “one-group pre/post-test design” and “untreated control group design with pre/post test.” The following results are for the more intensive “untreated control group design with pre/post test” design: after 12 months, no significant differences were found between the intervention and control group in ED visits or hospitalizations. ^142^
Couturaud et al. ^169^ | To assess the effects of an educational program in patients with asthma following treatment readjustment. | 54 adult patients with moderate to severe asthma seen at the outpatient clinic of two university hospitals in France. N_con_=28, N_int_=26. | RCT | All patients underwent an initial two-week run-in period and treatment readjustment if necessary. All patients were taught how to measure PF, and after the run-in all patients received asthma diary cards. Additionally, patients in the intervention group received 5 individual self-management educational sessions after each scheduled visit to the general practitioner (at 1,3, 6, 9, and 12 months) which included information on asthma, asthma triggers, asthma medications and the proper use of inhaler devices, and detection of asthma flare-ups and self-management strategy. The intervention provided to the control group was not described. | After 12 months, there was no significant difference between the groups in percentages of symptom-free days and days off work, unscheduled visits, FEV_1_ (% predicted), QOL, medication compliance, or use of self-management action plans. However, there was a patients in the education group reported a significantly higher percentage of days of oral steroid intake compared to the control group(p=0.01). ^169^
de Oliveira et al. ^170^ | To assess the effectiveness of population-based asthma management intervention especially tailored for deprived low-income populations of poor social and cultural backgrounds in Brazil. | 43 asthma patients. N_int_=22, mean age: 41 yrs. N_con_=21, mean age: 38 yrs. | RCT | Study subjects received monthly instruction over a 6-month period. The education was given by a physician and consisted of inhaler use training, information about environmental control and triggers and early recognition of warning signs of asthma. Instructional tools included posters, discussion sessions or video presentation, reading materials and diary cards. | After the 6 month intervention, intervention patients had fewer ED visits (p=0.03), fewer asthma symptoms (p=0.04), better QOL (p=0.0005), and improved inhaler technique. However, there was no difference in hospital admissions or PF between groups. ^170^
Feifer et al. ^171^ | To determine whether a population-based asthma disease management program, using broad-based educational interventions can have favorable effects on physician and patient adherence to guidelines-based care. | 70,900 patients with asthma patients aged 5–45 years using a specific prescription benefit plan in the U.S. 35,450 patients were in each group. | CBA | During the 12-months following enrollment, intervention patients and their physicians received educational materials. Patients in the intervention group received five workbooks and two newsletters. Educational materials emphasized guideline-based elements of asthma pharmacotherapy, self-management techniques, and trigger avoidance. Additionally, patients received refill reminders, prospective compliance reminders, and pollen count alerts by mail. Physicians received asthma management flow sheets to facilitate the tracking and review of patients' therapy. Patients in the control group received no educational materials, nor did their health-care providers. | All outcomes were measured as the change between baseline and 12 months after enrollment. The percentage of patients using controller therapy decreased less in the intervention group (p<0.0001), controller prescription refill rate increased in the intervention group (p<0.0001), and reliever prescription refills were reduced in the intervention group (p<0.001) compared to the control group. ^171^
Gallefoss et al. ^172^ – ^175^ | To evaluate the effects of patient education on patients with mild to moderate asthma and COPD patients. | 71 patients aged 18–70 years with mild to moderate asthma from a single clinic in Norway. N_con_=39, N_int_=32. | RCT^§^ | Patients attended two group sessions for asthma patients in an outpatient specialty care clinic (one led by a physician in which self care, basic physiology, and prevention of attacks was described and one led by a pharmacist who reviewed asthma drugs) and one or two individual sessions with nurses and physiotherapists in which individualized care plans were developed. Patient received a 19-page booklet with on asthma, compliance, medication, self-care, and self-management plans. | At 1 year, intervention patients had fewer asthma symptoms (p<0.05), better health related QOL (p<0.001), improved FEV_1_ (p<0.05) ^172^ , and higher steroid inhaler compliance (p=0.04) ^173^ compared to control patients (p<0.05). More patients in the intervention group reported they had symptom free days (p=0.001) and nights (p=0.001) and that asthma had no effect on daily life (p=0.02). ^174^ There was no significant difference found between the groups in dispensing of β-agonists, courses of oral steroids, ^173^ activity limitation, ^172^ hospitalizations, or absenteeism from work. ^175^ There was no significant difference found between the groups in direct costs, indirect costs, and total costs associated with the program. ^174^
Ghosh et al. ^176^ | To assess the effects of asthma self management training on the health status and resource use of patients with chronic asthma. | 176 patients aged 10–45 with chronic asthma who attended the asthma and allergy clinic in the Department of Respiratory Medicine at the Medical College in Trivandrum, India. N_con_=136, N_int_=140. | RCT | The intervention consisted of four 2-hour group sessions of asthma self-management education and training during the first month following baseline assessment. Patients in the intervention group were taught to adjust treatment based on severity, which was assessed by PF monitoring and early symptoms. They also kept daily diary recordings of outcome variables including PF values, symptom assessments, and hospitalizations or ED visits. Audiovisual aides supplemented the 2-hour education sessions. The control group received usual care for asthma management including medication. | At 12 months, the intervention group had significantly higher PF values (p<.001) and fewer productive days lost (p=0.003), less hospitalizations (p=0.043), and fewer ED visits (p=0.002). There was a significantly less indirect (p=0.003) and total costs (p=0.036) associated with the intervention group, but no significant difference in direct costs found between the two groups. ^176^
Grover et al. ^139^ | To determine the efficacy of cognitive behavior therapy as an adjunct to standard pharmacotherapy in bronchial asthma. | 10 asthma patients 18–50 years old in Bangalore. N_int_=5; N_con_=5. | RCT | The intervention consisted of 15 individual sessions which covered asthma physiology, muscle relaxation, cognitive restructuring and coping skills and behavioral counseling to significant others. A health educator delivered education within an outpatient specialty care setting. | At the end of the intervention there was no difference in asthma symptoms between the two groups. ^139^
Hilton et al. ^177^ | To test the hypothesis that an improvement in knowledge of asthma and its treatments leads to a reduction in morbidity. | 274 patients with asthma aged 5–70 years cared for by 33 general practitioners in London. N_con_=100, N_ltd-int_=88, N_max-int_=86. | RCT | One group received a maximum education program, one group a limited education program, and the third was a control group. Both intervention groups received a booklet about asthma and a treatment card. The booklet contained information on basic mechanisms of asthma, trigger factors, types of treatment, modes of action and side-effects of anti-asthmatic drugs, and self management. The treatment card contained information on how the patient's drugs acted and whether they were for symptom relief or preventative. Subjects in the maximum intervention group also received a 10–15 minute interview with his/her doctors which covered the same topics as the booklet, a 35-minute audiocassette which expanded on information in the booklet, and follow up appointments every 3 months with the family doctor for a year. | After 12 months, there were no significant differences among the groups in self-management of attacks, drug compliance, inhaler technique, activity limitation, number of days absent from school/work, hospitalization, ED visits, wheezing, frequency of attacks, frequency or severity of nights disturbed by wheezing, incidence of severe attacks, or the proportion of patients who had their drug regimens changed. There was no difference in number of days absent from school or work; however, the mean number of times absent from school or work was significantly lower in the control group than in the intervention groups (p<0.05). ^177^
Hoskins et al. ^178^ | To determine whether self-management plans reduce morbidity from asthma. | General practitioners in the U.K. were randomized to either provide their asthma patients with self-management plans or to provide usual care. N_con_=151, N_int_=139. | RCT | General practitioners in the intervention group were “invited to issue self-management plans personally to those patients known to have suffered an asthma attack in the past 3 months. The control group were simply asked to identify patients” with asthma. ^178^ No additional information was provided about the intervention. | The unit of randomization and analysis differed and no adjustments were made for this difference. Six months after the intervention there were no differences in hospital admissions, ED visits, or office visits for asthma among patients of intervention and control physicians. ^178^
Jenkinson et al. ^179^ | To compare the effects of a patient education program presented in either booklet or audio cassette tape form. | 177 patients aged 3 to 49 years with asthma from 8 general practices in the U.K. N_con_=41, N_book_=46, N_tape_=46, N_book+tape_=44. | RCT | Patients were randomized to receive education via booklet, audiocassette tape, both booklet and audiocassette tape, or a control group. The booklet was 27 pages: 9 pages described the asthma pathophysiology and prevention measures; 12 pages explained the types and uses of drugs, “how to get the best from them,” and coping with asthma problems; and 6 pages covered what to do when things go wrong in 18 possible scenarios. The audiocassette tape was 34 minutes, half on asthma pathophysiology and the actions of drugs and half presented a conversation between a doctor answering questions from a patient with asthma dealing with a series of asthma related problems. | After 12 months, there were no differences among the groups in inhaler technique, quantities of drugs prescribed, medication use, rates of consultations for asthma, or “perceived disability.” ^179^
Johnson et al. ^180^ | To evaluate the effectiveness of a comprehensive asthma disease management program. | Patients with asthma covered by Anthem Blue Cross and Blue Shield insurance in the U.S. N_int_=196, N_con_=196. | CBA | The intervention lasted 12 months. Intervention subjects received teaching that emphasized self-management behaviors such as avoidance of triggers, correct medication use, recognizing symptoms, seeking medical advice, smoking cessation, and adherence to treatment plans. The program is supported by computer generated communications to providers and case managers regarding whether the patient has an action plan, received flu vaccination, has a rescue inhaler, and use of daily controller medications. | 12 months after the intervention, the intervention group had fewer ED visits (118 vs. 305, p<0.0001) and hospitalizations (39 vs. 114, p<0.0001). There were no differences in use of asthma medications or preventative vaccinations. ^180^
Kotses et al. ^144^ | To compare the effectiveness of personalized asthma self-management recommendations with that of a group self-management program. | 34 adults with mild to severe asthma in the Toledo, OH area. N_con_=12, N_int-group_=11, N_int-ind_=11. | RCT | This study evaluated 3 groups: individualized self-management, group self-management, and a control. The individualized self-management education program consisted of identification of each patient's asthma triggers in a 60-minute session which included the use of PF values as an early warning sign for asthma onset, methods for avoiding precipitants, and instructions for reducing asthma exacerbations (including, as warranted, progressive relaxation techniques). The group self-management education program was based on Wheezers Anonymous (WA) and included two 2.5-hour sessions with video and audio materials and discussions facilitated by a group leader. WA also included the use of PF monitoring. All patients in the intervention groups kept daily asthma diaries. The control group received usual care. | As compared to the control group, patients in both intervention groups had significantly more improvement in morning PF values (p<0.05) as measured against baseline. There were no significant differences among the groups in evening PF values, asthma attacks, activity limitations, or frequency of visits to the ED. ^144^
Lahdensuo et al. ^181,^ ^182^ | To compare the efficacy of an asthma self-management program with traditional treatment. | 115 patients aged 18yrs and older with mild to moderate asthma from 3 outpatient clinics in FinlandN_con_=59, N_int_=56. | RCT | Patients in the intervention group received a 2.5-hr personal self-management education session covering asthma, asthma medications, and the principles of self-management by specially trained nurses with 3 follow up visits at 4 month intervals. They also received physiotherapeutic counseling, including proper breathing and relaxation techniques by physiotherapists, were given guided self-management plans based on PF monitoring, and kept daily asthma diaries. Control patients received usual care. | After 12 months, there were significant differences between the intervention and control groups in the number of courses of antibiotics taken (p=0.008), courses of prednisolone (p=0.01), days off work (p=0.03). No significant differences between the groups were found for unscheduled office visits, hospitalizations, and spirometric values. QOL scores did show trends toward significance when fully adjusted for baseline scores. ^181^ The total direct costs were 649 Finnish Marks less in the control group than in the experimental group (p=0.05) ^182^ (At the time of publication: 8.84 Finnish Marks=1£).
Legorreta et al. ^138^ | To evaluate the effectiveness of a population-based asthma management program in an HMO setting. | 999 patients aged 5–65 years with moderate to severe asthma from a large HMO in California. N_con_=385, N_int_=614. | CBA | Patients in the intervention group received educational material (Asthma Control Kit) directly from the HMO designed to educate asthmatic patients in proper or self-management skills. The kit included a PF meter, an Asthma Review Guide, a personal diary, a spacer device, and an educational video. Patients in the control group did not receive any materials but completed baseline and follow up assessments. Due to low participation, results from a second intervention (a nurse-led small-group education program) was not included. | After 6 months, patients in the intervention group had significantly greater improvement with daily use of a steroid inhaler (p=0.003) and daily use of a PF meter (p=0.038). No significant differences were found between the groups in absenteeism due to asthma, ED visits or hospitalizations for asthma. ^138^
Marabini et al. ^183^ | To evaluate the effectiveness of a patient education program by a physician in reducing morbidity and improving QOL. | 77 asthma patients aged ≥ 18 years in Perugia, Italy. N_int_=37, mean age: 53.1 yrs., SD: 6.8. N_con_=40, mean age: 49.3 yrs., SD: 16.8. | RCT | Patients participated in an educational program based on “Teach Your patients About Asthma: A Clinician Guide” (NHLBI publication). The three 2-hour sessions conducted by a physician, covered basic information on asthma medications, use of inhalers and PF meters, identification of asthma-warning signs, avoidance of triggers, and development of action/emergency plans. Handouts covering key points were also distributed. Patients were also involved with decision-making and taught how to deal with symptoms early. | 3 months after the intervention, no differences in FEV_1_, PF, days lost from work or school, symptom-free days, rescue salbutamol use, or medication expenses. 10% of patients were current smokers and 30% were ex-smokers. No reported change in tobacco rates. However, the intervention group had significantly higher overall QOL compared to the control group (p<0.05). ^183^
Magar et al. ^184^ | To evaluate the effectiveness of a self-management program for adults with asthma. | Adults (18–60yrs) with asthma in France. Patients enrolled: N_con_=89, N_int_=104. | RCT | Intervention subjects received an individualized 30–60 minute interview to assess their educational needs and to discuss diary and PF meter use. Then they received two 2.5 hr interactive group sessions separated by 15 days that reviewed asthma signs, symptoms, pathophysiology, medication use, avoiding triggers, and self-monitoring using symptoms and PF results. Control subjects were asked to keep a symptom diary and received usual care. | At 12 months, the intervention group had greater reductions in symptom-free days per month, nighttime wakening, oral corticosteroids, and greater improvement in QOL scores ^184^ (p values difficult to interpret from the data provided). There was no significant difference in the rate of tobacco use (7% stopped smoking in the intervention group compared to 2% in the control, p=0.18). ^184^
Mayo et al. ^185^ | To determine the effect of an outpatient program designed to reduce readmissions for asthma exacerbations among adults with asthma. | 104 adult patients with asthma who had been hospitalized at a single hospital in New York. Patients had all had at least 2 hospitalizations in the previous 12 months or 5 ED visits in the previous 24 months. N_con_=57, N_int_=47. | RCT | Intervention subjects had 2 initial 1-hour visits with a physician or nurse practitioner for discussion of asthma pathophysiology and treatment emphasizing self-management strategies tailored to each patient. During subsequent visits (≥30minutes long with frequency determined by the patient preference and asthma severity), medical regimens were tailored to each patient's asthma pattern to encourage compliance. Patients were taught to use spacers and PF meters and to vary their own treatment according to symptoms, using a PF meter to identify attacks requiring prednisone. The control group received usual care. | After 8 months, mean hospital admissions and hospital days were significantly lower in the intervention group compared to the control group (p<0.004 and p<0.02, respectively). ^185^
Moldofsky et al. ^186^ | To determine whether a videotape program about asthma would be successful in transferring information about asthma. | 79 adult patients with asthma were recruited from the Gage Research Institute in Toronto. N_int_=149, mean age: 24.0 yrs., N_con_=160, mean age: 24.8 yrs. | RCT | The intervention group watched an educational videotape entitled “Living With your Asthma” consisting of a dialogue between a physician and a well-known professional hockey player who has had asthma all his life. The 55-minute program described the normal structure and function of the lungs, the physiological abnormalities in asthma, the management of asthma by self-care and drug therapy, and the approach to problems commonly encountered by persons with asthma. | No difference in frequency of visits to their physicians, FEV_1_, or hospitalizations. ^186^
Onyirimba et al. ^187^ | To determine the effectiveness of clinician-to-patient feedback of inhaled steroid use compared with standard asthma care. | 19 adults from low socioeconomic groups with moderate to severe asthma in Hartford, CT. N_int_=9, mean age: 45 yrs., N_con_=10, mean age: 53 yrs., SD:14. | RCT | Clinicians reviewed data from an instrument that electronically recorded inhaler use. This information was then discussed with the patient at a 4 weekly follow up visits, and suggestions were made about where to keep the inhaler based on when the non-adherence occurred. | During the 10-week study period, the intervention group had improved medication adherence rates than the control group (p<0.0001). No change in FEV_1_ or QOL between groups. ^187^
Perneger et al. ^188^ | To assess the effectiveness of a newly established education program designed to improve patients' health and functional status. | 115 adults with asthma at a single hospital in Geneva, Switzerland. N_con_=57, N_int_=58. | RCT | The interactive education program consisted of three 75-minute group education sessions scheduled one week apart and delivered by two respiratory physicians and a physiotherapist. Educational materials were also distributed. The primary purpose of the education methods was the design of individual self-management programs. Patients in the control group underwent a baseline evaluation, received “minimal asthma information,” and were scheduled for a 6-month follow up. | After 6 months, comparisons were made between the intervention and control groups for 40 outcome variables. Of these, only four variables varied significantly between the intervention and control groups. When adjusted for baseline data, an improvement was seen in inhaler technique in the intervention group compared to control (p=0.048). There were no significant differences between the groups in amount of medication used, work days missed, limitations on physical activity, ED visits, hospitalizations, PF values, or overall QOL. 20% of subjects were smokers and there was no significant decline in tobacco use at the end of the intervention. There was no correction made for multiple comparisons. ^188^
Put et al. ^189^ | To determine if an individualized education and cognitive-behavioral intervention would improve asthma-related behavior. | 25 asthma patients aged 18–65 years in Belgium. N_int_=13, mean age: 43 yrs., SD: 10. N_con_=12, mean age: 48 yrs., SD: 12. | RCT | Patients received a workbook with information, exercises, and homework assignments. During six 1-hour individual program sessions, different strategies were employed: psycho-education; behavioral techniques; self-observation/self-monitoring; stimulus control (change of behavior antecedents); response control (learns to select the appropriate behavior to avoid or minimize the influence of stimuli by considering behaviors short term vs. long term consequences); cognitive techniques. In addition, whenever problem areas, such as disease-specific anxiety, were identified, certain parts of the training program were elaborated. | 3 months after the intervention, there were no difference between groups in terms of PF during the day or night. However, QOL scores were significantly different between the intervention and control groups. The AQLQ scores were higher and the Negative Emotivity Scale were lower (p<0.001 and p<0.01, respectively). ^189^
Rasmussen et al. ^190^ | To assess the outcomes associated with an Internet-based asthma management tool. | 253 adults with asthma aged 18–45 years living in Denmark. N_cont-GP_=80, N_cont-sp_=88, N_int_=85 | RCT | There were three groups: an internet management group, a group receiving treatment from an asthma specialist, and a group receiving care from a general practitioner (GP). The Internet-based management tool was comprised of an electronic asthma diary, an action plan for patients, and a decision support system for physicians. Patients were given PF meters, and the Internet tool's action plan comprised a 3-color warning system with a written treatment plan. Patients were encouraged to fill out the diary daily and follow instructions given by the computer or physician. Physicians used the decision support system to follow up with patients on therapeutic changes. | After 6 months, the Internet group had significantly fewer asthma symptoms (p=0.002 compared to specialists; p<0.001 compared to GPs), higher QOL (p=0.03 compared to specialists, p=0.04 compared to GPs), and better FEV_1_ (p=0.002 compared to specialists, p<0.001 compared to GPs). The Internet group had significantly more acute, unscheduled visits compared to the two control groups (p=0.05). No significant differences among the groups were found in ED visits, hospitalizations, or medication compliance. ^190^
Ringsberg et al. ^191^ | To measure the effects of a multi-disciplinary asthma school in Sweden. | 38 adult asthma patients who had been treated in the hospital where the asthma school was located. N_int_=20, mean age: 49 yrs. N_con_=18, mean age: 45 yrs. | RCT | The intervention group was divided into 4 small sub-groups that were educated in an asthma school 4 times in the Spring, 2 times in September 1986, and 1 time in January 1987. Classes met once a week and emphasized information on elementary anatomy and physiology, how to prevent asthma attacks by avoiding triggers, drugs, and self-treatment techniques. | The decrease in number of days hospitalized was greater for the intervention group (83% vs. 74%, p=0.0001). No difference found in FEV_1_, leisure time activities, social interactions, or physical activities. ^191^
Schaffer and Tian ^192^ | To compare the effects of a theoretically focused audiotape or a standard educational booklet or both on adherence to asthma preventive medication. | 23 adult patients with asthma aged 18 to 65 years in the U.S.; N_int_=10; N_con_=13. | RCT | Patients received a 30-minute audiotape incorporating 5 topics critical to asthma self-management. Audiotapes included asthma-related lyrics set to popular tunes to enhance memory. Patients also received a 12-page booklet that covers the same topics as the audiotape but presents the content directly rather than as part of a larger narrative. | 6 months after the intervention, significant differences between groups were found in pharmacy adherence (p<0.05). There was no significant difference in QOL between the groups. ^192^
Snyder et al. ^143^ | To test the effectiveness of the Wheezers Anonymous program in teaching self-management skills to adults with asthma. | 75 adults (mean age 27yrs) with asthma from the Toledo, OH metropolitan area. (No report of the number of subjects allocated to treatment and control groups.) | RCT | The intervention group attended 2 two-hour group education sessions (8–12 patients) with 15- to 25-minute didactic videotaped presentations interspersed with 10- to 15- minute discussions led by a respiratory therapist who acted as a moderator for group discussion and for practice of the presented information and techniques. The sessions contained information on asthma self-management. In addition to answering questionnaires, patients kept an asthma diary and had their pulmonary function tested at 1, 2, and 3 months following intervention. The waiting list control group received usual care. | After 3 months, there was no significant group difference between the intervention and control in frequency of asthma attacks. ^143^
Sundberg et al. ^193^ | To assess the effectiveness of a computerized limited asthma education program designed to suit young people. | 147 patients with asthma aged 18–25 years who were referred to a special asthma outpatient clinic for young adults in Sweden. N_con_=49, N_int_=48. | RCT | Intervention consisted of an interactive 30-minute computer program that provided basic information on asthma, asthma medication use, inhaler and PF meter use, and information about asthma triggers and allergens. At the end of the program, an asthma-trained nurse led a structured discussion with each patient about his/her results. The control group received normal care, and all patients were followed up with the clinic team at 6 and 12 months. | After 12 months, no significant differences were found between the intervention and control groups in hospital admissions, ED visits, prevalence of respiratory symptoms, or QOL. However, a significant increase in FEV_1_ was observed in the intervention group compared to the control group (p=0.01). ^193^
Verver et al. ^125^ | To evaluate whether inhaler technique and respiratory symptoms of patients with asthma can be improved after instruction by a practice assistant. | 6 physicians assistants were trained in the appropriate use of powder inhalers and provided patient education to 48 Dutch asthma patients aged 15–85 years. | RCT | Patients received two training sessions (2 weeks apart) on the correct technique for use of dry powder inhalers (and the correct order in which to use multiple inhalers). | At baseline only 6% of all patients used the dry powder inhalers correctly. Most mistakes were made with the “breathe out” before inhaling and with the “hold your breath for 5 seconds” after inhaling instructions. There was no correlation between the number of inhaler errors and symptoms. The patients in the instruction group significantly reduced the number of inhaler use errors (p=0.01). There was no difference in reported asthma symptoms between the two groups. ^125^
Weng ^194^ | To evaluate the effects of a government sponsored QI intervention with patient and provider education and case management services for patients with asthma. | 1,067 patients with asthma enrolled in the program sponsored by the Taiwanese government. 4,340 patients with asthma who did not enroll in the program served as matched controls. | CBA | Providers received a 6-hour asthma curriculum that included conducting pulmonary function testing, use of medications and PF monitoring, environmental controls, and asthma pathophysiology. They were given copies of asthma clinical practice guidelines. Patients received individualized, personally tailored asthma education on recognizing triggers and symptoms, medication use, PF use, and self-monitoring self-management of exacerbations. Case managers (nurses or physician assistants) provided communication between patients, primary care physicians and specialists, and scheduled quarterly follow up. | 1 year after enrollment, the intervention group had longer hospital stays (by 40%, p=0.045) but no difference from control patients in the number of ED visits or number of hospitalizations. However, among patients newly diagnosed with asthma during the study interval, there was a decrease in ED visits (by 61%) in the intervention group compared to the controls. ^194^
Yilmaz and Akkaya ^195^ | To evaluate long-term efficacy of a patient education program in an asthma outpatient clinic in Istanbul. | 52 patients with asthma aged >16. N_int_=25, mean age: 330.6 yrs. N_con_=27, mean age: 28.9 yrs. | RCT | The educational program took place over a 12-month period and consisted of 6–10 sessions. Patients were provided education through video cassettes, special brochures, and seminars. Physicians checked patients' inhalation device and reviewed proper usage technique. A telephone help-line was available to the participants. | 3 years after the intervention, no difference in FEV_1_, asthma symptoms, ED visits, hospitalizations, or medication use. QOL scores were significantly higher in the intervention group compared to the control group (p=0.009). ^195^
Zeiger et al. ^196^ | To determine whether facilitated care provided by asthma specialists favorably affect asthma outcomes. | 309 asthma patients aged 6 to 59 with a recent ED visit or hospitalization for asthma years who were San Diego Kaiser Health Plan members. N_int_=149, N_con_=160. | QRCT^*^ | An expedited allergy-clinic evaluation was offered. Allergists provided detailed evaluation including history, physical examination, spirometry, inhalant skin tests, and a comprehensive treatment program, including instruction in relevant environmental control measures, asthma education, and individualized medication recommendations. No subject received immunotherapy during study. | 6 months after their index visit/hospitalization, the intervention group had improvement in asthma symptoms (p<0.00001), were more likely to use inhaled corticosteroids or inhaled cromolyn, and had fewer readmissions (p=0.017). There was no difference in absenteeism or spirometry. ^196^

* QRCT=quasi-randomized controlled trials. ED=emergency department; PF=peak flow; QOL=quality of life; CBA=controlled before-after trial; NHLBI=National Heart, Lung, and Blood Institute.

§ The design of the study by Gallefoss et al. ^172^ was as follows: Two groups of patients, those with asthma and those with COPD were randomly assigned to an intervention group who received an educational program and a control group who received usual care by their General Practitioners. The patients with asthma and COPD were educated separately. We present only the data for the asthma patients.

We did not find that the frequency of patient interactions with the provider of the educational intervention was a key factor in producing improvements for patients. Some interventions provided no direct interaction between healthcare providers but still found statistically significant improvements in patient outcomes (e.g., the study by Legorreta (one of the largest in this systematic review) involved 999 patients who received self-monitoring or self-management and educational materials including written materials, peak flow meters, and a video directly from their HMO, and were found to have improvement in daily use of steroid inhalers and PF meters ^138^ ). In contrast, other interventions provided intense interactions with patients but failed to produce or detect improvements for patients (e.g., the 10 patient study by Grover and colleagues in which patients received 15 individualized educational sessions ^139^ ).

Similarly, no particular intervention setting was consistently associated with improvements in outcomes. In contrast, three of the self-monitoring, self-management, or patient education studies were home-based and none found improvements in outcomes for patients. ^140^ – ^142^

Three of the included studies ^133,^ ^143,^ ^144^ based their self-management intervention on the Wheezers Anonymous program. Developed by Winder and colleagues, ^143,^ ^144^ Wheezers Anonymous was based on two effective self-monitoring or self-management programs for children (Living with Asthma ^145^ and the Family Asthma Program ^146^ ) and was designed to provide comprehensive asthma education and self-monitoring or self-management skills with minimal leader training for use in clinical settings (Table 18c). It uses a combination of teaching modalities including lectures, videotaped segments, and discussion sections. ^143^ The relatively small study by Kotses and colleagues, found improvements in peak flow measures among recipients of Wheezers Anonymous compared to control subjects. ^144^ However, the other studies did not report consistent improvement in clinical, functional, or health services utilization measures among recipients of Wheezers Anonymous compared to control subjects. ^133,^ ^143^

Conclusions. Self-monitoring, self-management, or patient education interventions can be effective for improving the processes and outcomes of care for adults with asthma. In particular, interventions that utilize combinations of educational modalities and those that rely on pharmacists to lead the educational effort have been associated with statistically significant improvements for patients.

#### Synthesis of Evidence From Self-Monitoring, Self-Management, or Patient Education Interventions for General Populations or Adults With Asthma

In this section we present the results of our evaluation of the association of study design characteristics (e.g., whether the authors specified a theoretical/conceptual framework, year of study, sample size, country), intervention characteristics (e.g., the number of educational sessions provided to students, the setting in which the intervention took place), and improvements in the outcomes of interest for the self-monitoring, self-management, or patient education interventions. We present our analyses according to each of the primary outcome types.

Clinical Outcomes. Sufficient numbers of studies presented results for percent predicted FEV_1_ and peak flow that these data could be synthesized quantitatively.

Percent predicted FEV _ 1 _. Among the self-monitoring, self-management, or patient education interventions for general populations or adults with asthma, 17 reported change in percent predicted FEV_1_ from which we were able to calculate individual study and a summary standardized mean difference (between intervention and control subjects at the end of the study) (Figure 17-see below). These studies were statistically homogeneous and produced a weighted mean difference of 2.92 percent change in FEV_1_ (95% CI: 0.92, 4.92; p=0.004). This corresponds to a summary mean difference of 0.13 (95% CI of 0.03, 0.23) favoring the intervention groups (p=0.01). The funnel plot from these 17 studies (Figure 15) does not suggest substantial publication bias. Of all the quantitative analyses in this report, the data included in this calculation are the most robust given the relatively large number of studies reporting the same outcome in the same way. However, the statistically significant effect reflects a clinical improvement of only borderline significance.

Figure 15. Funnel plot: FEV_1_ percent predicted

Figure 17. Self-monitoring, self-management, or patient education studies reporting percent of predicted FEV_1_

Note: The effect sizes presented here are the random effects standardized mean difference (SMD).

We sought study design and intervention characteristics associated with the greatest improvements in percent predicted FEV_1_. For this analysis, we used the standardized mean difference as the dependent variable in a weighted least squares regression. We found that the more recent the year of publication, the greater the likelihood of finding improvements in percent predicted FEV_1_ (p=0.004) (Table 19). We denoted the studies with interventions performed since 2000 in Figure 17 with an asterisk. We cannot determine the critical characteristics that distinguish these more recent studies and that might be associated with the improved spirometric measures.

Table 19 Association of study/intervention characteristics and improvements in FEV_1_ percent predicted

Predictor Variables | Regression Coefficients (SE) | P value
Model Constant | -23.6 (6.7) | 0.004
Intervention duration in months (continuous variable) | -0.0002 (0.001) | 0.8
Year of publication (continuous variable) | 0.01 (0.003) | 0.004
Studies that specified a theoretical/conceptual framework vs. those that did not | -0.004 (0.04) | 0.9
Study design (categorical variable) | 0.450 (0.387) | 0.7

Model details: Weighted least squares regression (weighted by the sample size). Dependent variable: standardized mean difference effect size for percent predicted FEV_1_. R^2^=0.56. 16 studies were included in this analysis (because they reported data for each of the variables included in this regression).

In none of our analyses was the study design, the use of a theoretical/conceptual framework, the duration of the intervention, the frequency of interactions with the patient, the type of provider of the education (e.g., nurse, physician), setting of the educational intervention (e.g., home, school), the type of educational materials used associated with improved outcomes (data not shown).

Peak flow measurements. Among the self-monitoring, self-management, or patient education interventions for general populations or adults, 16 studies reported mean peak flow at the end of the study period. Typically, they reported mean peak flow for the intervention and control groups and did not specify time of day. If they did present mean morning and mean evening measurements, we used mean morning values in our summary analysis because these were the most frequently reported. The weighted mean difference in peak flow from these 16 (statistically heterogeneous) was 27.95 L/min (95% CI: 10.75, 45.15; p=0.01). The standardized mean difference of 0.26 (95% CI of 0.10, 0.42) favored the intervention groups (p=0.001) (Figure 18-see below). As with the FEV_1_ results, this represents a change of only modest clinical relevance. The funnel plot (Figure 16) for this analysis does not suggest substantial publication bias.

Figure 16. Funnel plot: mean peak flow

Figure 18. Self-monitoring, self-management, or patient education studies reporting mean peak flow

Note: The effect sizes presented here are the random effects standardized mean difference (SMD).

We sought study design and intervention characteristics associated with the greatest improvements in mean peak flow. For this analysis, we used the standardized mean difference as the dependent variable in a weighted least squares regression. We did not find a combination of the intervention or design characteristics that explained a statistically significant proportion of the variation in mean peak flow (R^2^=0.29) (Table 20).

Table 20 Association of study/intervention characteristics and improvements in mean peak flow

Predictor Variables | Regression Coefficients (SE) | P value
Model Constant | 69.6 (49.1) | 0.2
Intervention duration in months (continuous variable) | -0.008 (0.02) | 0.7
Year of publication (continuous variable) | -0.35 (0.025) | 0.2
Number of educational meetings with the subjects (continuous variable) | -0.05 (0.13) | .7
Studies that specified a theoretical/conceptual framework vs. those that did not | -0.13 (0.2) | 0.6
Study design (categorical variable) | 0.17 (0.2) | 0.9

2 Model details: Weighted least squares regression (weighted by the sample size). Dependent variable: standardized mean difference effect size for mean peak flow. R=0.29. 13 studies were included in this analysis (because they reported data for each of the variables included in this regression).

Functional Status Outcomes. Nine studies reported mean days lost from work or school. For those studies that did not specifically report the timeframe over which the school absenteeism was recorded (e.g., days absent per month versus per school year); we assumed that the reported days of missed school were for the entire study duration. When interpreting these data, we note that not all authors specifically identified these data as mean days lost from school and some likely represent other parameters such as total days lost from school for the whole cohort. We calculated the standardized mean difference between intervention and control groups in terms of the mean number of days lost from work or school (Figure 19). The nine studies were statistically heterogeneous (I^2^=73%) and they did not find any statistically significant difference in days lost from work or school between intervention and control subjects (weighted mean difference of -0.19 days absent per month; 95% CI: -0.40, 0.02; p=0.08; standardized mean difference of -0.21; 95% CI: -0.44, 0.02; p=0.08).

Figure 19. Self-monitoring, self-management, or patient education studies reporting mean days lost from work or school

Note: The effect sizes presented here are the random effects standardized mean difference (SMD).

We performed logistic regression, using any statistically significant functional status outcome as the dependent variable and study/intervention characteristics as the independent variables. In none of our analyses was the study design, year of intervention, the use of a theoretical/conceptual framework, the duration of the intervention, the frequency of interactions with the patient, the type of provider of the education (e.g., nurse, physician), setting of the educational intervention (e.g., home, school), or the type of educational materials used associated with improved outcomes in any of our analyses (data not shown).

Health Services Utilization Outcomes. Twenty-one studies reported urgent care/emergency department visit data in such a way that they could be combined quantitatively (Figure 20). These studies were highly heterogeneous (I^2^=98.9%). They did not find a statistically significant difference in urgent care/emergency department visits between intervention and control subjects (weighted mean difference -0.23 visits per month; 95% CI: -0.64, 0.18; p=0.26; standardized mean difference -0.48; 95% CI: -1.11, 0.14; p=0.13).

Figure 20. Self-monitoring, self-management, or patient education studies reporting urgent care/emergency department visits

Note: The effect sizes presented here are the random effects standardized mean difference (SMD).

Similarly, 24 studies reported hospitalization rates (Figure 21); however, these were also highly heterogeneous (I^2^=99.4%) and they did not find a statistically significant difference in hospitalizations between intervention and control subjects (weighted mean difference -0.34 hospital days per month; 95% CI: -0.99, 0.31; p=0.3; standardized mean difference -0.58; 95% CI of -1.53, 0.37; p=0.23).

Figure 21. Self-monitoring, self-management, or patient education studies reporting hospitalizations

Note: The effect sizes presented here are the random effects standardized mean difference (SMD).

We performed logistic regression, using any statistically significant health services utilization outcome as the dependent variable and study/intervention characteristics as the independent variables. We did not find study design, intervention, or patient characteristics that were associated with improved outcomes in any of our analyses (data not shown).

Guideline Adherence Outcomes. The 40 studies reporting on guideline adherence measures were heterogeneous in terms of the specific outcomes evaluated. We performed logistic regression, using any statistically significant guideline adherence outcome as the dependent variable and study/intervention characteristics as the independent variables. We did not find study design, intervention, or patient characteristics that were associated with improved outcomes in any of our analyses (data not shown).

Conclusions. Self-monitoring, self-management, or patient education interventions for general populations or adults with asthma can result in improvements in FEV_1_ and peak flow. However, these improvements are of borderline clinical importance. Our analyses suggest that more recent studies may result in greater improvements in these spirometric measures. Whether year of the intervention reflects other key covariates that could affect spirometric outcomes, is likely.

#### Self-Monitoring, Self-Management, or Patient Education Trials Comparing Two Intervention Groups Without a Control Group

Background. Several of the included studies compared two or more intervention groups without including a control group that did not also receive a QI intervention. For example, if a study provided a 10-session asthma patient education program to the experimental group and a two-session asthma education program to the “control group,” we considered this to be a trial comparing two intervention groups (sometime called a study with an “active control group”). In this section, we present the results of these studies.

Results. We found 35 trials that compared two or more intervention groups without a control group that did not also receive a QI intervention (Table 21). They all included self-monitoring, self-management, or patient education interventions. Typically, these comparative studies were designed such that one group received a less intense version of what the second group received. Perhaps not surprisingly, these studies generally found improvements in both groups over baseline. Thirteen of these 35 (37%) also found differences between the two groups.

Pediatric interventions. Eleven studies focused exclusively on children and all of these were either self-monitoring, self-management, or patient education interventions and two also included organizational change components. ^57,^ ^64^ Five studies found statistically significant differences between interventions groups. ^55,^ ^56,^ ^62,^ ^64,^ ^197^ Notable among these was the study of a patient education intervention called A.C.T. (Asthma Care Training) for Kids, an intensive educational program for children with severe asthma whose content is based on programs with demonstrated effectiveness, that was compared to a less intense lecture and discussion program. ^62^ The article by Lewis et al. describes the conceptual rationale for the A.C.T. program and its contents in more detail than most of the included articles in this review. ^62^ Briefly, the program emphasizes that children can control their disease rather than being controlled by it. Using the analogy of driving safely, medications and other asthma prevention and treatment techniques are color-coded: green for daily medications used to “keep going and prevent symptoms,” yellow for “caution” to be used when mild symptoms develop, and red to “stop” the disease when severe symptoms occur. ^62^ Participants are taught about underlying asthma pathophysiology and symptomatology, reducing asthma triggers, relaxation skills and breathing techniques, medication use, and decision making skills. They found that the A.C.T. recipients had statistically significantly fewer emergency department visits (2.3 versus 3.7, p<0.001) compared with traditional patient education recipients and that, although there were no differences in terms of number of hospitalizations, the A.C.T. recipients tended to have shorter hospital stays (0.67 versus 1.54 days/child/yr, p<0.001). ^62^ The costs of the program were estimated at $125 per A.C.T. recipient and $37.50 per traditional patient education recipient. Given the lower emergency department and hospital costs in the A.C.T. group, the authors estimated a net incremental savings of $180 per child per year for the sponsoring institution. ^62^

We did not find that increasing either the frequency or the duration of contact between patients and health educators was consistently associated with improvement in outcomes. Specifically, five of nine studies compared two (or more) interventions of differing interventional frequency or duration and found no statistically significant improvements in any outcomes. There were no other distinguishing characteristics of the interventions that were associated with improved outcomes.

General population or adult interventions. We found 24 studies that compared two or more QI interventions without a control group that did not also receive a QI intervention for general/adult populations. Interestingly, only two of these were U.S.-based interventions. ^198,^ ^199^ Eight of sixteen studies reported significantly greater improvements in the intensive treatment arm. ^127,^ ^128,^ ^200^ – ^207^ For example, the study by McLean et al. ^205^ compared a lower intensity pharmacist-provided asthma education/management program to a more intense pharmacist-provided asthma education program that emphasized asthma action plans, the use of peak flow meters, and other self-monitoring or self-management techniques. This study found that the intensive education group experienced significantly greater improvement than the less intense intervention: 11% improvement in peak flows (p=0.0002), 50% overall decrease in asthma symptoms (p<0.01 for most symptoms evaluated), improvement in QOL (<0.05), and decrease in medical visits (but not emergency department visits or hospital visits) between groups. ^205^ The various interventions presented in these studies were heterogeneous with respect to material presented, type of educator, and frequency of interaction with the patients—thus, no particular intervention characteristics were associated with the most successful programs.

Conclusions. Among the trials comparing multiple QI interventions without a control group that did not also receive a QI intervention, we found that, in general, all intervention groups tended to improve from baseline, but only 37% of studies of this type reported statistically significant differences between groups in the outcomes evaluated. The heterogeneity of studies of this type limits conclusions about commonalities of interventions associated with clinically meaningful improvements.

### Provider Education Interventions

Background. The purpose of provider education programs is to inform providers about asthma treatment guidelines and to develop their skills in educating patients and their caregivers about asthma self-monitoring or self-management (whether for providers caring for children or for adults with asthma). ^223^ Health care providers include nurses, nurse practitioners, physicians, physical therapists, and pharmacists, among others.

Results. Eighteen of the included studies reported on the efficacy of provider education to improve the outcomes and processes of care for patients with asthma.

Interventions targeting providers of children with asthma. We found seven articles reporting interventions designed to provide training for clinicians caring for children with asthma (Table 22). ^114,^ ^223,^ ^224^ The Pediatric Asthma Care PORT (Patient Outcomes Research Team), conducted a RCT designed to assess the effectiveness of three strategies (physician-peer leaders, peer leaders in combination with asthma nurse visits, and usual care) to implement guidelines for childhood asthma (funded by AHRQ), which is noteworthy for several reasons: It is an effectiveness study intended to evaluate the effects of implementing QI interventions in real-world primary care practices (rather than an efficacy trial in a controlled trial environment), it included 42 primary care practices in four health care organizations around the country (Boston, Seattle, and Chicago), it is one of the largest included trials (with 638 patients), and it had a relatively long intervention and follow up period (two years). At the end of the two year follow up period, compared with the usual-care arm (N=199), patients randomized to the physician-peer leader arm (N=226) had annual increase of 6.5 symptom-free days, whereas those randomized to the physician-peer leader and nurse visit arm (N=213) had an annual increase of 13.3 symptom-free days over usual care patients. ^225,^ ^226^ The average number of physician visits during the two year trial was higher in the physician-peer leader and nurse visit arm as was regular use of inhaled controller medications (not found for physician-peer leader only patients). ^226,^ ^227^ Total treatment and intervention costs per year per patient were $1292 for PACI, $504 for physician-peer leaders, and $385 for usual care. The incremental cost-effectiveness compared to usual care was$18/symptom-free day for that physician-peer leader arm and $69/symptom-free day for the physician-peer leader with nurse visit arm. ^225^

Table 22 Summary of provider education interventions for the improvement of asthma in children

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Clark et al. ^233,^ ^234^ and Brown et. al ^223^ | To evaluate the long-term effects of an interactive seminar for physicians based on principles of self-regulation on patient care and outcomes. | 67 general pediatricians (N_int_=34, N_con_=33) and their patients with asthma aged 1–12 years (N_int_=202, N_con_=167) from Ann Arbor, MI and New York, NY. | RCT | Intervention physicians received 2 interactive, multimedia, small group, 2.5-hour seminars that focused on optimal clinical practice based on NAEPP expert panel guidelines and patient teaching and communication. They included brief lectures from a local asthma expert and video showing effective clinician teaching and communication behaviors, case studies of clinical problems, a protocol for self assessment, and a review of messages to communicate and materials to distribute to patients/families. Control group physicians received no intervention. | 2 years after the intervention, intervention physicians were more likely than controls to provide written instructions on how to adjust the dose or timing of medications when a child's symptoms changed (p=0.02) and provide specific guidelines for patients to use in order to change therapy when clinical conditions changed (p=0.02). There were no significant differences between the groups in the proportion of patients to whom physicians prescribed anti-inflammatory medication or number of ED visits for the previous 12 months. However, patients of intervention physicians had significantly fewer hospitalizations (p=0.03) for the previous 12 than those seen by control physicians. Data were adjusted for baseline values. ^233^
Evans et al. ^224^ | To evaluate the effects of provider training based on National Asthma Education and Prevention Program on all staff at selected pediatric clinics serving low-income minority children in New York City. The authors hypothesized that the intervention clinics would have increased numbers of children diagnosed with asthma and receiving continuing care and increased use of new pharmacologic and educational treatment methods. | 11 clinics in the study group (with 80 staff) served 3,118 patients and 11 clinics in the control group (with 54 staff) served 2,487 patients. 36% were Medicaid recipients. | RCT | Staff received five 3-hour educational sessions over a 5 month period. All staff (including clerical staff) participated in each session to ensure that everyone in the clinic understood the program and how they could contribute to it. 2 additional 3-hour sessions were held at the end of the 1year follow up period to give staff opportunities to discuss specific patients and reinforce communications skills. The second component of the intervention was a tutorial session with which the intervention physicians each spent 3 hours observing a Columbia faculty physician treating children with asthma. Outcomes were assessed over a 2 year period. | 2 years after the intervention, the intervention clinics had a greater rate of new asthma patients (40/100 vs. 16/100, p<0.01), greater percentage of asthma patients returning for treatment (42% vs. 12%, p<0.001), greater annual frequency of scheduled visits per patient (1.85 vs. 0.88, p<0.001), greater proportions of patients on inhaled β-agonists and corticosteroids. ^224^
Finkelstein et al., ^227,^ ^235^ Sullivan et al., ^225^ and Lozano et al. ^226^ | The Pediatric Asthma Care Patient Outcomes Research Team (I and II) compared 2 asthma care strategies in children with mild to moderate asthma with usual care in the primary care setting. | 42 primary care clinics in 4 health care organizations in Chicago, Seattle, and Boston that cared for 638 children aged 3–17 years with mild to moderate persistent asthma. | RCT | A peer leader-based physician behavior change intervention (PLE) and a practice-based redesign intervention (PACI) were compared with usual care. The PLE strategy involved training a pediatrician (in 2 workshops and through monthly contact from an educational coordinator and ongoing learning network for peer leaders) at each of the practices sites as an asthma expert and champion. The peer leader functioned as a change agent within the practice and provided support, education, and feedback to other members of the practice. The PACI strategy involved 4–5 scheduled asthma care visits with an asthma care nurse who provided standardized assessments, care planning, coordination with primary care physicians, and self-management tools for the patients and their families. Between visits, the asthma nurse provided phone follow up. The PACI arm included all the components of the PLE arm. | At 2 years, compared with the usual-care arm (N=199), patients randomized to the PLE arm (N=226) had annual increase of 6.5 symptom-free days (SFD), whereas those randomized to the PACI arm (N=213) had an annual increase of 13.3 SFD over usual care patients. ^225,^ ^226^ The average number of physician visits during the 2 yr trial was 4.7 in the PACI, 3.2 in the usual-care arm, and 3.1 in the PLE arm (p=0.002) for difference between PACI and the other two arms. ^225^ No difference among arms in terms of the number of hospital days and ED visits. PACI patients were more likely to have regular controller use compared with usual care subjects (RR 0.05; 95% CI 1.0–1.09), no similar effect was found for PLE patients. ^226,^ ^227^ Total treatment and intervention costs per year per patient were $1292 for PACI, $504 for PLE, and $385 for usual care. The incremental cost-effectiveness compared to usual care was$18/SFD for PLE and $69/SFD for PACI. ^225^
Glasgow et al. ^114^ | Train providers to use and then evaluate the feasibility and effectiveness of a general practice-based, proactive system of asthma care in children with moderate to severe asthma. | Australian children (101 intervention and 73 control) with moderate to severe asthma and a general practitioner and their physicians (12 control and 12 intervention physicians) were enrolled. | RCT | The physicians received 1-to-1 education by one of the study authors on a “3+ Visit Plan” (1^st^ visit: introduce concept of a contract for asthma care; 2^nd^ visit: assess patient's status; 3^rd^ visit: review patient's PF record, complete asthma action plan, and identify triggers; 4^th^ visit: assess progress and answer questions. | 12 months after the intervention, the intervention children had increased use of written asthma action plans and pressurized metered dose inhalers with a spacer, decreased rates of speech-limiting wheezing, and were less likely to use reliever medications more than 4 days of the week. There was no difference in symptom-free days or ED visits. ^114^
Homer et al. ^228^ | To implement a multi-disciplinary provider education program in a large number of practices and evaluate its effects on asthma outcomes for children. | 43 practices in Boston and Detroit with 13,878 pediatric patients (aged 2–17) with asthma. | RCT | Intervention practices (N=22) sent a 3-member multidisciplinary team (physician, nurse, and front office staff person) to three 1-day learning sessions on quality improvement strategies for asthma. Additional support was provided through biweekly conference calls, an active e-mail list, and performance feedback based on review of monthly team reports. Control practices (N=21) received no intervention during the experimental year. | After controlling for state, practice size, child age, sex, and within-practice clustering, there was no effect of the intervention on children receiving a written asthma plan, medication use, asthma attacks, activity limitation, hospitalizations or asthma ED visits. ^228^
Maslennikova et al. ^82^ | To assess the effects of a adapting a U.S. self-management educational intervention on asthma outcomes for children in Moscow. | 122 children with asthma and their families living in Moscow. N_int_=60; N_con_=62. | RCT | The authors adapted “Open Airways” (developed for low literacy children aged 4–7 years) and “Air Power” (developed for average literacy children aged 8–14 years) for similar populations in Moscow. Intervention subjects also received asthma care from clinicians who had been trained “according to the U.S. guidelines for the diagnosis and management of asthma and use of modern asthma medications.” Intervention subjects participated in 4 weekly 1hr sessions. Control subjects received usual care. | 1 year after the intervention, the % of children in the education group who were on inhaled anti-inflammatory medications increased by 46% compared to only 8% for the control group (p<0.05). Intervention children's PF measures also improved more than for control children (p<0.05). There was no difference in terms of the change in % of children using theophylline or β-agonists or days missed from school.
Toelle et al. ^88^ | To evaluate whether a community-based asthma management program could reduce asthma symptoms and lung function among school children in Sydney, Australia. | 132 school children aged 8 to 11 with asthma and all the adults who influence their care including parents, doctors, pharmacists, community nurses and school teachers. N_int_=72; N_con_=60. | CBA | Intervention group participant were invited to attend 2 education sessions each 2 hours, 1 week apart on asthma triggers, medication use, inhalation technique, use of written self-management plan. These children's physicians and pharmacists were invited to attend workshops on asthma management guidelines. Intervention community nurses and teachers received workplace in-service education sessions. All families, children, physicians, and pharmacists who did not attend the intervention sessions were mailed the materials. | 147 teachers and community nurses, 53 families (74%), 15 pharmacists (21%), and 11 physicians (20%) attended educational sessions. 6 mos after the intervention, both FEV_1_ and dose-response ratios fell in the intervention group but no the control group (p<0.001). Night cough decreased significantly in the intervention group (p<0.001). There was no significant difference in # of children with wheeze or symptoms that limit activity, physician or ED visits, or days absent from school. ^88^

Note: ED=emergency department; PF=peak flow; NAEPP=National Asthma Education and Prevention Program; CBA=controlled before-after trial.

The study by Homer and colleagues ^228^ is notable for its methodological rigor. For this study, a physician, nurse, and front office staff person from 22 practices in Boston and Detroit were invited to three 1-day educational sessions on quality improvement strategies for asthma based on the Chronic Care Model and concepts from QI theory including the Model for Improvement (a specific approach to QI that emphasized small, incremental tests of change). ^228^ Additional support was provided through biweekly conference calls, an active e-mail list, and performance feedback based on review of monthly team reports. The study specifically describes the authors' research hypotheses, study outcome measures, power calculations, and detailed information about the baseline characteristics of the study population. Further, they performed an intention to treat analysis and evaluated the effect of the intervention by comparing the change from baseline for the intervention group with the change from baseline in the control group (21 additional practices) adjusting for the effects of state, practice size, age, and gender. They found no intervention effect; however, the study serves as model for rigorous analysis and reporting of provider education interventions.

With the study just described by Homer and colleagues as the one exception, ^228^ all of the other studies found statistically significant improvements in use of medications (most often increases in the use of inhaled controller medications) (Table 22). Several also found improvements in asthma symptoms and reductions in emergency department use. All of the studies gave providers some information about current asthma treatment guidelines, about appropriate follow up for patients with asthma, and some training to encourage providers to teach patients (and their caregivers) about asthma self-monitoring or self-management (particularly through the use of asthma action plans). The interventions differed in terms of their intensity and scope of training. For example, the study by Evans and colleagues evaluated an intervention designed to train all the staff (including physicians, nurses, and clerical staff) at selected pediatric clinics serving low-income minority children in New York City. ^224^ All staff were included in the training because the developers of the intervention wanted to ensure that everyone in the clinic understood the program and how they could contribute to it. All staff received five three-hour educational sessions over a five month period and then two additional three-hour sessions at the end of the one-year follow up period to give staff opportunities to discuss specific patients and reinforce communications skills. Intervention physicians also spent three hours observing a Columbia faculty physician treating children with asthma in a tertiary care setting. They found that, two years after the intervention, the intervention clinics had enrolled more new asthma patients (40/100 vs. 16/100, p<0.01), a greater percentage of asthma patients returning for treatment (42% vs. 12%, p<0.001), a greater annual frequency of scheduled visits per patient (1.85 vs. 0.88, p<0.001), and a greater proportion of patients on inhaled β-agonists and corticosteroids than control clinics. ^224^ In contrast, the physicians in the educational intervention described by Glasgow and colleagues received a single one-on-one session training them in the use of a multi-visit asthma treatment plan. ^§^ ^114^ At 12 months after this intervention, Glasgow also showed statistically significant effects: the intervention children had increased use of written asthma action plans (44% versus 34%) and pressurized metered dose inhalers with a spacer (62% versus 38%), decreased rates of speech-limiting wheezing (5% versus 18%), and were less likely to use reliever medications more than 4 days of the week (9% versus 30%). There was no difference in symptom-free days or ED visits. ^114^

§ The article by Glasgow and colleagues provides a detailed description of what actions the physician should take at each of the recommended clinic visits.

Interventions targeting providers of general population or adults with asthma. We found 11 studies reporting on interventions with some component of provider education for general populations or adult patients with asthma (Table 23). One of these compared two intervention groups without a control that did not also receive a QI intervention (Table 21). ^199^

Table 23 Summary of provider education interventions for the improvement of asthma in general populations or adults

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Cordina et al. ^159^ | To examine the effects of a community pharmacy-based education and monitoring program for patients with asthma on a range of patient-specific asthma management outcomes. | 152 patients over the age of 14 who received their asthma prescriptions at private pharmacies in Malta. | CBA | A comprehensive asthma education and monitoring program was instituted in private pharmacies in Malta for 12 months. The intervention pharmacists reviewed patients asthma symptoms, PF records, medication use, and when necessary suggested changes in treatment to the patient's physician. | There was no significant difference between treatment and control groups in terms of PF measurement, self-reported inhaler use, days lost from work or school, or health related QOL. There were fewer self-reported hospitalizations for asthma among intervention patients (0/86) than among control patients (8/66) (p<0.002) but no other differences in health services utilization. The intervention patients were less likely to report nighttime wheezing and more likely to improve their inhaler technique than control patients. ^159^
Daniels et al. ^236^ | To assess the effectiveness of an intervention designed to increase compliance with national asthma care guidelines in primary care safety net health centers serving high-disparity patient populations | 16 federally-funded community health centers in eight southeastern states in the U.S. N_con_=9, N_int_=7. | RCT | The intervention consisted of three components: resources (asthma kits including PF meter, MDI spacer device, educational materials) which clinicians were encouraged to give to patients, training of all health center staff in asthma care guidelines which emphasized the need for patients to have Management, action, and prevention plans, and tools or templates for practice-level systems change (asthma flow sheets and standing orders). Control group sites received copies of the national asthma guidelines and one asthma resource kit with information on how they could obtain more at a discounted price. | There were no significant differences between the intervention and control sites in the number of patients who had been instructed how to use and MDI or a PF meter, counseled regarding environmental triggers, been given a written action plan, counseled on maintenance and rescue plans, or prescribed steroids or anti-inflammatory inhalers. There was a significant increase in the intervention group compared to the control in the number of patients who had their PF measured and recorded in clinic (p=0.006) and documenting interval symptom history (p=0.008). ^236^
Feifer et al. ^171^ | To determine whether a population-based asthma disease management program, using broad-based educational interventions can have favorable effects on physician and patient adherence to guidelines-based care. | 70,900 patients with asthma patients aged 5–45 years using a specific prescription benefit plan in the U.S. 35,450 patients were in each group. | CBA | During the 12-months following enrollment, intervention patients and their physicians received educational materials. Patients in the intervention group received five workbooks and two newsletters. Educational materials emphasized guideline-based elements of asthma pharmacotherapy, self-management techniques, and trigger avoidance. Additionally, patients received refill reminders, prospective compliance reminders, and pollen count alerts by mail. Physicians received asthma management flow sheets to facilitate the tracking and review of patients' therapy. Patients in the control group received no educational materials, nor did their health-care providers. | All outcomes were measured as the change between baseline and 12 months after enrollment. The percentage of patients using controller therapy decreased less in the intervention group (p<0.0001), controller prescription refill rate increased in the intervention group (p<0.0001), and reliever prescription refills were reduced in the intervention group (p<0.001) compared to the control group. ^171^
Gorton et al. ^237^ | To evaluate the effect of three different methods of disseminating asthma guidelines on physicians' behavior and attitudes toward education strategies | 76 primary care physicians in four Area Health Education Centers (AHECs) at the University of Arkansas for Medical Sciences. A total of 375 patient records were reviewed. N_con_=17, N_A_=11, N_B_=17, N_C_=18. | CBA | The study had 1 control group and 3 intervention groups. All intervention groups received the executive summary of the asthma guidelines produced by the National Institutes of Health (NIH). Physicians in Group A also received a 10-page summary of the guidelines, 2 telephone calls from “academic detailing” peer physicians, and were invited to attend a half-day continuing medical education (CME) conference. Physicians in Group B completed 4 computer-based modules, a computer conference with a moderator to discuss the guidelines. Physicians in Group C received a videocassette created for cable medical television, 4 facsimile messages in the hospital mailbox (weekly, for 4 weeks), and 4 posters were displayed in prominent locations in the hospital (monthly, for 4 months). Group C was also invited to the CME conference and received an audiocassette of the conference. Physicians in the control group received educational materials after the completion of the project. | After 4 months, both Group B and Group C physicians increased the appropriate use of oral β-agonists significantly more than control physicians (p=0.03 for both comparisons). Group C physicians increased the ordering of home PF monitoring more than control physicians (p=0.01). Groups A and B physicians increased PF monitoring at the office more than control physicians (p<0.05 and p<0.01, respectively). There were no differences among the groups in terms of improving the use of spirometry or symptom diaries, which remained low. There was also no significant difference in the use of any other asthma medication among the groups. ^237^
Lagerløv et al. ^230^ | To evaluate the effects of a newly developed form of group education for improving the quality of prescribing in primary health care. | 190 GPs responsible for the care of asthma patients in Norway. | CBA | Like the control group, the intervention group participated in 2 group meetings—during one they discussed asthma diagnosis, and the key information for making treatment decisions. At the second meeting international and national guidelines for treating asthma were presented. The group then agreed on common quality criteria for what they found to be acceptable and unacceptable prescribing practices. Feedback on their prescription behaviors was given relative to the agreed upon quality criteria. | There was no difference in the number of patients treated by intervention providers with “acceptable medications” (p=0.18). ^230^
Lundborg et al. ^231^ | To develop, implement, and evaluate a new educational model, with messages based on available national guidelines aimed at improving prescribing in primary care. | 204 GPs responsible for the care of asthma patients in Sweden. | CBA | GPs were asked to attend 2 group sessions. During the 1st session, individual feedback on written simulated cases was given and discussed. During the 2nd session, feedback on individual prescribing was presented and discussed. GPs were expected to: start/increase inhaled corticosteroids when bronchodilator use is too high; treat asthma exacerbations with anti-inflammatory treatment and not routinely with antibiotics; and 3) not start long-acting β_2_-agonists when the patient is on a sub-optimal level of inhaled corticosteroids. | Both the intervention and control groups had increases in the prescription of inhaled corticosteroids. ^231^
Rossiter et al. ^232^ | To determine the potential of a disease management program in terms of improving the health of low-income Medicaid patients while achieving cost savings in providing treatment. | Virginia Medicaid population with moderate to severe asthma (a designation based on assessment of claims) who received care in a primary-care case management program (fee-for-service and HMO-based practices were excluded). | See note^§^ | Providers in primary-case-management programs with asthma patients were identified, and those who volunteered received an education workshop to improve communication skills and to inform them about current asthma treatment recommendations. Additionally, most participants also received intermittent feedback regarding who among their patients might benefit from further asthma education and treatment. | The intervention group had improved prescribing practices for β-agonists, but not for inhaled corticosteroids. The program had a significant effect on emergency visits, but only in the short-term post-intervention. This benefit was greater among those Medicaid claimants whose providers received feedback in addition to the educational workshop. The projected direct cost savings of the program is $3–4 for every incremental dollar spent. ^232^
Tomson et al. ^238^ | To assess the effects of a provider education program on prescribing practices and physician and patient knowledge of asthma. | General practitioners practicing in primary care clinics of Stockholm County (Sweden) (of whom 44 practicing in a similar region were assigned to the intervention group and 19 in a different region were assigned to the control group). | CBA* | A clinical pharmacologist and pharmacist visited the intervention practices and met with physicians in groups to discuss the treatment of asthma and to provide written information encouraging the use of inhaled glucocorticoids for prophylaxis, the use of PF meters, and testing to distinguish patients with COPD and asthma. | Significantly more providers in the intervention group reported recommending the use of PF meters and advised their patients in its use. There was no significant difference in prescribing practices. ^238^
Veninga et al. ^229^ | To evaluate the effects of a newly developed form of group education for improving the quality of prescribing in primary health care. | 181 general practitioners (GPs) responsible for the care of asthma patients in the Netherlands. | CBA | Intervention providers received group education on asthma prescribing and performed a self-learning audit program for peer groups. During 2 meetings, groups met with a moderator with individual feedback material for all members of the groups; anonymity was not maintained by mutual agreement; use of case vignettes which the GPs had received by mail prior to the meetings; individualized feedback on prescribing provided at second meeting. | Increased use of inhaled corticosteroids was found in the intervention group. ^229^
Weng ^194^ | To evaluate the effects of a government sponsored QI intervention with patient and provider education and case management services for patients with asthma. | 1067 patients with asthma enrolled in the program sponsored by the Taiwanese government. 4,340 patients with asthma who did not enroll in the program served as matched controls. | CBA | Providers received a 6-hour asthma curriculum that included conducting pulmonary function testing, use of medications and PF monitoring, environmental controls, and asthma pathophysiology. They were given copies of asthma clinical practice guidelines. Patients received individualized, personally tailored asthma education on recognizing triggers and symptoms, medication use, PF use, and self-management of exacerbations. Case managers (nurses or physician assistants) provided communication between patients, primary care physicians and specialists, and scheduled quarterly follow up. | 1 year after enrollment, the intervention group had longer hospital stays (by 40%, p=0.045) but no difference from control patients in the number of ED visits or number of hospitalizations. However, among patients newly diagnosed with asthma during the study interval, there was a decrease in ED visits (by 61%) in the intervention group compared to the controls. ^194^

* CBA=controlled before-after trials

§ The intervention group for this study was selected from providers in specified geographic areas. Medicaid claims were compared between the intervention area and non-intervention areas. Comparisons were made over time (ITS-like, with only two “before” measures but with explanation that analysis of a longer pre-intervention period yielded little change in variables) and between groups. Note: ED=emergency department; PF=peak flow; QOL=quality of life.

Four studies evaluated interventions that combined provider education with a component of provider feedback (Table 26). ^229^ – ^232^ Two of these four combination interventions were associated with improvements in provider prescribing practice. For example, the study by Cordina and colleagues of an intervention in which Maltese pharmacists were trained to provide patient education and monitoring of asthma symptoms found improvements in inhaler technique, nighttime wheezing, and patient-reported hospitalizations for asthma (there are additional details about this study in the section on organizational change interventions, Table 25). ^159^ In contrast, a Swedish study of pharmacists/clinical pharmacologists visiting groups of primary care providers to teach them about asthma treatments and to encourage self management found no statistically significant change in prescribing practices. ^231^

Table 25 Organizational change interventions for adults with asthma

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Barbanel et al. ^137^ | To evaluate whether a community pharmacist with basic asthma training could improve asthma control by providing self-management advice. | 23 adults aged 18–65 years with asthma living in inner city East London. N_int_=12, N_con_=11. | RCT | Intervention patients received a 45–60 minute individual session from the pharmacist on asthma pathophysiology, recognition and avoidance of triggers, inhaler technique, self-management skills including symptom and PF monitoring, actions in response to worsening symptoms, accessing emergency care, and smoking cessation, if relevant. They received written self-management plans and weekly phone calls for the next 3 months to review plans and answer questions. | 3 months after the intervention, the symptom score increased in the control group and decreased in the intervention group (p<0.001). ^137^
Cordina et al. ^159^ | To examine the effects of a community pharmacy-based education and monitoring program for patients with asthma on a range of patient-specific asthma management outcomes. | 152 patients over the age of 14 who received their asthma prescriptions at private pharmacies in Malta. | CBA* | A comprehensive asthma education and monitoring program was instituted in private pharmacies in Malta for 12 months. The intervention pharmacists reviewed patients asthma symptoms, PF records, medication use, and when necessary suggested changes in treatment to the patient's physician. | There was no significant difference between treatment and control groups in terms of PF measurement, self-reported inhaler use, days lost from work or school, or health related QOL. There were fewer self-reported hospitalizations for asthma among intervention patients (0/86) than among control patients (8/66) (p<0.002) but no other differences in health services utilization. The intervention patients were less likely to report nighttime wheezing and more likely to improve their inhaler technique than control patients. ^159^
Garrett et al. ^152,^ ^153^ | To determine the efficacy of establishing a community asthma education center. | 747 patients aged 2–55 years who had received asthma care in the ED in South Auckland. | CBA | 2 nurse specialists and a group of respiratory physicians established a community education center run by a nurse and 3 community health workers. The purpose of the education program provided was to educate patients in basic pathophysiology, define and teach trigger avoidance, medications use, inhaler technique and self-management skills (emphasis on PF recordings and symptom diaries), and teach how best to access medical care in response to worsening symptoms. | At nine months, the intervention group were more likely to have preventive medications, PF meters and better PF meter technique, more self-management plans, better knowledge of appropriate action to take when confronted with worsening asthma, less nocturnal awakening, and better self-reported asthma control than the control group. There was no difference between intervention and study patients in medication compliance, hospital admissions, days lost from school or work, ED visits, QOL, or smoking rates (33% for control group and 34% for the intervention group). ^152^
Heard et al. ^155^ | To test whether asthma clinics (intervention) were more effective in reducing morbidity from asthma than standard medical treatment (control). | 195 asthma patients aged 5–64 years in Australia. | RCT | Each participating practice operated one 3-hour asthma clinic (run by trained nurses) once a week, which were. Clinic sessions involved education in asthma management strategies, written asthma management plans, spirometry and PF instruction, and an asthma diary card. Sessions ended with a consultation with the general practitioner. Patients were asked to attend 3 sessions within the 6 month study interval. | At the end of the study, patients in the intervention group were more likely to own a PF meter and to be smokers than those in the control group. Intervention patients were less likely to wake at least weekly at night due to asthma than control patients. There were no differences in reported time lost from work or school, having an action plan, use of medications, or health services utilization between intervention and control patients. Baseline smoking rates of 9% in the control group and 12% in the intervention group did not change. ^155^
Johnson et al. ^180^ | To evaluate the effectiveness of a comprehensive asthma disease management program. | Patients with asthma covered by Anthem Blue Cross and Blue Shield insurance in the U.S. N_int_=196, N_con_=196. | CBA | The intervention lasted 12 months. Intervention subjects received teaching that emphasized self-management behaviors such as avoidance of triggers, correct medication use, recognizing symptoms, seeking medical advice, smoking cessation, and adherence to treatment plans. The program is supported by computer generated communications to providers and case managers regarding whether the patient has an action plan, received flu vaccination, has a rescue inhaler, and use of daily controller medications. | 12 months after the intervention, the intervention group had fewer ED visits (118 vs. 305, p<0.0001) and hospitalizations (39 vs. 114, p<0.0001). There were no differences in use of asthma medications or preventative vaccinations. ^180^
Jones and Mullee ^244^ | To compare the outcome of asthma care in two similar practices when on practice provided proactive, nurse-run care for asthma and the other continued with a traditional (reactive) approach to the disease. | 141 asthma patients aged 5–65 years receiving care in two general practices in the Southampton area of the U.K. | CBA | The intervention practice established a nurse-led asthma clinic in which specialist nurses identified patients with asthma, developed a therapeutic plan for these patients, and developed a “call” system to contact patients with asthma for assessment and follow up. | There were no significant difference between the intervention and control patients in terms of PF, symptoms, health services utilization, or medication use. ^244^
Pilotto et al. ^158^ | To assess the ability of nurse-run asthma clinics based in general practice compared with usual medical care to produce at least a moderate improvement in the QOL in adults with asthma. | 153 patients with asthma over the age of 18 from general practices in Australia. N_con_=82, N_int_=71. | RCT | Two respiratory nurses conducted asthma clinics where baseline data was collected, a review of and instruction about inhaler technique was provided, and a packet of information was distributed to each patient. Follow up visits were scheduled at 2 weeks, 3, 6, and 9 months to review inhaler technique and answer questions. Control patients received usual care by their general practitioner. | After 9 months, no significant differences between the intervention and control groups in QOL scores, FEV_1_, ED visits, clinic visits or hospitalizations. However, significantly less people in the intervention group compared to the control missed one or more days of work (p=0.004). ^158^
Rasmussen et al. ^190^ | To assess the outcomes associated with an Internet-based asthma management tool. | 253 adults with asthma aged 18–45 years living in Denmark. N_cont-GP_=80, N_cont-sp_=88, N_int_=85. | RCT | There were three groups: an internet management group, a group receiving treatment from an asthma specialist, and a group receiving care from a general practitioner (GP). The Internet-based management tool was comprised of an electronic asthma diary, an action plan for patients, and a decision support system for physicians. Patients were given PF meters, and the Internet tool's action plan comprised a 3-color warning system with a written treatment plan. Patients were encouraged to fill out the diary daily and follow instructions given by the computer or physician. Physicians used the decision support system to follow up with patients on therapeutic changes. | After 6 months, the Internet group had significantly fewer asthma symptoms (p=0.002 compared to specialists; p<0.001 compared to GPs), higher QOL (p=0.03 compared to specialists, p=0.04 compared to GPs), and better FEV_1_ (p=0.002 compared to specialists, p<0.001 compared to GPs). The Internet group had significantly more acute, unscheduled visits compared to the two control groups (p=0.05). No significant differences among the groups were found in ED visits, hospitalizations, or medication compliance. ^190^
Swanson et al. ^243^ | To evaluate the effects of a health board program on asthma care in general practice in terms of patients' service and use of self-management. | 400 patients aged 2–50 years with asthma receiving care in registered general practices in the U.K. between 1992 and 1994. | CBA | The Scottish health board developed an asthma program which included protocols for asthma treatment, assessment and follow up record cards for use in asthma clinics, and PF diaries. | Chart reviews of patients receiving care in practices adhering to the health board program compared to those of patients receiving care in other general practices. There was no significant difference between patients in terms of the number of general practitioner visits or hospitalizations, days lost from work or school, nighttime awakening from asthma, smoking rates (20% for intervention group and 25% for the control group); however, patients in the intervention group were more likely to make asthma clinic visits than control group patients (p<0.001) and more likely to have PF diaries and asthma self-management plans. ^243^
Verver et al. ^125^ | To evaluate whether inhaler technique and respiratory symptoms of patients with asthma can be improved after instruction by a practice assistant. | 6 physicians assistants were trained in the appropriate use of powder inhalers and provided patient education to 48 Dutch asthma patients aged 15–85 years. | RCT | Patients received two training sessions (2 weeks apart) on the correct technique for use of dry powder inhalers (and the correct order in which to use multiple inhalers). | At baseline only 6% of all patients used the dry powder inhalers correctly. Most mistakes were made with the “breathe out” before inhaling and with the “hold your breath for 5 seconds” after inhaling instructions. There was no correlation between the number of inhaler errors and symptoms. The patients in the instruction group significantly reduced the number of inhaler use errors (p=0.01). There was no difference in reported asthma symptoms between the two groups. ^125^
Weng ^194^ | To evaluate the effects of a government sponsored QI intervention with patient and provider education and case management services for patients with asthma. | 1,067 patients with asthma enrolled in the program sponsored by the Taiwanese government. 4,340 patients with asthma who did not enroll in the program served as matched controls. | CBA | Providers received a 6-hour asthma curriculum that included conducting pulmonary function testing, use of medications and PF monitoring, environmental controls, and asthma pathophysiology. They were given copies of asthma clinical practice guidelines. Patients received individualized, personally tailored asthma education on recognizing triggers and symptoms, medication use, PF use, and self-management of exacerbations. Case managers (nurses or physician assistants) provided communication between patients, primary care physicians and specialists, and scheduled quarterly follow up. | 1 year after enrollment, the intervention group had longer hospital stays (by 40%, p=0.045) but no difference from control patients in the number ED visits or number of hospitalizations. However, among patients newly diagnosed with asthma during the study interval, there was a decrease in ED visits (by 61%) in the intervention group compared to the controls. ^194^

Note: *CBA=controlled before-after trials; ED=emergency department; PF=peak flow; QOL=quality of life.

Table 26 Audit and feedback interventions

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Johnson et al. ^180^ | To evaluate the effectiveness of a comprehensive asthma disease management program. | Patients with asthma covered by Anthem Blue Cross and Blue Shield insurance in the U.S. N_int_=196, N_con_=196. | CBA* | The intervention lasted 12 months. Intervention subjects received teaching that emphasized self-management behaviors such as avoidance of triggers, correct medication use, recognizing symptoms, seeking medical advice, smoking cessation, and adherence to treatment plans. The program is supported by computer generated communications to providers and case managers regarding whether the patient has an action plan, received flu vaccination, has a rescue inhaler, and use of daily controller medications. | 12 months after the intervention, the intervention group had fewer ED visits (118 vs. 305, p<0.0001) and hospitalizations (39 vs. 114, p<0.0001). There were no differences in use of asthma medications or preventative vaccinations. ^180^
Lagerløv et al. ^230^ | To evaluate the effects of a newly developed form of group education for improving the quality of prescribing in primary health care. | 190 GPs responsible for the care of asthma patients in Norway. | CBA | Like the control group, the intervention group participated in 2 group meetings—during one they discussed asthma diagnosis, and the key information for making treatment decisions. At the second meeting international and national guidelines for treating asthma were presented. The group then agreed on common quality criteria for what they found to be acceptable and unacceptable prescribing practices. Feedback on their prescription behaviors was given relative to the agreed upon quality criteria. | There was an increase in the number of patients treated by intervention providers in terms of acceptable medications (p=0.18). ^230^
Lundborg et al. ^231^ | To develop, implement, and evaluate a new educational model, with messages based on available national guidelines aimed at improving prescribing in primary care. | 204 GPs responsible for the care of asthma patients in Sweden. | CBA | GPs were asked to attend 2 group sessions. During the 1st session, individual feedback on written simulated cases was given and discussed. During the 2nd session, feedback on individual prescribing was presented and discussed. GPs were expected to: start/increase inhaled corticosteroids when bronchodilator use is too high; treat asthma exacerbations with anti-inflammatory treatment and not routinely with antibiotics; and 3) not start long-acting β_2_-agonists when the patient is on a sub-optimal level of inhaled corticosteroids. | Both the intervention and control groups had increases in the prescription of inhaled corticosteroids. ^231^
Rossiter et al. ^232^ | To determine the potential of a disease management program in terms of improving the health of low-income Medicaid patients while achieving cost savings in providing treatment. | Virginia Medicaid population with moderate to severe asthma (a designation based on assessment of claims) who received care in a primary-care case management program (fee-for-service and HMO-based practices were excluded). | See note | Providers in primary-case-management programs with asthma patients were identified, and those who volunteered received an education workshop to improve communication skills and to inform them about current asthma treatment recommendations. Additionally, most participants also received intermittent feedback regarding who among their patients might benefit from further asthma education and treatment. | The intervention group had improved prescribing practices for β-agonists, but not for inhaled corticosteroids. The program had a significant effect on emergency visits, but only in the short-term post-intervention. This benefit was greater among those Medicaid claimants who's providers received feedback in addition to the educational workshop. The projected direct cost savings of the program is $3–4 for every incremental dollar spent. ^232^
Veninga et al. ^229^ | To evaluate the effects of a newly developed form of group education for improving the quality of prescribing in primary care. | 181 general practitioners (GPs) responsible for the care of asthma patients in the Netherlands. | CBA | Intervention providers received group education on asthma prescribing and performed a self-learning audit program for peer groups. During 2 meetings, groups met with a moderator with individual feedback material for all members of the groups; anonymity was not maintained by mutual agreement; use of case vignettes which the GPs had received by mail prior to the meetings; individualized feedback on prescribing provided at second meeting. | Increased use of inhaled corticosteroids was found in the intervention group. ^229^

Note: The intervention group for this study was selected from providers in specified geographic areas. Medicaid claims were compared between the intervention area and non-intervention areas. Comparisons were made over time (ITS-like, with only two “before” measures but with explanation that analysis of a longer pre-intervention period yielded little change in variables) and between groups. Note: *CBA=controlled before-after trials; ED=emergency department; PF=peak flow.

As a group, 55% of these 11 provider education interventions reported that providers receiving the education improved adherence to asthma management guidelines (most often, providing written asthma management plans and increased prescription of inhaled corticosteroids). They were less likely to report improvements in health services utilization (27%) or improvements in clinical outcomes (9%).

Conclusions. Most provider education interventions include components of training in current asthma therapies, follow up, and self-monitoring or self-management and most reported improvements in the prescription of inhaled controller medications. Given the heterogeneity in the studies and relatively small number of studies, we cannot evaluate the specific provider education intervention characteristics likely to be associated with improvements in clinical outcomes for patients. Moreover, given the wide variation in the types of interventions included, we cannot specify which educational components led to the greatest benefit.

### Organizational Change Interventions

#### Organizational Change Interventions for Children With Asthma

Background. The studies of organizational change interventions designed to improve the processes and outcomes of care for children with asthma fall broadly into two categories: those that augment the care provided in general pediatrics clinics and those that provide an increased level of care in schools. Whereas the interventions described in the section on patient education (Table 12b) were asthma education programs in schools that often just taught children about the disease and its management, the school-based interventions described in this section all added increased levels of asthma care provided in the school setting. Asthma in children affects schools in several ways: Ongoing disease management typically happens while children are in school and life-threatening acute asthma symptoms can occur at school. Asthma is a leading cause of illness-related school absenteeism and this absenteeism often necessitates “make up” school work for these children and their teachers. Thus, schools are a natural site for asthma-based education and management programs.

Results. We found 13 studies of organizational change strategies designed specifically for children with asthma (Table 24). ^108,^ ^115,^ ^117,^ ^119,^ ^124,^ ^239^ – ^241^ Two of these studies compared two or more intervention groups without a control that did not also receive a QI intervention and are presented with studies of that design (Table 21). As a group of interventions, these were relatively heterogeneous and not as likely as other types of QI interventions to report improvements in outcomes for patients: three studies reported improvements in clinical outcomes, three studies reported improvements in health services utilization, and three studies reported improvements in functional status. They were more likely to report improvements in terms of the number of asthma patients receiving inhaled controller medications.

Table 24 Organizational change interventions for children with asthma

Reference | Study Purpose | Target population | Study Design | Type of intervention | Results
Anderson et al. ^239^ | To assess the health-related benefits of a daily program of a school-based disease management program. | 18 asthma patients attending the Kunsberg school in Denver (mostly of low socioeconomic groups) were compared to 36 control children with asthma from the Denver area attending different schools. | CBA* | The Kunsberg school has a nurse administrator, two nurses, a social worker, and teachers familiar with methods for managing children with chronic medical conditions who provide a range of patient and parent asthma educational interventions, case management including communication with primary care providers, and daily directly observed medical therapy. | At the Kundsberg school, nurses reported that 89% of children with asthma received their controller inhaled corticosteroids on a daily monitored basis. Compared with controls, children enrolled in the Kundsberg school had fewer hospitalizations (p=0.05), ED visits (p=0.04), and follow up visits for their asthma (p=0.01). Hospital and clinic costs for asthma care decreased by 80% in the Kunsberg children compared to a 19% decrease in control children ($8,122/year vs. $1,588/year). A survey of school nurses and parents indicated that improved medication compliance resulted from directly observed therapy and an overall increased structure of care resulted in better outcomes. ^239^
Bynum et al. ^51^ | To assess the effectiveness of pharmacists using interactive compressed video (telepharmacy) for teaching metered dose inhaler (MDI) technique to rural, adolescents with asthma. | 36 adolescents in grades 7–12 with asthma from junior high and high schools in rural Arkansas. N_con_=21, N_int_=15. | RCT | All patients had two 15-minute individual sessions with a pharmacist. During the 1^st^ session, intervention subjects demonstrated their MDI technique to the pharmacist who provided via verbal instructions and demonstrations on improved MDI technique. The control subjects demonstrated MDI technique, were then given written instructions for MDI technique from a package insert for their placebo inhaler. The sessions took place at local health clinics equipped with interactive compressed video technology. | At the 4 week follow up, there was no significant difference between the intervention and the control group in MDI technique. However, there was more significant improvement in the intervention group compared to the control group (p<0.001) in MDI technique from baseline. ^51^
Finkelstein et al., ^227,^ ^235^ Sullivan et al., ^225^ and Lozano et al. ^226^ | The Pediatric Asthma Care Patient Outcomes Research Team (I and II) compared 2 asthma care strategies in children with mild to moderate asthma with usual care in the primary care setting. | 42 primary care clinics in 4 health care organizations in Chicago, Seattle, and Boston that cared for 638 children aged 3–17 years with mild to moderate persistent asthma. | RCT | A peer leader-based physician behavior change intervention (PLE) and a practice-based redesign intervention (PACI) were compared with usual care. The PLE strategy involved training a pediatrician (in 2 workshops and through monthly contact from an educational coordinator and ongoing learning network for peer leaders) at each of the practices sites as an asthma expert and champion. The peer leader functioned as a change agent within the practice and provided support, education, and feedback to other members of the practice. The PACI strategy involved 4–5 scheduled asthma care visits with an asthma care nurse who provided standardized assessments, care planning, coordination with primary care physicians, and self-management tools for the patients and their families. Between visits, the asthma nurse provided phone follow up. The PACI arm included all the components of the PLE arm. | At 2 years, compared with the usual-care arm (N=199), patients randomized to the PLE arm (N=226) had annual increase of 6.5 symptom-free days (SFD), whereas those randomized to the PACI arm (N=213) had an annual increase of 13.3 SFD over usual care patients. ^225,^ ^226^ The average number of physician visits during the 2 yr trial was 4.7 in the PACI, 3.2 in the usual-care arm, and 3.1 in the PLE arm (p=0.002) for difference between PACI and the other two arms. ^225^ No difference among arms in terms of the number of hospital days and ED visits. PACI patients were more likely to have regular controller use compared with usual care subjects (RR 0.05; 95% CI 1.0–1.09), no similar effect was found for PLE patients. ^226,^ ^227^ Total treatment and intervention costs per year per patient were $1,292 for PACI, $504 for PLE, and $385 for usual care. The incremental cost-effectiveness compared to usual care was$18/SFD for PLE and $69/SFD for PACI. ^225^
González-Martin et al. ^115^ | To measure the effects of a pharmaceutical care program in children with asthma. | 13 children with stable and moderate asthma in Chile. | RCT | Children were assigned to either a pharmacist-led asthma program or to usual care by their pediatricians. The intervention pharmacists provided both written and verbal instructions to children and parents, information about asthma triggers, treatment alternatives, inhaler techniques, medication side effects, and what to do in the event of an acute attack. | 9 weeks after enrollment, there were no differences in spirometry or any domains of health-related QOL. ^115^
Halterman et al ^240^ | To determine whether a systematic, school-based asthma screening, coupled with primary care provider notification of asthma severity, would prompt providers to take preventative medication action. | 180 children aged 3 to 7 years with mild persistent or more severe asthma and who were from urban and primarily minority and low-income demographic groups in Rochester, New York. | RCT | The intervention cohort received their daily dose of inhaled corticosteroids from the school nurse. The control group continued, as usual, to receive their inhaled corticosteroids at home. Children were followed for a mean of 2.9 years (range 1–6). | Children in the intervention group had a reported 84% compliance rate with inhaled corticosteroids vs. 63% among the control group. Children in the intervention group missed significantly fewer days of school (6.8 vs. 8.8 days, p=0.47) and experienced more symptom-free days during the early winter months (p=0.02) than did children in the control group. No other statistically significant differences in symptom measures or health care utilization measures were found. Children in both groups had improved health status over time. In addition, parents of children receiving directly observed therapy at school reported an improvement in their QOL significantly greater than that among parents of control-group children. In a post-hoc analysis, it was found that all significant improvements were found in those patients not exposed to second-hand smoke. ^240^
Kamps et al. ^117,^ ^118^ | To establish whether there are differences between outpatient management of childhood asthma by pediatricians or by asthma nurses. | 74 children aged 2–16 with chronic persistent asthma in the Netherlands. | RCT | Children were randomly assigned to receive 1 year of asthma care by either a pediatrician or a specialist asthma nurse. The asthma nurse provided detailed education about the mechanisms of disease, use of medications, management of acute symptoms, and proper inhaler techniques. | At 1 year, there was no difference between children receiving asthma care from a pediatrician than from a nurse specialist in terms of symptom-free days, airway hyperresponsiveness, functional health status, disease-specific QOL. ^117^ There were also no differences between the groups in terms of inhaled or oral corticosteroids, courses of antibiotics, unscheduled outpatient visits, ED visits, hospitalizations, or overall healthcare costs. ^118^
Kelly et al. ^119^ | To examine the effects of a comprehensive education and outreach program designed to decrease emergency department utilization and hospitalization for Medicaid-insured children with asthma. | 78 children with asthma aged 2–16 years enrolled in Medicaid and receiving their care in Norfolk, Virginia. | RCT | Intervention children (and their caretakers) were enrolled in an education and treatment program in a pediatric allergy clinic. They received 1-on-1 education by a physician and asthma outreach nurse on topics including recognition of triggers, environmental control, early warning signs and symptoms, medication usage and side effects, proper usage of inhalers and PF meters. The nurse contacted intervention families on a monthly basis to review the patient's health status, symptoms, medications, refill prescriptions, and assist with scheduling and transportation to clinic follow up. | At the end of the study year, children in the intervention group were less likely to have an ED visit and more likely to receive an annual influenza vaccine (95% vs. 23%; p<0.001). 47% of the intervention group and 50% of the control group reported at least one smoker in the home. Subgroup analysis suggested a trend toward greater effectiveness of the intervention to decrease hospitalizations among children residing in smoke-free households. ^119^
Mangione-Smith et al. ^242^ | To examine whether a collaborative to improve pediatric asthma care positively influenced processes and outcomes of care. | Children aged 2–17 receiving care in 13 primary care clinics (9 experimental and 3 control) across the participating in a collaborative to improve the care of children with asthma. | CBA | Each participating clinic sent a team of 3 to 5 health care providers for three 2-day sessions to learn “proven strategies for improving care and refine plans for incorporating such strategies within their organizations.” | 385 children received care in intervention clinics and 126 children received care in control clinics. Chart review 16 months after the intervention revealed that intervention children were more likely to have PF measurements recorded (p<0001), have written action plan (p<0.0001), have routine asthma follow up at least every 6 months (p=0.004), receive asthma self-management education (p<000.1), receive instruction on inhaler use (p=0.002), and have higher QOL scores (p=0.03). There were no differences between groups in terms of long-term use of controller medications, acute care service use, school absenteeism, or parental missed work days. ^242^
Salisbury et al. ^108^ | To compare a nurse-led clinic in schools with general practice care for adolescents with asthma. | 382 adolescents with asthma attending secondary schools in Bristol, North Somerset, and South Gloucestershire, U.K. | RCT | Adolescents were randomized to receive either usual care with a pediatrician or to attend a nurse-run asthma clinic. The care in these school-based clinics was “similar to that offered at a nurse-led asthma clinic in general practice, but the discussion was specifically targeted at the needs and interests of adolescents.” ^108^ | At 6 months, intervention adolescents had better inhaler technique, were more like to have a PF meter, and self management plans. There was no significant difference between groups in terms of asthma symptoms, days lost from school, use of inhaled steroids, health services utilization, or health related QOL. The costs of six months asthma care for the intervention adolescents were higher than for the control patients. ^108^
Stergachis et al. ^241^ | To assess the effects of a pharmaceutical care program on changes in disease control, functional status, and health services utilization for pediatric and adolescent patients. | 330 children aged 6–17 years with moderate to severe asthma (N_int_=153; N_con_=177) in Seattle. | RCT | Pharmacists received an 8-hour training session on management assessment, drug delivery technique and general principles of pediatric asthma care. Specific topics included instructions on how to establish relationship with patients, collect data, assess drug related problems, and implement and plan follow up. | At 12 months, there was no difference between groups in PF, FEV_1_, asthma severity, inhaler technique, days lost from school, use of inhaled corticosteroids, or health services utilization. ^241^
Weingarten et al. ^124^ | To evaluate the effects of multi-disciplinary non-pharmaceutical management of childhood asthma. | 21 children with asthma receiving medical care in a general practice in Israel. | RCT | Children were examined by a family physician and a physiotherapist and received information about asthma and its treatment, they also received 12 one-hour group sessions with a physiotherapist who discussed chest expansion exercises for improved lung capacity and clearance of secretions. Mothers had 10 two-hour group meetings with social workers to develop coping mechanisms for acute attacks. | At the end of 10 weeks, PF increased in the intervention group but not in the control group. ^124^

Note: *CBA=controlled before-after trials; ED=emergency department; PF=peak flow; QOL=quality of life

Asthma specialty clinics/care. Nine studies compared usual asthma care to asthma care augmented by providers with special training (i.e., nurses, ^108,^ ^117,^ ^118,^ ^225^ – ^227,^ ^235^ pharmacists, ^115,^ ^241^ psychologists and physiotherapists). ^124^

The Pediatric Asthma Care PORT (Patient Outcomes Research Team), a RCT designed to assess the effectiveness of three strategies (physician-peer leaders (PLE), peer leaders in combination with asthma nurse visits (PACI), and usual care) to implement guidelines for childhood asthma found that, at the end of the two year follow up period, compared with the usual-care arm (N=199), patients randomized to the PLE arm (N=226) had annual increase of 6.5 symptom-free days (SFD), whereas those randomized to the PACI arm (N=213) had an annual increase of 13.3 SFD over usual care patients. ^225,^ ^226^ The average number of physician visits during the two year trial was higher in the PACI arm as was regular use of inhaled controller medications (not found for PLE patients). ^226,^ ^227^ Total treatment and intervention costs per year per patient were $1,292 for PACI, $504 for PLE, and $385 for usual care. The incremental cost-effectiveness compared to usual care was$18/SFD for PLE and $69/SFD for PACI. ^225^

The RCT by Kelly and colleagues of low income children in Virginia who were randomized to receive comprehensive education and management by a physician allergist with monthly phone follow up by an outreach nurse found that children in the intervention group were less likely to visit an emergency department or require hospitalization than control children (95% versus 23%; p<0.001). ^119^ The rate of smoking was high in both the intervention and control households (47% and 50%, respectively). Subgroup analysis suggested a trend toward greater effectiveness of the intervention to decrease hospitalizations among children residing in smoke-free households. ^119^

School-based directly-observed therapy programs. Two of the included studies evaluated the use of directly observed therapy for children with asthma. Long-term asthma control therapies work best when taken on a consistent basis, but compliance with this treatment is a known problem—schools provide an opportunity for directly-observed therapy among pediatric patients. Anderson and colleagues compared outcomes among asthma patients attending the Kunsberg school in Denver (designed specifically for children with chronic health conditions) to outcomes among a matched group of children with asthma attending regular schools. ^239^ The Kunsberg school had a nurse administrator, two nurses, a social worker, and teachers familiar with methods for managing children with chronic medical conditions who provided a range of patient and parent asthma educational interventions, case management including communication with primary care providers, and daily directly observed medical therapy. At the Kunsberg school, nurses reported that 89% of children with asthma received their inhaled corticosteroids on a daily monitored basis. ^239^ Compared with controls, children enrolled in the Kunsberg school had fewer hospitalizations, ED visits, and follow up visits for their asthma. ^239^ A survey of school nurse and parents indicated that improved medication compliance resulted from directly-observed therapy and an overall increased structure of care resulted in better outcomes. ^239^ Given the resources available to children in this type of school, it may be difficult to generalize their results to other school settings.

Another study, a RCT by Halterman and colleagues specifically evaluated the role of directly-observed therapy. ^240^ Their study population of children aged 3 to 7 years with asthma from urban and primarily minority and low-income demographic groups received their daily dose of inhaled corticosteroids from the school nurse. The control group continued to receive their inhalers at home. Overall, children in the intervention group had a reported 84% compliance rate with inhaled corticosteroids versus 63% among the control group. Children in the intervention group missed significantly fewer days of school and had more symptom-free days than did children in the control group. In a post-hoc analysis, it was found that all statistically significant improvements that were observed in the study were found in those patients not exposed to second-hand smoke. (Overall, 44% of children with asthma enrolled in the study lived in a home with at least one smoker.)

Conclusions. From the few studies of this type, we conclude that augmenting usual asthma care with additional specialty asthma clinics staffed by asthma-trained nurses and pharmacists can be effective. Directly-observed therapy may increase the rate of inhaled corticosteroid use and improve clinical outcomes among school children with asthma, particularly those who are not exposed to second hand smoke.

#### Organizational Change Interventions for Adults With Asthma

Background. Most of the QI strategies that involve organizational change are designed to create new opportunities for patients to receive comprehensive education and monitoring of symptoms—often by creating asthma specialty clinics in the general practice setting or by creating asthma-specific clinics in other settings (e.g., pharmacies, specialists' offices). For example, recognizing that most patients receive their asthma care in primary care settings, the development of asthma clinics within the general practices of the United Kingdom has been encouraged (a 1993 national survey found that 77% of general practices in the U.K. ran asthma clinics). ^243^

Results. We found 14 studies of organizational change strategies for general populations of adults with asthma (Table 25). Three of these studies compared two or more intervention groups without a control that did not also receive a QI intervention and are presented with studies of that design (Table 21).

In contrast to the organizational change interventions for children with asthma, the studies of organization change interventions for general populations or adults with asthma reported considerably more improvements in clinical outcomes. We cannot clearly identify the distinguishing characteristics between the organizational change interventions for pediatric versus adult populations; however, the organizational change studies in this section were more likely to augment providers' roles (e.g., adding a teaching role to pharmacists already providing routine pharmacy care for patients) or augment the types of providers encountered while receiving “usual care” (e.g., by adding multidisciplinary teams to routine clinical practice). This is in contrast to the addition of specialty care clinics where patients receive care that is distinctly separate from their routine health care encounters (these specialty clinics were more common for children).

For example, none of the three articles that described nurse-run asthma clinics within general care practices found statistically significant improvements in processes or outcomes of care for asthma patients. ^155,^ ^158,^ ^244^ However, several of the other organizational change interventions did result in improvements in the processes and outcomes of care for patients with asthma. For example, the ambitious intervention described by Cordina and colleagues provided training for pharmacists in Malta to assume a greater role in patient education, monitoring of asthma status (including monthly review of patients' medication use, peak flow records, and symptoms), and to recommend treatment changes to patients' physicians (as needed). ^159^ This represented “a major change in conventional practice for Maltese pharmacists” and resulted in a lower rate of self-reported hospitalizations (no patients in the intervention group versus eight patients in the control group) and nighttime wheezing (20% versus 36%).

Two interventions associated with improvements in clinical outcomes for patients utilized computer tools to facilitate asthma management. ^180,^ ^190^ One such intervention, described by Johnson and colleagues, ^180^ was a comprehensive asthma disease management program in which subjects received asthma education and providers and case managers received computer generated communications regarding whether the patient had an action plan, received influenza vaccinations, had rescue inhalers, and reported on patients' use of daily controller medications. This study reported that 12 months after the intervention, the intervention group (196 patients) had fewer emergency department visits (118 versus 305, p<0.0001) and hospitalizations (39 versus 114, p<0.0001) than the control group (196 subjects) albeit no differences in use of asthma medications or preventative vaccinations. ^180^

Three of the studies of organizational change interventions reported smoking rates for participants—in general, these rates were relatively high and recalcitrant to change. For example, in the 1994 study of the implementation of the Scottish health board's asthma education and treatment protocol in general practices, 20–25% of asthma patients studied reported smoking at baseline and there was no statistically significant reduction in smoking as a result of the program. ^243^ Similarly, the intervention reported by Garrett and colleagues of patients (principally from lower socioeconomic groups) receiving care in a South Auckland asthma community education center found even higher baseline smoking rates (33%–34%), which did not change after nine months enrollment in the education center. ^152,^ ^153^

Conclusions. Interventions that augment the “routine care” being provided to patients both in their physicians' offices and in pharmacies were associated with improved outcomes for patients. For example, technologies that enhance communication of patient information to providers can result in statistically significant improvements in outcomes of care for patients.

### Audit and Feedback Interventions

Background. Updated guidelines for asthma treatment are made widely available, but their implementation may nonetheless be delayed. Audit and feedback interventions are generally designed to help providers improve their patient care by adopting current practice recommendations.

Results. We found five studies describing audit and feedback interventions (Table 26). ^229^ – ^232^ All of these studies evaluated interventions that were combinations of provider education with a component of provider feedback and all reported at least some minimal improvements in outcomes for patients. Three of these articles were from European countries instituting the same intervention—group educational sessions for providers during which providers first reviewed theoretical cases of patients with asthma and then discussed clinical decision-making for asthma care as well as their own individual prescribing practices. ^229^ – ^231^ During these group sessions, providers were confronted with feedback about their actual treatment choices. These interventions were designed based on the premise that behavioral change requires both buy-in on the part of providers and a psychological change. Two of the interventions with this group session design found statistically significant improvements in prescribing practice.

Conclusions. We found no studies that evaluated audit and feedback strategies for clinicians in isolation. Two of the four interventions that combined audit and feedback with provider education were associated with improvements in provider prescribing practice. These types of interventions may be promising but there is currently scant evidence about their efficacy.

### Facilitated Relay of Clinical Data

Background. Most studies of facilitated relay of clinical data to providers involve inserting letters or reports of patient information collected from the patients, their medical records, or insurance records into the charts of patients for providers to review.

Results. Our search identified five interventions that utilized the facilitated relay of clinical data for the improvement of care for patients with asthma: three that targeted providers for children and two for providers for adults. Two studies compared two or more intervention groups without a control that did not also receive a QI intervention (Table 21). ^57,^ ^206^

In one intervention, facilitators reviewed the charts of children with asthma being cared for in general practice in Scotland. ^245,^ ^246^ Children in the intervention group (n=1585) had their charts reviewed by a facilitator who placed a project sticker on the outside of the chart and, inside, created a separate section devoted to asthma care including a protocol for managing acute asthma attacks and a letter to their providers suggesting that they review the patient and asthma treatment guidelines. Control group children (n=1563) received usual care. One year after the intervention, the intervention group was more likely to have appointments for asthma care (568 versus 242 appointments), new diagnoses of asthma (249 versus 104 patients, and receive prescriptions for inhaled cromoglycate (128 versus 78 patients). Hospitalizations and hospital care costs decreased in the intervention group and rose in the control group (25 versus 28 admissions; total costs 20,727£ versus 19,650£). ^245^ Outpatient primary care costs rose in the intervention group and fell in the control group (total costs 37,243£ versus 27,990). ^245^ However, at four years after the intervention, the processes and outcomes of care were similar in intervention and control groups. The overall reduction in costs seen in the intervention group was equivalent to the cost of the facilitator. ^246^

In the study by Halterman and colleagues, ^247^ parents of children aged 3 to 7 years entering school completed a screening form that inquired about chronic diseases including asthma. Parents of children with asthma identified through this screening were interviewed about asthma symptoms, emergency visits, and asthma hospitalizations. Children were then randomized to either the control group (N=77) which received usual care or the provider notification group (N=74) for whom the information obtained from the parental interview was sent via fax to the primary care providers with a copy of the 2002 NHLBI asthma management guidelines. Three to six months after the intervention, there was no difference in terms of new medications prescribed, changes in medication doses, discussion about environmental controls, referral to asthma or allergy specialists, or requests for asthma follow up appointments between the groups. ^247^

In the study by Coleman and colleagues, drug utilization information collected from 135 adult Connecticut Medicaid patients using high doses of inhaled β_2_-agonists was compared to 510 adult patients using normal doses of inhaled β_2_-agonists. ^248^ Letters were sent to providers and pharmacies of the high dose group explaining the rationale for the drug utilization review and the specific problem identified for the specific patient (e.g., high dose inhaled β_2_-agonists use or under-utilization of long-term control agents). ^248^ Seven months after the letters were sent, there were no statistically significant differences between control and intervention groups in terms of use of inhaled medications or health services utilization.

Conclusions. Two of the five studies of facilitated relay of clinical information reported improvements in clinical outcomes. There are too few studies of facilitated relay of clinical information for asthma to determine the overall effectiveness of these interventions for improving the processes and outcomes of care for asthma.

### Provider Reminder Interventions

Background. Treatment guidelines for asthma have been widely available, yet not widely implemented. Provider reminder systems for asthma care are designed to use information from clinical practice guidelines applied to patient-specific information to provide reminders to providers at the point of care.

Results. We found four articles describing provider reminders. ^114,^ ^249^ – ^251^ They described highly heterogeneous interventions (e.g., paper-based versus computer-based, some readily adopted by providers versus others that providers found more cumbersome to include in routine clinical practice).

The study by White and colleagues, which evaluated a paper-based reminder implemented over two years in 23 general practices in England, found no improvement in patient reported symptoms, use of health services, or prescribing.^**^ ^251^ Similarly, the evaluation of an implementation of a computerized clinical decision support system for the management of asthma in 62 general practices in England by Eccles and colleagues found that the system had no statistically significant effect on health services utilization, prescribing practices, or patient-reported asthma outcomes 12 months after implementation.^††^ ^249^

** White and colleagues provide copies of both their data collection forms and reminder notices in this article.

†† The decision support system used in this study was based on currently available software to support prescribing decisions for acute conditions. More information about this software is available in Purves IN. PRODIGY: Implementing clinical guidance using computers. Br J Gen Pract 1998;48:1552–3.

In contrast, the evaluation of a computerized clinical decision support system for asthma care in 17 general practices in England by McCowan and colleagues found that although fewer patients in the intervention group sought primary care for their asthma at six months after implementation (22% versus 34%; OR 0.59 [95% CI 0.37–0.95]), there was no statistically significant change in the use of peak flow meters, self management plans, self-reported symptoms, prescribing of maintenance medications, or hospitalizations. ^250^ Interestingly, McCowan and colleagues found a lower rate of asthma exacerbations in the intervention group than in the control group (8% versus 17%; OR 0.43 [95% CI 0.21–0.85]) but no difference in use of oral steroids to manage these attacks. ^250^ (For details of the study by Glasgow and colleagues ^114^ which implemented a provider education intervention that reminded providers to schedule a follow up appointment for patients—see the provider education section).

Conclusions. The results of the studies of provider reminders to improve the care of patients with asthma are mixed. The small number of studies of reminder interventions limits our ability to determine their overall effectiveness for improving the processes and outcomes of care for asthma.

### Financial Incentives

Background. The annual health care costs attributed to asthma exceed $6 billion. If the provision of financial incentives could statistically significantly reduce costly emergency department visits or asthma hospitalizations, they could be highly cost-effective.

Results. Financial incentives are typically intended to be used to change the behavior of providers. We found no interventions that utilized financial incentives directed at providers. However, we found two interventions that included financial incentives to change patient behavior. The first intervention, described by Burkhart and colleagues (Table 11), encouraged children with asthma to contract with their parents and caregivers to perform daily asthma self-monitoring or self-management behaviors. ^71^ For each completed self-monitoring or self-management task, parents gave their children a sticker-star. ^71^ When five stars had been awarded, children received a pre-negotiated award including special activities (43%), a toy or game (24%), pizza or other fast food (19%), or a monetary reward (14%). ^71^ They found no difference in adherence with peak flow monitoring between the intervention and the usual-care (control group) children. ^71^

The second intervention, described by Baren and colleagues, recruited patients aged 16 to 46 years who had recently visited the University of Pennsylvania emergency department for asthma exacerbation. The patients in the intervention group (N=95) were provided a free 5-day course of oral prednisone, two taxi-cab vouchers for transportation to and from their primary care provider (PCP), and a telephone reminder to make an appointment with their PCP. The patients in the control group (N=83) received a short course of oral steroid therapy and were given instructions and prescriptions at the discretion of the treating physician. The main outcome measure was whether patients successfully followed up with a PCP after their emergency department visit. Patients in the intervention group were more likely (46.3%) than patients in the control group (28.9%) to follow up with their PCP ([RR]1.6; 95% CI 1.1, 2.4). ^252^

Conclusions. There is insufficient evidence to assess the effectiveness of QI interventions utilizing financial incentives.

## Secondary Outcomes

For a study to be included in this review, it had to report one or more of the primary outcomes of interest. From the included articles, we also abstracted data about three secondary outcomes of interest: cost, quality of life, and reduction in asthma triggers/allergens such as exposure to tobacco smoke (Appendix B *). In the evidence tables presented throughout this report, we also present data from the included studies on these secondary outcomes. In this section, we summarize the results of the effects of QI interventions on these secondary outcomes. When interpreting these results, we note that our literature search was not designed to find all articles presenting results for these secondary outcomes. Thus, we are likely to be missing articles describing the effects of QI interventions for asthma that were targeted at specifically improving these outcomes.

### Costs

Background. In 1990, the direct medical costs attributed to asthma care in the U.S. were $3.6 million. ^253^ This included physician visits and medications; however, the greatest proportion (nearly $3 million) was attributed to emergency department visits and hospitalizations. ^253^ Since only a small proportion of patients with asthma require emergency department and hospital care, it has been estimated that 5% of patients with asthma account for more than 70% of the costs. ^254^ (We direct interested readers elsewhere for reviews of the cost-effectiveness of programs directed at this “high cost” group of patients. ^255,^ ^256^ ) In general, given the large number of patients with asthma in the U.S., even minimally effective programs can be quite cost-effective (e.g., cost-effectiveness analyses of interventions in children with mild to moderate asthma have estimated that treatment with inhaled corticosteroids costs approximately $11/symptom-free day gained ^257^ and that a community-based education program for inner-city children costs $9/ symptom-free day gained ^75^ ). In this section, we summarize the cost data provided by the included articles.

Results. Twenty-three studies reported cost data: 13 were QI interventions for children and ten were QI interventions for general populations or adults with asthma. Table 27 presents three types of cost data reported in the included articles: costs associated with the implementation of the interventions, asthma-related healthcare costs for study subjects, and other types of costs.

Table 27 Summary of studies presenting cost data

Reference | Table | Intervention Cost Data | Asthma-related Healthcare Cost Data | Other
Interventions for children with asthma
Anderson et al. ^239^ | Table 24 | No data. | Hospital and clinic costs for asthma care decreased by 80% in the Kunsberg school (intervention) children compared to a 19% decrease in control children ($8,122/year vs. $1,588/year). ^239^ | No data.
Clark et al. ^96,^ ^97^ | Table 12a | No data. | No data. | The cost of delivering the program exceeded the healthcare savings realized (for every $1 spent, $0.62 were saved). However, the program saved $11.22 for every $1 spent for children with 1 or more pre-intervention hospitalizations. ^96,^ ^97^
Finkelstein et al., ^227,^ ^235^ Sullivan et al., ^225^ and Lozano et al. ^226^ | Table 22 Table 24 | No data. | No data. | Total treatment and intervention costs per year per patient were $1,292 for intensive intervention, $504 for less intensive intervention, and $385 for usual care. The incremental cost-effectiveness compared to usual care was$18/symptom-free day gained for less intensive and $69/symptom-free day gained for more intensive interventions. ^225^
Greineder et al. ^197^ | Table 21 | No data. | At the end of the 2 year study period, both groups experienced reductions health care costs. The more intensive treatment group improved significantly more than the less intensive treatment group with 71% fewer out-of-plan costs (p<0.001). ^197^ | No data.
Kamps et al. ^117,^ ^118^ | Table 12d Table 24 | No data. | At 1 year, there was no difference between the groups in terms of overall healthcare costs. ^118^ | No data.
LaRoche et al. ^78^ | Table 11 Table 12a | The intervention program cost approximately $2,295 (for 11 patients). ^78^ | The savings from reduced ED visits was $4,675 (for 11 patients). ^78^ | No data.
Lewis et al. ^62^ | Table 21 | The costs of the program were estimated at $125/intervention recipient and $37.50 per control recipient. ^62^ | No data. | Given the lower hospital costs in the intervention group, the authors estimate a $180 annual cost savings per child for the sponsoring institution. ^62^
McCowan et al. ^245,^ ^246^ | See text describing Facilitated Relay Interventions | No data. | 1 year after the intervention, hospital care costs decreased in the intervention group and rose in the control group. ^245^ Outpatient primary care costs rose in the intervention group and fell in the control group. ^245^ | The reduction in costs seen in the intervention group was equivalent to the cost of the facilitator. ^246^
McNabb et al. ^80^ | Table 11 | No data. | No data. | At 12 months, they estimated a program related $507 per child savings on the basis of the reduced ED visits. ^80^
Morgan et al., ^73^ Evans et al., ^74^ , and Sullivan et al. ^75^ | Table 11 Table 12a | The cost of the intervention was $337 per child for 2 years. ^75^ | No data. | The program resulted in an estimate incremental cost-effectiveness ratio of $9.20 per symptom-free day gained (95% CI: -$12.56 to $55.29 per symptom free day gained). ^75^
Runge et al ^52^ | Table 11 Table 12d | It cost 585€ to deliver the intervention. ^52^ | The intervention reduced asthma costs by 461€. ^52^ | Adjusting for benefits in the control group, 0.79€ were saved for every 1€ spent on the intervention during the 1^st^ year. ^52^
Salisbury et al. ^108^ | Table 12b Table 12c Table 24 | No data. | No data. | At 6 months, the costs of six months of asthma care for the intervention adolescents were higher than for the control patients. ^108^
Yoos et al. ^65^ | Table 21 | No data. | The average reduction in health care charges due to reduced healthcare utilization was $82 per child for control children, $162 per child for children asked to monitor their PF when symptoms increased, and $61 per child for the daily PF monitoring children. ^65^ | No data.
Interventions for general populations or adults with asthma
Bailey et al. ^166^ ; Windsor et al. ^167^ | Table 18c | The intervention program cost $32.03 per patient versus the control program, which cost $3.61 per patient. ^167^ | No data. | No data.
Bolton et al. ^147^ | Table 18a | No data. | After 12 months, ED costs were significantly less (p<0.02) for the intervention. However, physician and hospitalization costs did not significantly differ between groups. ^147^ | Total costs did not significantly differ between groups. ^147^
Drummond et al., ^210^ ^211^ Osman et al., ^212^ and Buckingham et al. ^213^ | Table 21 | No data. | No data. | Total cost of integrated care for asthma was estimated to be £40.11/patient/year compared to £62.12/patient/year for conventional care. ^213^
Gallefoss et al. ^172^ – ^175^ | Table 18c | At 1 year, there was no significant difference found between the groups in direct costs associated with the program. ^174^ | No data. | At 1 year, there was no significant difference found between the groups in indirect costs and total costs associated with the program. ^174^
Ghosh et al. ^176^ | Table 18c | At 12 months, there was no significant difference in direct costs found between the two groups. ^176^ | No data. | At 12 months, there were significantly less indirect (p=0.003) and total costs (p=0.036) associated with the intervention group. ^176^
Kauppinen et al. ^215^ – ^217^ | Table 21 | No data. | There was no significant difference between the groups at 5 years for total costs attributed to asthma care. ^217^ | No data.
Knoell et al. ^163^ | Table 18b | No data. | No differences in drug costs. ^163^ | No data.
Lahdensuo et al. ^181,^ ^182^ | Table 18c | The total direct costs were 649 Finnish Marks less in the control group than in the experimental group (p=0.05). ^182^ (At the time of publication: 8.84 Finnish Marks=1£.) | No data. | No data.
Ostojic et al. ^206^ | Table 21 | The additional cost of the intervention per patient, per week was 1.67€ ($1.3 per 1 Euro). ^206^ | No data. | No data.
Rossiter et al. ^232^ | Table 23 Table 26 | No data. | The projected direct cost savings of the program is $3–4 for every incremental dollar spent. The projected Medicaid savings of the program was $839 per physician trained. ^232^ | No data.

Intervention costs. Nine studies described the costs associated with intervention implementation. Two of these found that there was no statistically significant difference between intervention and control program direct costs. ^172^ – ^176^ The other seven studies uniformly found that intervention program costs were higher than control program costs.

Asthma-related healthcare costs. Among the interventions for children with asthma, seven reported asthma-related healthcare cost data, five of which reported reduced costs among the intervention groups (Table 27). Among the interventions for general populations or adults with asthma, four presented asthma-related healthcare costs. Two of these reported cost savings among the intervention groups. The study by Bolton and colleagues of a patient education intervention found that, after 12 months, emergency department costs were statistically significantly less for the intervention group than for the control (p<0.02); however, physician and hospitalization costs did not statistically significantly differ between groups. ^147^ The study by Rossiter and colleagues of a diseases management program for Virginia Medicaid recipients found that the projected direct cost savings of their audit and feedback/provider educational program was $3 to $4 for every incremental dollar spent on the intervention. ^232^ Additionally, they estimated that the projected Medicaid savings of the program was $839 per physician trained. ^232^ The other two studies found no difference in asthma-related healthcare costs between intervention and control subjects.

Other costs. Twelve studies reported other types of cost data, including indirect costs associated with the intervention and analyses of incremental cost-effectiveness. These studies were heterogeneous with respect to cost accounting methods utilized and cost data reported.

Conclusions. In general, we conclude that the implementation of QI interventions for asthma cost more than usual care. The extent to which savings may be reaped from these interventions has not been consistently documented. A critical gap in this literature that prevents an understanding of the cost-effectiveness of QI programs is that there is not a common effectiveness variable such as symptom-free days gained or episode-free days gained. Also, since many studies only include the costs and benefits accrued during the first year after an intervention, it is difficult to estimate the long-term cost-effectiveness of these programs.

### Quality of Life

Background. Poorly controlled asthma can result in symptoms that limit a person's ability to participate in the routine activities of daily life. Thus, health-related quality of life (QOL) is an important metric for evaluating the effects of an asthma QI intervention. A retrospective analysis of 8994 patients from 27 RCTs of trials of various interventions for patients with persistent asthma that reported FEV_1_, Asthma Quality of Life Questionnaire (AQLQ) scores, and self-reported symptoms found that percent predicted FEV_1_ and symptom-free days were weakly correlated with AQLQ scores. ^258^ Further, they found that changes in percent predicted FEV_1_ correlated weakly with changes in SFD but was more strongly correlated with changes in overall AQLQ scores (r=0.26 and 0.38, respectively; p<0.001). ^258^ This study suggests that directly measuring changes in QOL may evaluate important aspects of patient's asthma experiences not fully accounted for by objective measures such as lung function. ^258^

Results. Forty-five of the included studies reported QOL data. They utilized a variety of generic measures such as the SF-36 and disease-specific measures such as the Asthma Quality of Life Questionnaire and the St. George's Respiratory Questionnaire, among others.

Thirteen of 31 (42%) of the interventions aimed at general populations or adult patients and only three of 12 (25%) of interventions aimed at children resulted statistically significant improvement in QOL compared to controls. Overall, the pediatric QI interventions reported little effect on parent or caregiver quality of life.

As has been previously reported, ^258^ we found an association between improvements in clinical status and improvements in QOL: Of the 27 studies that found no statistically significant difference between intervention and control groups, only seven reported any statistically significant clinical outcomes. However, of the 18 studies that reported a statistically significant improvement in quality of life, 15 reported at least one statistically significant clinical outcome. We calculated an unweighted correlation between studies reporting statistically significant improvements in QOL and clinical measures (r=0.4, p=0.019) and functional status measures (r=0.4, p=0.037). We found no associations between QOL and other study design, intervention design, or patient characteristics.

Improving QOL for children with asthma. Fourteen studies of QI interventions for children with asthma reported QOL results—this includes the 12 described above plus two that were directed at caregivers of children with asthma (Table 28). Of these, only four found significantly better quality of life among the intervention group compared to the control group. Of the nine studies that found no statistically significant difference in any outcome, six were self-monitoring, self-management, or patient education interventions whose principal educational modality was individualized, or “one-on-one”, educational sessions.

Table 28 Summary of interventions assessing QOL for children with asthma and caregivers

Reference | Evidence Tables | Duration of Follow up | Caregiver QOL assessed | Type of intervention | QOL Result
Brown et al. ^90^ | Table 12a | 12 months after intervention | √ | Home-based asthma education of low-income parents of children in pre-school. | Education group experiences better caregiver QOL among those children aged 1–3 but not those children aged 4–6. ^90^
Butz et al. ^95^ | Table 12a | 10 months after enrollment | √ | Parent and child asthma education. | No differences in caregiver or child QOL. ^95^
Chan ^57^ | Table 21 | 6 months | | Child asthma education online vs. outpatient education. | There were no differences between the groups at the end of for QOL. ^57^
Eggleston et al. ^98^ | Table 12a | 12 months after intervention | | Home-based parent or caregiver asthma education of parents in the inner-city. | There were no difference in QOL scores. ^98^
González-Martin et al. ^115^ | Table 12d Table 24 | 2 months after enrollment | | Organizational change and patient education provided by pharmacists. | There were no differences in any domains of health-related QOL. ^115^
Henry et al. ^105^ | Table 12b Table 12c | 6 months after intervention | | School-based patient education program for adolescents. | Compared with control students, intervention students had small but significant improvements in total QOL (p=0.003). ^105^
Kamps et al. ^117,^ ^118^ | Table 12d Table 24 | 12 months | | Organizational change and patient education intervention comparing care by a pediatrician or specialist asthma nurse. | There was no difference between children receiving asthma care from a pediatrician than from a nurse specialist in terms of disease-specific QOL. ^117^
Mangione-Smith et al. ^242^ | Table 24 | 16 months after the intervention | | Organizational change strategy in which intervention clinics participated in a collaborative. | Intervention children were more likely to have higher QOL scores (p=0.03). ^242^
Runge et al. ^52^ | Table 11 Table 12d | 6 months after enrollment | | Self-monitoring, self-management, and patient education program. One arm evaluated the use of an internet-based education program. | Significant improvements were seen in 3 of 8 QOL domains in both intervention groups but not in the CG. ^52^
Salisbury et al. ^108^ | Table 12b Table 12c Table 24 | 6 months | | School-based, nurse led education and asthma care clinics for adolescents. | There was no significant difference between groups in terms of health related QOL. ^108^
Shames et al. ^58^ | Table 12d | 12 months | | Patient education program including the use of a video game. | There were some improvements in health related QOL in the intervention group. ^58^
Stevens et al. ^103^ | Table 12a | 12 months | √ | Parent or caregiver education for parents of children in pre-school. | There was no significant difference between the groups in parental/caregiver QOL. ^103^
Walders et al. ^59^ | Table 21 | 12 months after enrollment | | Pediatric self-monitoring, self-management, and education program. | There was no difference between groups in terms of QOL (both groups improved over baseline). ^59^
Wensley and Silverman ^63^ | Table 21 | 3 months | √ | PF-based vs. symptom-based self-management programs. | There was no difference between groups in child or caregiver QOL. ^63^

Three of the four studies that reported parental/caregiver QOL outcomes showed no statistically significant difference between the groups. ^63,^ ^95,^ ^103^ The study by Brown and colleagues of home-based asthma education program for low-income parents of children in pre-school found a statistically significant difference between the parents or caregivers of children aged 1 to 3 years, but no statistically significant difference for parents or caregivers of children aged 4 to 6 years. ^90^ All of the studies that reported parent or caregiver QOL outcomes were parent or caregiver education or self-monitoring or self-management interventions.

Improving the QOL for general populations or adults with asthma. Thirty-one studies of QI strategies for general populations or adults with asthma reported QOL results (Table 29). Of these, 18 found no statistically significant difference in quality of life at follow up between the intervention and control groups. However, 13 studies did show statistically significantly higher quality of life outcomes in the intervention group compared to the control group at follow up. We found no intervention characteristics that were clearly associated with statistically significant improvements in patient quality of life. However, of the eight nurse-led interventions that reported quality of life outcomes, none reported statistically significant differences between the intervention and control groups.

Table 29 Summary of Interventions assessing QOL for general populations or adults with asthma

Reference | Reference Table | Duration of Follow up | Type of Intervention | Results
Cambach et al. ^148^ | Table 18a | 6 months after intervention | Patient education, self-monitoring, or self-management training by a nurse. | No difference in QOL between the groups. ^148^
Cordina et al. ^159^ | Table 18b Table 23 Table 25 | 12 months | Patient education, self-monitoring or self management training by pharmacists who received specialized education. | No difference in QOL between the groups. ^159^
Côté et al. ^201^ – ^203^ | Table 21 | 12 months | Patient education, self-monitoring, or self-management training based on either symptoms or PF. | QOL scores improved for all groups but were significantly more improved among action plan patients than controls. ^201,^ ^202^
Couturaud et al. ^169^ | Table 18c | 12 months | Patient education, self-management training. | No difference in QOL between the groups. ^169^
de Oliveira et al. ^170^ | Table 18c | 6 months | Patient education, self-management training by a physician. | The intervention group had significantly higher QOL scores (p=0.0005). ^170^
Delaronde et al. ^149^ | Table 18a | 6 months after intervention | Patient education, self-management by a nurse. | No difference were in QOL between the groups. ^149^
Gallefoss et al. ^172^ – ^175^ | Table 18c | 12 months | Patient education, self-management training by a physician, pharmacist, nurse, and physiotherapist. | Intervention patients had better health related QOL (p<0.001) compared with control patients. (p<0.05). ^172^
Garrett et al. ^152,^ ^153^ | Table 18a Table 25 | 9 months | A community health center was created where a patient education, self-management training program run by a nurse and community health workers. | QOL was measured as “improvement of ability to do things [patients] liked.” No difference in QOL between the groups. ^152^
Herborg et al. ^160^ | Table 18b | 12 months after intervention | Patient education, self-management training by a pharmacist. | Intervention patients had more significantly improved health-related QOL than control patients (p<0.05). ^160^
Janson et al. ^156^ | Table 18a | 2 months | Patient education, self-management training by a nurse. | No difference between the groups in QOL. ^156^
Jones et al. ^214^ | Table 21 | 6 months after intervention | Patient education, self-management training or a doctor-managed regimen. | No difference between the groups in QOL. ^214^
Kauppinen et al. ^215^ – ^217^ | Table 21 | 60 months | Patient education or self-management training of varying intensity. | No difference between the groups in QOL. ^217^
Knoell et al. ^163^ | Table 18b | 1.5 months | Patient education, self-management training by a pharmacist. | No difference between the groups in QOL. ^163^
Lahdensuo et al. ^181,^ ^182^ | Table 18c | 12 months | Patient education, self-management training and physiotherapeutic counseling. | QOL scores did show trends toward significance when fully adjusted for baseline scores. ^181^
Levy et al. ^157^ | Table 18a | 6 months | Patient education, self-management training by a nurse. | No difference between the groups in QOL. ^157^
Magar et al. ^184^ | Table 18c | 12 months | Patient education, self-management training. | The intervention group had higher QOL scores compared to the control group. ^184^
Marabini et al. ^183^ | Table 18c | 3 months after intervention | Patient education, self-management training by a physician. | The intervention group had significantly higher overall QOL compared to the control group (p<0.05). ^183^
McLean et al. ^205^ | Table 21 | 12 months | Patient education, self-management training. | QOL scores were significantly higher overall for the intervention group compared to control (p<0.05). ^205^
Onyirimba et al. ^187^ | Table 18c | 2.5 months | Patient education, self-management training. | No difference between the groups in QOL. ^187^
Perneger et al. ^188^ | Table 18c | 6 months | Patient education, self-management training by two respiratory physicians and a physiotherapist. | No difference between the groups in overall QOL. ^188^
Pilotto et al. ^158^ | Table 18a Table 25 | 9 months | Nurses created asthma clinic and provided patient education, self-management training. | No difference between the groups in QOL. ^158^
Put et al. ^189^ | Table 18c | 3 months after intervention | Patient education, self-management training. | QOL scores were significantly different between the intervention and control groups. The AQLQ scores were higher and Negative Emotionality Scale (NEM) were lower (p<0.0001 and p<0.01, respectively). ^189^
Rasmussen et al. ^190^ | Table 18c Table 25 | 6 months | Patient education or self-management training through an Internet-based decision support system that physicians also used to follow up with patients vs. care by a specialist or general practitioner. | The Internet group had significantly higher QOL (p=0.03 compared to specialists, p=0.04 compared to GPs). ^190^
Schaffer and Tian ^192^ | Table 18c | 6 months after intervention | Patient education, self-management training. | No difference between the groups in QOL. ^192^
Schonlau et al. ^199^ | Table 21 | 12 months after intervention | Provider education to promote changes in asthma care. | No difference between the groups in QOL. ^199^
Schulz ^164^ | Table 18b | 12 months after intervention | Patient education, self-management training by a pharmacist. | Patients in the intervention group had significantly higher overall QOL scores (p=0.02); however, there was no significant difference between the groups in SF-36 mental summary score. ^164^
Smith et al. ^141^ | Table 18a | 6 months after intervention | Home-based patient education, self-management training provided by a nurse. | No difference between the groups in QOL. When adjusted for major baseline score differences, there was an improvement in asthma-specific QOL (p=0.03). ^141^
Sundberg et al. ^193^ | Table 18c | 12 months | Patient education, self-management training by a nurse with the aid of a computer program. | No difference between the groups in QOL. ^193^
Thomas et al. ^129^ | Table 21 | 6 months after intervention | Patient education, self-management training by nurses compared to breathing retraining by physiotherapists. | There was a slight improvement in one domain of QOL in the breathing retraining group compared to the nurse educator group (p<0.05). ^129^
Turner et al. ^130^ | Table 21 | 6 months | Both groups received patient education by a nurse. Groups then received self-management plans based on either symptoms or PF. | No difference between the groups in QOL. ^130^
Yilmaz and Akkaya ^195^ | Table 18c | 36 months | Patient education, self-management training. | QOL scores were significantly higher in the intervention group compared to the control group (p=0.009). ^195^

Conclusions. QI strategies can improve QOL for patients with asthma. This benefit is correlated with improvements clinical outcomes and functional status. Among the included studies, QOL was less likely to change for children or their parents or caregivers. The relatively small numbers of studies reporting QOL measures limits our ability to identify specific interventional characteristics most associated with improvements in QOL.

### Reductions in Environmental Allergen Exposure

Background. Identifying and reducing exposure to environmental allergens that can exacerbate asthma symptoms is a critical component of asthma prevention. There is a large literature of interventions specifically targeting allergen exposure which we did not review; however, among the included studies, we abstracted information regarding whether the intervention resulted in reductions in environmental allergens.

Results. Five studies reported the effects of their interventions on environmental allergens. ^73^ – ^75,^ ^98^ All were self-monitoring, self-management, or patient education interventions and two targeted children with asthma. These studies as a group are notable for their relatively large sample sizes (range: 65–937; median 129).

The large National Cooperative Inner-City Asthma Study ^73^ – ^75^ was a RCT of 1,023 families of children with asthma in eight major U.S. cities to evaluate whether a home-based intervention for inner-city children designed to teach caregivers to reduce environmental asthma triggers specific to that child (as determined through skin testing) would result in improvements in asthma-related outcomes. During the 12 month intervention, research assistants visited each home five to seven times. Each visit was followed by a phone call to address any barriers to implementing the plan. Caregivers were taught about the role of allergens in asthma, mattress covers were installed, families were given a vacuum cleaner with HEPA filter, and a HEPA air purifier was set up in the child's bedroom. Professional pest control was provided. Two years after enrollment, intervention children had more symptom free days (565.1 vs 538.5 days), fewer asthma symptoms (p<0.001), days lost from school (0.54 versus 0.71 days per two weeks, p<0.009), and lower allergen levels than control children. ^73^ There was no difference in spirometry or peak flow measurements or unscheduled visits to the emergency department, clinic or hospital between the two groups. ^73^ – ^75^ The cost of the intervention was $337 per child for 2 years resulting in an estimate incremental cost-effectiveness ration of $9.20 per symptom-free day gained (95% CI: -$12.56 to $55.29 per symptom free day gained). ^75^

The study by Eggleston and colleagues was a RCT of home-based environmental intervention for 100 children with asthma living in inner city Baltimore based on the National Cooperative Inner-City Asthma Study. ^98^ As part of the intervention, families received comprehensive home-based evaluations of environmental triggers and were given air filters, pillow covers, and cockroach extermination as needed. Additionally, they received three home visits and a telephone follow up to review allergen reduction principals. One year later, the intervention children had fewer daytime asthma symptoms (p=0.02) but there were no difference in nighttime symptoms, exercise-related symptoms, exercise-limiting symptoms, acute visits for asthma, FEV_1_, or QOL scores. ^98^

The other three self-monitoring or self-management patient education interventions all reported environmental allergen reductions in the intervention groups. ^136,^ ^156,^ ^201^ – ^203^

Conclusions. QI improvement strategies can reduce environmental allergens. In particular, home-based environmental control interventions can be effective and may be cost-effective. Patient education and self-monitoring or self-management programs can effectively motivate persons with asthma to reduce environmental allergens.

### Tobacco Smoke Exposure

Background. Exposure to tobacco smoke is a well-recognized trigger for asthma. ^259^ – ^264^ In most developed countries the prevalence of active smoking in adults with asthma is about 25%. ^265^ Between 25% and 43% of all children in the U.S. are regularly exposed to tobacco smoke. ^266,^ ^267^ As exposure to environmental tobacco smoke increases, acute exacerbations of asthma increase, pulmonary function decreases, and therapeutic responses to corticosteroids become impaired. ^268^ The mechanism of corticosteroid resistance in smokers with asthma is currently unexplained but could be due to alterations in airway inflammatory cell phenotypes, changes in glucocorticoid receptor alpha-to-beta ratio, and reduced histone deacetylase activity. ^265,^ ^269^ Cigarette smoking also increases the clearance of drugs such as theophylline by induction of metabolizing enzymes. A complete review of effective interventions for the reduction of tobacco smoke exposure is outside the scope of our review. However, several of the included studies described changes in tobacco exposure among patients with asthma. In this section we summarize their results.

Results. Twelve studies reported either post-intervention tobacco exposure rates or reported whether there was a difference at the end of the intervention between intervention and control subjects (Table 30). When interpreting these results, we note that reducing tobacco exposure may not have been a primary aim of these studies and small sample sizes may have limited their ability to detect relatively rare events (such as identifying one or two people who stopped smoking).

Table 30 Rate of reported tobacco use among patients with asthma and their family members

Reference | Target Population | Demographics | Baseline Smoking* | Results of Intervention
Cowie et al. ^109^ | Adolescents with severe asthma in Calgary | None reported | 53% | No change in smoking rates after the study. ^109^
Eggleston et al. ^98^ | Inner city children with asthma aged 6–12 years with asthma in Baltimore. | 73% of families lived below the 2000 federal poverty level | 69% | After the intervention, 2 parents stopped smoking (did not report group assignment of these parents). ^98^
Halterman et al. ^240^ | Children with asthma 3–7 years from urban, primarily minority low-income demographic groups in Rochester, NY | 32% Hispanic; 59% Black; 53% parents were not high school graduates; 62% received public assistance; 15% private insurance | 44% | Children in the intervention group missed significantly fewer days of school and experienced more symptom-free days during the early winter months than did children in the control group. In a post-hoc analysis, it was found that all significant improvements were found in those patients not exposed to second-hand smoke. ^240^
Heard et al. ^155^ | Asthma patients aged 5–64 years receiving care in general practices in Australia | None reported. | 11% | Intervention patients were more likely to own PF meters and to smoke but less likely to wake at night due to asthma than control group patients. Baseline smoking rates did not change. ^155^
Hughes et al. ^116^ | Children with asthma aged 6–16 years living in Halifax county, Canada | None reported | 57–60% | 60% of intervention families and 57% of control families had at least one smoker in the home at the start of the intervention. During the home visit, the role of cigarette smoke as an asthma trigger was addressed, parents were discouraged from smoking in the home, and participation in smoking cessation programs was encouraged. At the end of the intervention, 52% of intervention families and 51% of control families still had at least one smoker (no difference between groups). ^116^
Kelly et al. ^119^ | Children with asthma 2 to 16 years old enrolled in Medicaid in Norfolk, Virginia | 94% Black 100% Medicaid recipients | 49% | Subgroup analysis suggested trend toward greater effectiveness of the intervention program to decrease hospitalization among children in smoke-free households compared to those households with smokers. A similar trend was noted among children living in households with continuous telephone service compared to those whose telephone service had been disconnected. ^119^
Magar et al. ^184^ | Adults (18–60yrs) with asthma in France. N_con_=89, N_int_=104. | None reported. | Not reported. | There was no significant difference in the rate of tobacco use—7% stopped smoking in the intervention group compared to 2% in the control, p=0.18. ^184^
Perneger et al. ^188^ | 115 adults with asthma in Geneva, Switzerland | Swiss nationality 55%; University education 18% | 21% | No change in smoking rates at the end of the intervention. ^188^
Schulz et al. ^164^ | 164 asthma patients in Hamburg. N_int_=101; N_con_=63 | 37% unemployed | 23% | No change in smoking rates. ^164^
Swanson et al. ^243^ | Asthma patients aged 2–50 years in Scotland | None reported. | 23% | There was no significant difference between groups in smoking rates. ^243^
Wilson et al. ^136^ | 235 patients ages 18–50 with moderate to severe asthma from five Northern California Kaiser Medical Centers. | None reported. | 10% | No significant difference in smoking status between groups. ^136^
Wilson et al. ^94^ | Families of children 6 months to 7 years old with asthma in the U.S. | 89%White/Caucasian 52% of mothers were college graduates | 16% | None of the family members stopped smoking. Intervention children did have improvements in symptom-free days. ^94^

* This represents the pre-intervention rate in the study population of at least one smoker at home.

Not surprisingly, we found that rates of tobacco exposure seemed to be negatively correlated with socioeconomic status. For example, the study by Eggleston and colleagues of inner city children in Baltimore, 73% of whom lived below the 2000 federal poverty level, reported that up to 69% of children with asthma were exposed to tobacco smoke. ^98^

None of the QI interventions resulted in a statistically significant reduction in tobacco use (although only a few were specifically designed to reduce tobacco use). None of the studies was specifically designed to evaluate the differences in processes or outcomes of care between those exposed to smoke and those who were not exposed to smoke; however, several noted that improvements were more likely to be found among those who were not exposed.

Conclusions. We note that this section does not provide a comprehensive assessment of interventions to reduce tobacco exposure among patients with asthma—it is intended simply to summarize the results of tobacco exposure as reported in the included studies of QI interventions for asthma and we emphasize that most of the included interventions were not designed to specifically assess or reduce tobacco exposure. The reported rate of tobacco exposure among children of lower socioeconomic groups was higher than that of higher socioeconomic groups. None of the included interventions resulted in a reduction in tobacco smoke exposure among patients with asthma or their family members.

## Summary Answers to the Key Questions

Research Question 1: What is the evidence that QI strategies improve the processes and outcomes of outpatient care for pediatric and adult populations with asthma? Specifically, which QI strategies are effective for improving processes and outcomes of asthma care for specific patient populations (e.g., adults, children, low SES, racial groups, urban/rural)?

A wide variety of types of QI interventions have been found to improve the outcomes and processes of care for children and adults with asthma. The QI interventions with the richest evidence base are those that employ self-monitoring, self-management, or patient education strategies. Specifically, for young children—even those from lower socioeconomic groups—educational strategies targeting their caregivers/parents can contribute to statistically significant reductions in asthma symptoms. For general populations or adults with asthma, educational strategies that include a component of organizational change (e.g., adding a pharmacist to the team caring for the patient) have be shown to improve outcomes. Interventions that are based on a theoretical framework, use multiple educational sessions, have longer durations, and use combinations of instructional modalities (e.g., small group teaching with role-playing and handouts) are more likely to result in improvements for patients than interventions lacking these characteristics.

Additionally, the use of school personnel to administer directly-observed therapy may increase the rate of inhaled corticosteroid use among school children with asthma, particularly those who are not exposed to second-hand smoke. Provider education strategies directed at clinicians caring for children with asthma have resulted in improvements in medication use and adherence to practice guidelines. There is insufficient evidence to assess the effectiveness of audit and feedback strategies, provider reminders, facilitated relay of clinical data, and financial incentives.

Also, does the setting of the QI intervention (e.g., home, school, clinic) determine its effectiveness for improving processes and outcomes of asthma care?

We did not find that a particular setting (or combination of settings) of the QI intervention consistently predicted its effectiveness.

Research Question 2: Are QI interventions for asthma care that incorporate multiple strategies more effective than those that employ a single strategy?

The majority of the included articles evaluated a single QI strategy. However, 75 studies evaluated QI interventions with two or more QI strategies and 21 studies evaluated intervention with more than two QI strategies. Among those interventions with more than one QI strategy, the most common combination was self-monitoring or self-management and patient education. We found that the greater the number of QI strategies, the more likely a study was to report improvements in clinical status (p=0.009). We note that clinical outcomes were the most frequently reported and that we may have lacked sufficient evidence to find an effect for the other outcomes of interest.