# Technical Expert Panel and Peer Reviewers

## Technical Expert Panel

Martin Eccles, M.D., Centre for Health Services Research, University of Newcastle upon Tyne, EPOC

Russell Glasgow, Ph.D., Kaiser Permanente, Colorado

Jeremy Grimshaw, M.B.Ch.B., Ph.D., University of Ottawa, Cochrane Collaboration Effective Practice and Organisation of Care Group (EPOC)

Charles Homer, M.D., M.P.H., National Institute for Children's Health Care Quality

Harmon Jordan, Sc.D., previously with New England Medical Center Evidence-based Practice Center, currently at Abt Associates

Val Lawrence, M.D., M.Sc., The University of Texas Health Science Center at San Antonio and South Texas Veterans Health Care System

Andrew Oxman, M.D., M.Sc., Department of Health Services Research, Norwegian Directorate for Health and Social Welfare, EPOC

Sandra Wilson, Ph.D., Department of Health Services Research, Palo Alto Medical Foundation

James Zazzali, Ph.D., RAND

## Peer Reviewers

David Atkins, M.D., M.P.H., Chief Medical Officer, Agency for Healthcare Research and Quality, Center for Outcomes and Evidence

William Bailey, M.D., The Kirklin Clinic

Homer Boushey, M.D., Past President ATS, Professor, Department of Medicine, Division of Pulmonary and Critical Care Medicine, University of California San Francisco

Noreen Clark, Ph.D., Professor and Dean, University of Michigan School of Public Health

Peter Cvietusa, M.D., Kaiser Permanente

Rob Fulwood, Ph.D., M.S.P.H., Senior Manager Public Health Program Development, NHLBI/OPEC

Kevin Weiss, M.D., M.P.H., F.A.C.P., Midwest Center for Health Services and Policy Research, Hines VA Hospital, The Center for Health Care Studies, Northwestern University Feinberg School of Medicine, Chicago

Barbara Yawn, M.D., M.Sc., American Academy of Family Physicians