# List of Excluded Studies

## References

Abdulwadud O, Abramson M, Forbes A, James A, Walters E. Evaluation of a randomised controlled trial of adult asthma education in a hospital setting. Thorax. 1999;54(6):493-500. No eligible outcomes. [pmid: 10335002]. [pmcid: 1745497].
Abisheganaden J, Ng SB, Lam KN, Lim TK. Peak expiratory flow rate guided protocol did not improve outcome in emergency room asthma. Singapore Med J. Nov. 1998;39(11):479-484. Ineligible study design. [pmid: 10067382].
Agertoft L, Pedersen S. Importance of training for correct Turbuhaler use in preschool children. Acta Paediatr. Aug. 1998;87(8):842-847. Reported data not usable. [pmid: 9736231].
Akerman MJ, et al. A successful effort to improve asthma care outcome in an inner-city emergency department. J Asthma. May. 1999;36(3):295. Excluded topic. [pmid: 10350227].
Akkaya E, Yilmaz A, Ece F, Bayramguler B, Baran A, Akakca A. Effects of patient education to the life quality in asthma patients: 3 years experience [abstract]. Eur Respir J Suppl. 1997;10(Suppl 25):194S. Abstract.
Alexander J, Divin-Cosgrove C, Faner ML, O'Connell M. Increasing the knowledge base of asthmatics and their families through asthma clubs along the southwest border. J Am Acad Nurse Pract. Jul. 2000;12(7):260-266. Ineligible study design. [pmid: 11930464].
Amirav I, Goren A, Kravitz RM, Pawlowski NA. Physician-targeted program on inhaled therapy for childhood asthma. J Allergy Clin Immunol. Apr. 1995;95(4):818-823. No eligible outcomes. [pmid: 7722161].
Anthonisen NR, Connett JE, Kiley JP, et al. Effects of smoking intervention and the use of an inhaled anticholinergic bronchodilator on the rate of decline of FEV1. The Lung Health Study. JAMA. Nov 16. 1994;272(19):1497-1505. Excluded topic. [pmid: 7966841].
Arbes SJ, Sever M, Archer J, et al. Abatement of cockroach allergen (Bla g 1) in low-income, urban housing: A randomized controlled trial.[comment]. J Allergy Clin Immunol. 2003;112(2):339-345. No eligible outcomes. [pmid: 12897740].
Aronson N, Lefevre F, Piper M, et al. Management of chronic asthma. Evid Rep Technol Assess (Summ). Sep 2001(44):1–10. Other
Asthma program targets patient and physician compliance; wins first DM excellence award. Healthc Demand Dis Manag. Dec 1998;4(12):181–184; suppl 181–184. Ineligible study design
Bailey WC, Richards JM Jr, Manzella BA, Windsor RA, Brooks CM, Soong SJ. Promoting self-monitoring or self-management in adults with asthma: an overview of the UAB program. Health Educ Q. Fall. 1987;14(3):345-355. Reported data not usable. [pmid: 3654238].
Baltins M, Holsta A, Silins V, Krams A. Strategy for patient education in asthma [abstract]. Eur Respir J Suppl. 1995;8(Suppl 19):114. Abstract.
Barrett JC. Effects of nursing intervention on teacher inclusion anxiety. The University of Alabama at Birmingham ** D. 1996(172 p). Thesis/Dissertation
Barta PJ, Brodsky KL. Approaches to asthma care. Medicaid health plans pilot programs to combat a complex health issue. Healthplan. Mar–Apr. 2002;43(2):42-45. Ineligible study design. [pmid: 11961923].
Becker A, Watson W, Ferguson A, Dimich-Ward H, Chan-Yeung M. The Canadian asthma primary prevention study: outcomes at 2 years of age. J Allergy Clin Immunol. Apr. 2004;113(4):650. Excluded topic. [pmid: 15100668].
Berwick DM, Yox SB. Change leads to improvement: pediatric asthma and breast cancer care. HMO Practice. Jun. 1995;9(2):75. Ineligible study design. [pmid: 10184354].
Blackstien-Hirsch P, Anderson G, Cicutto L, McIvor A, Norton P. Implementing continuing education strategies for family physicians to enhance asthma patients' quality of life. J Asthma. May. 2000;37(3):247. Ineligible study design. [pmid: 10831149].
Blixen C, Hammel J, Murphy D, Ault V. Feasibility of a nurse-run asthma education program for urban African- Americans: a pilot study. J Asthma. 2001;38(1):23-32. Excluded topic. [pmid: 11256551].
Blumenthal MN, Cushing RT, Fashingbauer TJ. A community program for the management of bronchial asthma. Ann Allergy. Jul. 1972;30(7):391-398. Ineligible study design. [pmid: 5039529].
Bobb C, Ritz T. Do asthma patients in general practice profit from a structured allergy evaluation and skin testing? A pilot study. Respir Med. Nov. 2003;97(11):1180-1187. Not an evaluation of a QI intervention. [pmid: 14635971].
Borrelli B, McQuaid E, Becker B, et al. Motivating parents of kids with asthma to quit smoking: the PAQS project. Health Educ Res. 2002;17(5):659-669. Reported data not usable. [pmid: 12408210].
Bosnic-Anticevich S, Donnelly A, Saini B. The effect of a peer-led asthma education program on asthma knowledge, confidence and skills [Abstract]. Proceedings of the Thoracic Society of Australia & New Zealand, Annual Scientific Meeting, Adelaide, 4–9 April 2003. 2003. Abstract
Boulet LP, Boutin H, Cote J, Leblanc P, Laviolette M. Evaluation of an asthma self-monitoring or self-management education program. J Asthma. 1995;32(3):199-206. Ineligible study design. [pmid: 7759459].
Brambilla R. Eformoterol in elderly patients: a follow-up. Br J Clin Pract Suppl. Sep. 1995;81:6-7. Not an evaluation of a QI intervention. [pmid: 8546894].
Bramson R. Self-monitoring or self-management of asthma. J Fam Pract. Jul. 1996;43(1):21-22. Ineligible study design. [pmid: 8691172].
Brandt HD, Muntingh GL. Decreasing asthma morbidity. S Afr Med J. Dec. 1994;84(12):842-844. No eligible outcomes. [pmid: 7570234].
Brazil K. The influence of health education on family adaption to childhood asthma [Dissertation]. University of Toronto. 1992. Thesis/Dissertation
Brewin AM, Hughes JA. Effect of patient education on asthma management. Br J Nurs. Jan 28–Feb 8 1995;4(2):81–82, 99–101. Excluded topic
Bright P, Burge PS. Occupational lung disease. 8. The diagnosis of occupational asthma from serial measurements of lung function at and away from work. Thorax. Aug. 1996;51(8):857-863. Ineligible study design. [pmid: 8795680]. [pmcid: 472574].
Bundy DG, Berkoff MC, Ito KE, Rosenthal MS, Weinberger M. Interpreting subgroup analyses: is a school-based asthma treatment program's effect modified by secondhand smoke exposure? comment. Arch Pediatr Adolesc Med. May. 2004;158(5):469. Ineligible study design. [pmid: 15123480].
Bunjaroonsilp N, Bunnag A, Jungsomjatepaisal W, Pongsaranunthakul Y, Maksuwan D. Effectiveness of the nurse-run asthma self-monitoring or self-management program for sick children of the university hospitals in Bangkok. Thai J Nurs. 2002;6(3):128. Other.
Burkhart PV, Dunbar-Jacob JM, Rohay JM. Accuracy of children's self-reported adherence to treatment. J Nurs Scholarsh. 2001;33(1):27-32. No eligible outcomes. [pmid: 11253577].
Cabana MD, Le TT. Challenges in asthma patient education. J Allergy Clin Immunol. Jun. 2005;115(6):1225-1227. Not an evaluation of a QI intervention. [pmid: 15940138].
Callahan K, Eggleston P, Rand C, Kanchanaraksa S, Swartz L, Wood R. Knowledge and practice of dust mite control by specialty care. Ann Allergy Asthma Immunol. 2003;90(3):302-307. No eligible outcomes. [pmid: 12669893].
Campbell TM, Stamm PL, Johnson JR. Improving drug use in a capitated program for the poor. Am J Health Syst Pharm. Nov 1. 1997;54(21):2449-2450. Ineligible study design. [pmid: 9359950].
Capen CL, Sherman JM. Fatal asthma in children: a nurse managed model for prevention. J Pediatr Nurs. Dec. 1998;13(6):367-375. Ineligible study design. [pmid: 9879173].
Castro M, Zimmermann NA, Crocker S, Bradley J, Leven C, Schechtman KB. Asthma intervention program prevents readmissions in high healthcare users. Am J Respir Crit Care Med. Nov 1. 2003;168(9):1095-1099. Excluded topic. [pmid: 12807696].
Catrambone CD. Effect of a case management intervention on symptoms of asthma in high risk children. Rush university, college of nursing ** 2000 d. 2000(141 p). Thesis/Dissertation
Chandler MH, Clifton GD, Louis BA, Coons SJ, Foster TS, Phillips BA. Home monitoring of theophylline levels: a novel therapeutic approach. Pharmacotherapy. 1990;10(4):294-300. Excluded topic. [pmid: 2388876].
Chan-Yeung M, Manfreda J, Dimich-Ward H, Ferguson A, Watson W, Becker A. A randomized controlled study on the effectiveness of a multifaceted intervention program in the primary prevention of asthma in high-risk infants. Arch Pediatr Adolesc Med. Jul. 2000;154(7):657-663. No eligible outcomes. [pmid: 10891016].
Charlton I, Charlton G, Broomfield J, Mullee MA. Audit of the effect of a nurse run asthma clinic on workload and patient morbidity in a general practice. Br J Gen Pract. Jun. 1991;41(347):227-231. Ineligible study design. [pmid: 1931200]. [pmcid: 1371584].
Charlton I. Self-monitoring or self-management plans for asthma control. Nurs Times. May 15–21. 1991;87(20):52. other. [pmid: 2034542].
Chiang LC, Huang JL, Yeh KW, Lu CM. Effects of a self-monitoring or self-management asthma educational program in Taiwan based on PRECEDE-PROCEED model for parents with asthmatic children. J Asthma. Apr. 2004;41(2):205-215. Reported data not usable. [pmid: 15115173].
Chouaid C, Bal JP, Fuhrman C, Housset B, Caudron J. Standardized protocol improves asthma management in emergency department. J Asthma. Feb. 2004;41(1):19. Ineligible study design. [pmid: 15046374].
Chowienczyk PJ, Parkin DH, Lawson CP, Cochrane GM. Do asthmatic patients correctly record home spirometry measurements?. BMJ. Dec 17. 1994;309(6969):1618. Not an evaluation of a QI intervention. [pmid: 7819938]. [pmcid: 2541991].
Clancy K. Avoid irritants to reduce breathlessness. Prof Nurse. Feb. 2005;20(6):29. Not an evaluation of a QI intervention. [pmid: 15726865].
Clark NM, Brown R, Joseph CL, Anderson EW, Liu M, Valerio MA. Effects of a comprehensive school-based asthma program on symptoms, parent management, grades, and absenteeism. Chest. May. 2004;125(5):1674-1679. Reported data not usable. [pmid: 15136375].
Clark NM, Evans D, Mellins RB. Patient use of peak flow monitoring. Am Rev Respir Dis. Mar. 1992;145(3):722-725. Ineligible study design. [pmid: 1546857].
Clark NM. Asthma self-monitoring or self-management education. Research and implications for clinical practice. Chest. May. 1989;95(5):1110-1113. Ineligible study design. [pmid: 2651035].
Cloosterman SG, Schermer TR, Bijl-Hofland ID, et al. Effects of house dust mite avoidance measures on Der p 1 concentrations and clinical condition of mild adult house dust mite-allergic asthmatic patients, using no inhaled steroids. Clin Exp Allergy. Oct. 1999;29(10):1336-1346. Not an evaluation of a QI intervention. [pmid: 10520054].
Coleman R, Gill G, Wilkinson D. Noncommunicable disease management in resource-poor settings: a primary care model from rural South Africa. Bull World Health Organ. 1998;76(6):633-640. Ineligible study design. [pmid: 10191559].
Colland VT. Learning to cope with asthma: a behavioural self-monitoring or self-management program for children. Patient Educ Couns. Dec 31. 1993;22(3):141-152. No eligible outcomes. [pmid: 8153036].
Comino EJ, Mitchell CA, Bauman A, et al. Asthma management in eastern Australia, 1990 and 1993. Med J Aust. Apr 1. 1996;164(7):403-406. Ineligible study design. [pmid: 8609850].
Coover L, Vega C, Persky V, et al. A collaborative model to enhance the functioning of the school child with asthma. Chest. Oct. 1999;116(4 Suppl 1):193S-195S. Ineligible study design. [pmid: 10532484].
Costante C. Asthma: promoting best practice in the school setting. Nasnewsletter. Mar. 2000;15(2):12. Not an evaluation of a QI intervention. [pmid: 11051997].
Couriel J, Littleton V, Milnes L, Barow S. Patient education for children attending an accident and emergency (a & e) department with acute asthma - a randomised controlled study. European Respiratory Society; 1999 Oct 9–13; Madrid, Spain. 1999:P1756. Other
Crain EF, Walter M, O'Connor GT, et al. Home and allergic characteristics of children with asthma in seven U.S. urban communities and design of an environmental intervention: the Inner-City Asthma Study. Environ Health Perspect. Sep. 2002;110(9):939-945. Ineligible study design. [pmid: 12204830]. [pmcid: 1240995].
Creer TL, Backial M, Burns KL, et al. Living with Asthma. I. Genesis and development of a self-monitoring or self-management program for childhood asthma. J Asthma. 1988;25(6):335-362. No eligible outcomes. [pmid: 3235422].
Creer TL, Caplin DA, Holroyd KA. A self-monitoring or self-management program for adult asthma: part IV, Analysis of context and patient behaviors. J Asthma. Jul–Aug. 2005;42(6):455-462. Reported data not usable. [pmid: 16293540].
Crockett A, Leonard A. Local asthma guidelines can help reduce hospital admissions. Asthma J. 2001;6(1):31. Ineligible study design.
Darr MS, Self TH, Ryan MR, Vanderbush RE, Boswell RL. Content and retention evaluation of an audiovisual patient-education program on bronchodilators. Am J Hosp Pharm. May. 1981;38(5):672-675. No eligible outcomes. [pmid: 6169276].
de Blay F, Fourgaut G, Hedelin G, et al. Medical Indoor Environment Counselor (MIEC): role in compliance with advice on mite allergen avoidance and on mite allergen exposure. Allergy. Jan. 2003;58(1):27-33. No eligible outcomes. [pmid: 12580803].
De Blay F, Fourgaut G, Lieutier-Colas F, et al. Mite allergen reduction: Role of an indoor technician in patients compliance and allergen exposure. J Allergy Clin Immunol. 2001;107(2):S218. Abstract.
de Oliveira MA, Bruno VF, Ballini LS, BritoJardim JR, Fernandes AL. Evaluation of an educational program for asthma control in adults. J Asthma. 1997;34(5):395-403. Ineligible study design. [pmid: 9350156].
Demiralay R. Comparison of the effects of three forms of individualized education on asthma knowledge in asthmatic patients. Turk J Med Sci. 2002;32(1):57-64. No eligible outcomes.
Design and implementation of a patient education center for the Childhood Asthma Management Program. Childhood Asthma Management Program Research Group. Ann Allergy Asthma Immunol. Dec 1998;81(6):571–581. Not an evaluation of a QI intervention
Deter H, Allert G. Group therapy for asthma patients: a concept for the psychosomatic treatment of patients in a medical clinic—a controlled study. Psychotherapy & Psychosomatics. 1983;40(14):95-105. Not an evaluation of a QI intervention. [pmid: 6657887].
Diaz Vazquez C, Riano Galan I, Cobo Ruisanchez A, Orejas Rodriguez-Arango G, Sandoval Gutierrez L, Florido Mancheno I. Reduction in the number of hospitalizations for asthma. Quality assurance program for the management of asthma crises in a district hospital. Spanish. An Esp Pediatr. Nov. 1998;49(5):456. Foreign language article language.
Dickinson J, Hutton S, Atkin A, Jones K. Reducing asthma morbidity in the community: the effect of a targeted nurse-run asthma clinic in an English general practice. Respir Med. Nov. 1997;91(10):634-640. Reported data not usable. [pmid: 9488898].
Dickinson J, Hutton S, Atkin A. Implementing the British Thoracic Society's guidelines: the effect of a nurse-run asthma clinic on prescribed treatment in an English general practice. Respir Med. Feb. 1998;92(2):264-267. Ineligible study design. [pmid: 9616523].
Dinelli DL, Higgins JC. Case management of asthma for family practice patients: a pilot study. Mil Med. Mar. 2002;167(3):231-234. Ineligible study design. [pmid: 11901573].
Doherty SR, Jones PD. Use of an ‘evidence-based implementation’ strategy to implement evidence-based care of asthma into rural district hospital emergency departments. Rural Remote Health. Jan–Mar. 2006;6:529. Excluded topic. [pmid: 16569189].
Dolinar RM, Kumar V, Coutu-Wakulczyk G, Rowe BH. Pilot study of a home-based asthma health education program. Patient Educ Couns. Apr. 2000;40(1):93-102. No eligible outcomes. [pmid: 10705068].
Dosa N, Ilardi D. An opportunity for school nurses and pediatricians to collaborate. School Nurse News. Nov. 2003;20(5):16-22. Other. [pmid: 14650894].
D'Souza W, Burgess C, Ayson M, Crane J, Pearce N, Beasley R. Trial of a “credit card” asthma self-monitoring or self-management plan in a high-risk group of patients with asthma. J Allergy Clin Immunol. May. 1996;97(5):1085-1092. Ineligible study design. [pmid: 8626986].
D'Souza W, Crane J, Burgess C, et al. Community-based asthma care: trial of a “credit card” asthma self-monitoring or self-management plan. Eur Respir J. Jul. 1994;7(7):1260-1265. Ineligible study design. [pmid: 7925904].
D'Souza WJ, Slater T, Fox C, et al. Asthma morbidity 6 yrs after an effective asthma self-monitoring or self-management programme in a Maori community. Eur Respir J. Mar. 2000;15(3):464-469. Ineligible study design. [pmid: 10759438].
D'Souza WJ, Te Karu H, Fox C, et al. Long-term reduction in asthma morbidity following an asthma self-monitoring or self-management programme. Eur Respir J. Mar. 1998;11(3):611-616. Ineligible study design. [pmid: 9596111].
Edgren KK, Parker EA, Israel BA, et al. Community involvement in the conduct of a health education intervention and research project: Community Action Against Asthma. Health Promot Pract. Jul. 2005;6(3):263-269. Not an evaluation of a QI intervention. [pmid: 16020621].
Education and follow-up. CMAJ. Sep 13 2005;173(6 Suppl):S51–55. Ineligible study design
Einhorn E, DiMaio MF. An interdisciplinary program to control pediatric asthma. Continuum Soc Soc Work Leadersh Health Care. May–Jun. 2000;20(3):8-13. Not an evaluation of a QI intervention. [pmid: 11183639].
Emmerton L, Shaw J, Kheir N. Asthma management by New Zealand pharmacists: a pharmaceutical care demonstration project. J Clin Pharm Ther. Oct. 2003;28(5):395. Ineligible study design. [pmid: 14632964].
Emond SD, Woodruff PG, Lee EY, Singh AK, Camargo CA Jr. Effect of an emergency department asthma program on acute asthma care. Ann Emerg Med. Sep. 1999;34(3):321-325. Ineligible study design. [pmid: 10459087].
Emtner M, Herala M, Stalenheim G. High-intensity physical training in adults with asthma. A 10-week rehabilitation program. Chest. Feb. 1996;109(2):323-330. Ineligible study design. [pmid: 8620700].
Erickson S, Tolstykh I, Selby JV, Mendoza G, Iribarren C, Eisner MD. The impact of allergy and pulmonary specialist care on emergency asthma utilization in a large managed care organization. Health Serv Res. Oct. 2005;40(5 Pt 1):1443-1465. Ineligible study design. [pmid: 16174142]. [pmcid: 1361198].
Erickson SR, Ascione FJ, Kirking DM, Johnson CE. Use of a paging system to improve medication self-monitoring or self-management in patients with asthma. J Am Pharm Assoc (Wash). Nov–Dec. 1998;38(6):767-769. Ineligible study design. [pmid: 9861796].
Evans D, Clark NM, Feldman CH. School health education programs for asthma. Clin Rev Allergy. Aug. 1987;5(3):207-212. Ineligible study design. [pmid: 3304603].
Feder G, Griffiths C, Highton C, Eldridge S, Spence M, Southgate L. Do clinical guidelines introduced with practice based education improve care of asthmatic and diabetic patients? A randomised controlled trial in general practices in east London. BMJ. Dec 2. 1995;311(7018):1473. No eligible outcomes. [pmid: 8520339]. [pmcid: 2543702].
Feder G, Griffiths C. The dissemination of asthma and diabetes guidelines to inner-city general practice. An evaluation in east London non-training general practices. A personal account of the first year of life of the Lambeth Community Care Centre. 1995. Other
Fedullo AJ, Swinburne AJ, McGuire-Dunn C. Complaints of breathlessness in the emergency department. The experience at a community hospital. N Y State J Med. Jan. 1986;86(1):4-6. Not an evaluation of a QI intervention. [pmid: 3456515].
Ferguson RG, Webb A. Childhood asthma: an outpatient approach to treatment. Can Nurse. Feb. 1979;75(2):36-39. Ineligible study design. [pmid: 252931].
Finkelstein J, O'Connor G, Friedmann RH. Development and implementation of the home asthma telemonitoring (HAT) system to facilitate asthma self-care. Medinfo. 2001;10(Pt 1):810. Ineligible study design. [pmid: 11604847].
Fischer L, Scott L, Boonstra D, et al. Pharmaceutical care for patients with chronic conditions. J Am Pharm Assoc (Wash). 2000;40(2):174-180. No eligible outcomes. [pmid: 10730021].
Fisher EB Jr, Strunk RC, Sussman LK, et al. Acceptability and feasibility of a community approach to asthma management: the Neighborhood Asthma Coalition (NAC). J Asthma. 1996;33(6):367-383. Reported data not usable. [pmid: 8968292].
Fisher EB, Strunk RC, Sussman LK, Sykes RK, Walker MS. Community organization to reduce the need for acute care for asthma among African American children in low-income neighborhoods: the Neighborhood Asthma Coalition. Pediatrics. Jul. 2004;114(1):116-123. Reported data not usable. [pmid: 15231917].
Ford M, Havstad S, Tilley B, Bolton M. Health outcomes among African American and Caucasian adults following a randomized trial of an asthma education program. Ethn Health. 1997 1997;2(4):329–339. Reported data not usable
Ford ME, Edwards G, Rodriguez JL, Gibson RC, Tilley BC. An empowerment-centered, church-based asthma education program for African American adults. Health Soc Work. Feb. 1996;21(1):70-75. Reported data not usable. [pmid: 8626161].
Francis C. Asthma care in a school environment. Nurs Times. Sep 14–20. 2000;96(37):43-45. Ineligible study design. [pmid: 11968264].
Francis C. School clinics for adolescents with asthma. Prof Nurse. May. 2001;16(8):1281-1284. Reported data not usable. [pmid: 12029922].
Freeman LW, Welton D. Effects of imagery, critical thinking, and asthma education on symptoms and mood state in adult asthma patients: a pilot study. J Altern Complement Med. Feb. 2005;11(1):57-68. Ineligible study design. [pmid: 15750364].
Freemantle N, The Ebor Trialists. A Randomised trial of the effect of Evidence Based OutReach visits by community pharmacists on prescribing in English primary care (EBOR). 2001. Other
Frost L, Kieckhefer GM, Rubino C. Incorporating research into a community asthma program. Pediatr Nurs. May–Jun. 1988;14(3):197-200. Reported data not usable. [pmid: 3380568].
Galant DM. Effect of feedback to physicians on asthma patients' health-related quality of life. Dissertation Abstracts International: Section B: the Sciences & Engineering. 1999;60(2-B). Abstract
Gallefoss F, Bakke P. Does smoking affect the outcome of patient education and self-monitoring or self-management in asthmatics?. Patient Educ Couns. Jan. 2003;49(1):91-97. Reported data not usable. [pmid: 12527158].
Gallefoss F, Bakke P. Effect of patient education on compliance in asthmatics and chronic obstructive lung disease [abstract]. Am J Respir Crit Care Med. 1998;157(3 Suppl):A275. Abstract.
Gallefoss F, Bakke PS, Kjaersgaard P. Health related quality of life assessment after patient education in a randomised study on bronchial asthma and chronic obstructive pulmonary disease [abstract]. Eur Respir J Suppl. 1998;12(Suppl 28):227S. Abstract.
Gallefoss F, Bakke PS. Patient satisfaction with healthcare in asthmatics and patients with COPD before and after patient education. Respir Med. Nov. 2000;94(11):1057-1064. No eligible outcomes. [pmid: 11127492].
Gani F, Pozzi E, Crivellaro MA, et al. The role of patient training in the management of seasonal rhinitis and asthma: clinical implications. Allergy. Jan. 2001;56(1):65-68. Excluded topic. [pmid: 11167354].
Gardida A, Rojas M, Tavera C, Catalan M. [Evaluation of an educational program to control asthma in school age children in the Morelos state, Mexico]. Revista del Instituto Nacional de Enfermedades Respiratorias. 2002;15(1):27-30. Foreign language article language.
Gebert N, Hummelink R, Konning J, et al. Efficacy of a self-monitoring or self-management program for childhood asthma—a prospective controlled study. Patient Educ Couns. Nov. 1998;35(3):213-220. No eligible outcomes. [pmid: 9887853].
George M, O'Dowd L, Martin I, et al. A comprehensive educational program improves clinical outcome measures in inner-city patients with asthma. Arch Intern Med. Aug 9–23. 1999;159(15):1710-1716. Excluded topic. [pmid: 10448773].
Georgiou A, Buchner DA, Ershoff DH, Blasko KM, Goodman LV, Feigin J. The impact of a large-scale population-based asthma management program on pediatric asthma patients and their caregivers. Ann Allergy Asthma Immunol. Mar. 2003;90(3):308-315. Ineligible study design. [pmid: 12669894].
Ghory JE. The pre-school child in an asthma rehabilitation program. J Asthma Res. Sep. 1973;11(1):37-42. Ineligible study design. [pmid: 4798220].
Gibbs S, Waters WE, George CF. The benefits of prescription information leaflets (1). Br J Clin Pharmacol. Jun. 1989;27(6):723-739. Reported data not usable. [pmid: 2569323]. [pmcid: 1379799].
Gibson P, Shah S, Mamoon H. Peer-led asthma education for adolescents: impact evaluation. J Adolesc Health. 1998;22(1):66-72. No eligible outcomes. [pmid: 9436069].
Gibson PG, Coughlan J, Abramson M. Self-monitoring or self-management education for adults with asthma improves health outcomes. West J Med. May. 1999;170(5):266. Ineligible study design. [pmid: 10409081]. [pmcid: 1305580].
Gillies J, Barry D, Crane J, et al. A community trial of a written self management plan for children with asthma. Asthma Foundation of NZ Children's Action. N Z Med J. Feb 9. 1996;109(1015):30-33. Ineligible study design. [pmid: 8606811].
Gipson JS, Millard MW, Kennerly DA, Bokovoy J. Impact of the national asthma guidelines on internal medicine primary care and speciality practice. Baylor University Medical Center Proceedings. October. 2000;13(4):407-412. Ineligible study design. [pmid: 16389351]. [pmcid: 1312241].
Godoy N, Howard K, Cassino C, Ciotoli C, Ziegler P, Reibman J. Asthma education in the emergency department improves patient knowledge and behavior [abstract]. Am J Respir Crit Care Med. 1998;157(3 Suppl):A837. Abstract.
Goldberg R, Chan L, Haley P, Harmata-Booth J, Bass G. Critical pathway for the emergency department management of acute asthma: effect on resource utilization. Ann Emerg Med. May. 1998;31(5):562-567. Ineligible study design. [pmid: 9581139].
Grainger-Rousseau T-J. A model for community pharmacist involvement with general practitioners in the management of asthma patients. Appl Ther. 1996;1:145-161. Reported data not usable.
Grant IW. Asthma in New Zealand. Br Med J (Clin Res Ed). Jan 29. 1983;286(6362):374-377. Not an evaluation of a QI intervention.
Griffin KW, McNabb WL, Shields MC. Telephone instruction as an adjunct to patient education of children with asthma. J Healthc Educ Train. 1989;4(1):1-6. Reported data not usable. [pmid: 10293028].
Griffiths C, Foster G, Barnes N, et al. Specialist nurse intervention to reduce unscheduled asthma care in a deprived multiethnic area: the east London randomised controlled trial for high risk asthma (ELECTRA). BMJ. Jan 17. 2004;328(7432):144. No eligible outcomes. [pmid: 14718266]. [pmcid: 314511].
Griffiths C. (ELECTRA study):Can asthma liaison nurses cost effectively reduce unscheduled care for patients with high risk asthma? - a randomised controlled trial. National Research Register. 2000. Other
Griffiths CJ. Educational outreach: a key to implementing asthma guidelines?. Qual Health Care. 2000;8:73. Ineligible study design. [pmid: 10557678].
Guevara JP, Wolf FM, Grum CM, Clark NM. Effects of educational interventions for self management of asthma in children and adolescents: systematic review and meta-analysis. BMJ. Jun 14. 2003;326(7402):1308-1309. Ineligible study design. [pmid: 12805167]. [pmcid: 161636].
Guevara JP, Wolf FM, Grum CM, Clark NM. Learning about asthma: educational programmes improve the ability of children and teenagers to manage their asthma. BMJ. 2003;326. Ineligible study design
Gustafsson PA, Kjellman NI, Cederblad M. Family therapy in the treatment of severe childhood asthma. J Psychosom Res. 1986;30(3):369-374. Not an evaluation of a QI intervention. [pmid: 2874221].
Haahtela T, Klaukka T, Koskela K, Erhola M, Laitinen LA. Asthma programme in Finland: a community problem needs community solutions. Thorax. Oct. 2001;56(10):806-814. Ineligible study design. [pmid: 11562522]. [pmcid: 1745939].
Hadjianastassiou VG, Karadaglis D, Gavalas M. A comparison between different formats of educational feedback to junior doctors: a prospective pilot intervention study. J R Coll Surg Edinb. Dec. 2001;46(6):354. No eligible outcomes. [pmid: 11768577].
Hanks S, Strudley M. Asthma in the classroom. Nurs Stand. Nov 7–13. 1990;5(7):49-51. Ineligible study design. [pmid: 2123687].
Harper T, Wizowski L. Group plus individual education improved quality of life and lung function in patients with asthma [commentary on Gallefoss F, Bakke PS, Kjaersgaard P. Quality of life assessment after patient education in a randomized controlled study on asthma and chronic obstructive pulmonary disease. Am J Respir Crit Care Med 1999 Mar;159:812–7]. Evid Based Nurs. 1999 1999;2(4):118. Ineligible study design
Hazell J, Henry RL, Francis JL, Halliday JA. Teacher initiated improvement of asthma policy in schools. J Paediatr Child Health. Dec. 1995;31(6):519-522. Ineligible study design. [pmid: 8924303].
Hendricson WD, Wood PR, Hidalgo HA, et al. Implementation of individualized patient education for Hispanic children with asthma. Patient Educ Couns. Nov. 1996;29(2):155-165. No eligible outcomes. [pmid: 9006232].
Hindi-Alexander M, Cropp GJ. Community and family programs for children with asthma. Ann Allergy. Mar. 1981;46(3):143-148. No eligible outcomes. [pmid: 7469142].
Hindi-Alexander MC, Throm J, Middleton E Jr. Collaborative asthma self-monitoring or self-management. Evaluation designs. Clin Rev Allergy. Aug. 1987;5(3):249-258. Ineligible study design. [pmid: 3304606].
Hockemeyer J, Smyth J. Evaluating the feasibility and efficacy of a self-administered manual-based stress management intervention for individuals with asthma: results from a controlled study. Behav Med. Winter. 2002;27(4):161-172. Not an evaluation of a QI intervention. [pmid: 12165970].
Holcomb SS. Asthma update 2005: guidelines for pregnant women. Dimens Crit Care Nurs. Nov–Dec. 2005;24(6):263-266. Not an evaluation of a QI intervention. [pmid: 16327509].
Holzheimer L, Mohay H, Masters IB. Educating young children about asthma: comparing the effectiveness of a developmentally appropriate asthma education video tape and picture book. Child Care Health Dev. Jan. 1998;24(1):85-99. Reported data not usable. [pmid: 9468782].
Home-taught pediatric asthma program improves outcomes, cuts hospital, physician visits. Health Care Cost Reengineering Rep. Mar 1997;2(3):40–43. Reported data not usable
Horner SD. Using the Open Airways curriculum to improve self-care for third grade children with asthma. J Sch Health. Oct. 1998;68(8):329-333. Ineligible study design. [pmid: 9800183].
Hovell MF, Meltzer SB, Wahlgren DR, et al. Asthma management and environmental tobacco smoke exposure reduction in Latino children: a controlled trial. Pediatrics. Nov. 2002;110(5):946-956. No eligible outcomes. [pmid: 12415035].
How asthma friendly is your school? National Heart, Lung, and Blood Institute. National Asthma Education and Prevention Program. School Asthma Education Subcommittee. J Sch Health. Apr 1998;68(4):167–168. Ineligible study design
Huss K, Huss R, Squire E, et al. Computer education for asthmatics: what effects?. J Nurs Care Qual. 1992;6(3):57-66. No eligible outcomes. [pmid: 1550949].
Huss K, Salerno M, Huss RW. Computer-assisted reinforcement of instruction: effects on adherence in adult atopic asthmatics. Res Nurs Health. Aug. 1991;14(4):259-267. No eligible outcomes. [pmid: 1891611].
Huss K, Winkelstein M, Nanda J, Naumann PL, Sloand ED, Huss RW. Computer game for inner-city children does not improve asthma outcomes. J Pediatr Health Care. Mar–Apr. 2003;17(2):72-78. No eligible outcomes. [pmid: 12665729].
Hyland ME, Kenyon CA, Allen R, Howarth P. Diary keeping in asthma: comparison of written and electronic methods. BMJ. Feb 20. 1993;306(6876):487-489. No eligible outcomes. [pmid: 8448458]. [pmcid: 1676776].
Hyman D. Reorganizing health systems to promote best practice medical care, patient self-monitoring or self-management, and family-centered care for childhood asthma. Ethn Dis. Summer 2003;13(3 Suppl 3):S3-94–98. Not an evaluation of a QI intervention
Im J. Evaluation of effectiveness of an asthma clinic managed by an ambulatory care pharmacist. Calif J Hosp Pharm. 1989;39:182-186. Ineligible study design.
Indinnimeo L, Midulla F, Hindi-Alexander M, et al. Controlled studies of childhood asthma self-monitoring or self-management in Italy using the “open airways” and “living with asthma” programs: a preliminary report. Health Educ Q. Fall. 1987;14(3):291-308. No eligible outcomes. [pmid: 3654236].
Irvine L, Crombie IK, Clark RA, et al. Advising parents of asthmatic children on passive smoking: randomised controlled trial. BMJ. May 29. 1999;318(7196):1456-1459. No eligible outcomes. [pmid: 10346773].
Jans MP, Schellevis FG, Le Coq EM, Bezemer PD, van Eijk JT. Health outcomes of asthma and COPD patients: the evaluation of a project to implement guidelines in general practice. Int J Qual Health Care. Feb. 2001;13(1):17. Reported data not usable. [pmid: 11330439].
Jans MP, Schellevis FG, Van Hensbergen W, van Eijk JT. Improving general practice care of patients with asthma or chronic obstructive pulmonary disease: evaluation of a quality system see comments. Eff Clin Pract. Jan–Feb. 2000;3(1):16. Reported data not usable. [pmid: 10788032].
Jones CA, Clement LT, Hanley-Lopez J, et al. The Breathmobile Program: structure, implementation, and evolution of a large-scale, urban, pediatric asthma disease management program. Dis Manag. Aug. 2005;8(4):205-222. Ineligible study design. [pmid: 16117716].
Joseph V. A study compliance to two alternative drug regimens and the effect of health education on drug compliance in school age children with bronchial asthma. Nurs J India. Jul. 2004;95(7):153-154. Not an evaluation of a QI intervention. [pmid: 15641583].
Joyce N. A blow for accuracy. Nurs Stand. Mar 1–7. 2000;14(24):22. Ineligible study design. [pmid: 11235365].
Kaplan DL, Rips JL, Clark NM, Evans D, Wasilewski Y, Feldman CH. Transferring a clinic-based health education program for children with asthma to a school setting. J Sch Health. Sep. 1986;56(7):267-271. No eligible outcomes. [pmid: 3640126].
Kattan M, Stearns SC, Crain EF, et al. Cost-effectiveness of a home-based environmental intervention for inner-city children with asthma. J Allergy Clin Immunol. Nov. 2005;116(5):1058-1063. Reported data not usable. [pmid: 16275376].
Kauppinen R, Sintonen H, Pekurinen M. Economic evaluation of intensive vs. conventional patient education and supervision for self-monitoring or self-management of asthma [abstract]. 12th Annual Meeting of the International Society of Technology Assessment in Health Care; 1996 Jun 23–26. 1996:5. Abstract
Kemp VH, Baker RR. School-based asthma screening program. J Am Acad Nurse Pract. Nov. 1997;9(11):511-513. Not an evaluation of a QI intervention. [pmid: 9429375].
Kerac M, Montgomery H, Johnson N. A low cost spacer device used for asthma treatment in a Calcutta street clinic to improve efficacy of metered dose inhalers. Trop Doct. Oct. 1998;28(4):228-229. Not an evaluation of a QI intervention. [pmid: 9803846].
Killian JM, Naessens JM, Kelley LK, Angstman GL. Baseline results for the assessment of the impact of clinical guidelines for pediatric asthma on medical care utilization. In: Data needs in an era of health reform: proceedings of the 25th Public Health Conference on Records and Statistics and the National Committee on Vital and Health Statistics 45th Anniversary Symposium, July 17–19, 1995, Washington, D.C. 1995. Ineligible study design
Klingelhofer EL, Gershwin ME. Asthma self-monitoring or self-management programs: premises, not promises. J Asthma. 1988;25(2):89-101. Ineligible study design. [pmid: 3053603].
Klinnert MD, Liu AH, Pearson MR, Ellison MC, Budhiraja N, Robinson JL. Short-term impact of a randomized multifaceted intervention for wheezing infants in low-income families. Arch Pediatr Adolesc Med. Jan. 2005;159(1):75-82. Reported data not usable. [pmid: 15630062].
Kokubu F, Nakajima S, Ito K, et al. Hospitalization reduction by an asthma tele-medicine system. Japanese. Arerugi. Jan. 2000;49(1):19. Foreign language article language.
Kotses H, Bernstein IL, Bernstein DI, et al. A self-monitoring or self-management program for adult asthma. Part I: Development and evaluation. J Allergy Clin Immunol. Feb. 1995;95(2):529-540. Reported data not usable. [pmid: 7852669].
Kotses H, Stout C, Wigal JK, Carlson B, Creer TL, Lewis P. Individualized asthma self-monitoring or self-management: a beginning. J Asthma. 1991;28(4):287-289. Reported data not usable. [pmid: 1890082].
Krieger JK, Takaro TK, Allen C, et al. The Seattle-King County healthy homes project: implementation of a comprehensive approach to improving indoor environmental quality for low-income children with asthma. Environ Health Perspect. Apr. 2002;110(Suppl 2):311-322. Reported data not usable. [pmid: 11929743]. [pmcid: 1241178].
Labelle M, Beaulieu M, Renzi P, Rahme E, Thivierge RL. Integrating clinical practice guidelines into daily practice: impact of an interactive workshop on drafting of a written action plan for asthma patients. J Contin Educ Health Prof. Winter. 2004;24(1):39. Ineligible study design. [pmid: 15069911].
Laurant M, Hermens RP, Braspenning JC, Sibbald B, Grol RP. Impact of nurse practitioners on workload of general practitioners: randomised controlled trial. BMJ. Apr 17. 2004;328(7445):927. No eligible outcomes. [pmid: 15069024]. [pmcid: 390208].
Lawrence G. Asthma self-monitoring or self-management programs can reduce the need for hospital-based asthma care. Respir Care. Jan. 1995;40(1):39-43. Ineligible study design. [pmid: 10142885].
Le Clainche L, Le Bourgeois M, Delacourt C, Scheinmann P, de Blic J. Between Scylla and Carybdis: how to monitor severe asthma in early childhood?. Pediatr Allergy Immunol. 1998;9(11 Suppl):37-41. Not an evaluation of a QI intervention. [pmid: 9723111].
Lewis BE. Research at Fallon Community Health Plan. Med Care Res Rev. Mar. 1996;53(Suppl):S92-103. Ineligible study design. [pmid: 10157723].
Lewis MA, de la Sota A, Rachelefsky G, Lewis CE, Quinones H, Richards W. ACT-asthma control y tratamiento para ninos: a progress report. Health Educ Q. Fall. 1987;14(3):281-290. Reported data not usable. [pmid: 3654235].
Lincicome V, Lozano P, Jones C, et al. The nurse-patient collaboration: Experiences with a self-monitoring or self-management support intervention for asthma. J Allergy Clin Immunol. 2001;107(2):S73. Abstract.
Lindberg M, Ahlner J, Ekstrom T, Jonsson D, Moller M. Asthma nurse practice improves outcomes and reduces costs in primary health care. Scan J Caring Sci. Mar. 2002;16(1):73. Ineligible study design.
Lindberg M. Evaluation of nurse-run asthma clinics in primary care. Higher quality for less money?. Swedish. Lakartidningen. May 16. 2002;99(20):2277. Foreign language article language.
Lundborg CS, Wahlstrom R, Diwan VK, Oke T, Martenson D, Tomson G. Combining feedback from simulated cases and prescribing. Design and implementation of an educational intervention in primary care in Sweden. Int J Technol Assess Health Care. Summer. 1999;15(3):458. No eligible outcomes. [pmid: 10874374].
Lurie N, Bauer EJ, Brady C. Asthma outcomes at an inner-city school-based health center. J Sch Health. Jan. 2001;71(1):9-16. Ineligible study design. [pmid: 11221541].
Macarthur C, Calpin C, Parkin PC, Feldman W. Factors associated with pediatric asthma readmissions. J Allergy Clin Immunol. Nov. 1996;98(5 Pt 1):992-993. Not an evaluation of a QI intervention. [pmid: 8939164].
Madge P, McColl J, Paton J. Impact of a nurse-led home management training programme in children admitted to hospital with acute asthma: a randomised controlled study. Thorax. Mar. 1997;52(3):223-228. Excluded topic. [pmid: 9093336]. [pmcid: 1758505].
Maes S, Schlosser M. Changing health behaviour outcomes in asthmatic patients: a pilot intervention study. Soc Sci Med. 1988;26(3):359-364. Reported data not usable. [pmid: 3347856].
Maggio L. Asthma Education Project: “the asthma warriors”. Ambul Outreach. Spring 1998:9. Ineligible study design
Maiman LA, Green LW, Gibson G, MacKenzie EJ. Education for self-treatment by adult asthmatics. JAMA. May 4. 1979;241(18):1919-1922. No eligible outcomes. [pmid: 430774].
Marabini A, Brugnami G, Currad iF, et al. Short-term effectiveness of an asthma patient education program [abstract]. Am J Respir Crit Care Med. 1998;157(3 Suppl):A737. Abstract.
Marini A, Agosti M, Motta G, Mosca F. Effects of a dietary and environmental prevention programme on the incidence of allergic symptoms in high atopic risk infants: three years' follow-up. Acta Paediatr Suppl. May. 1996;414:1-21. Not an evaluation of a QI intervention. [pmid: 8831855].
Marks MK, Hynson JL, Karabatsos G. Asthma: communication between hospital and general practitioners. J Paediatr Child Health. Jun. 1999;35(3):251. No eligible outcomes. [pmid: 10404444].
Martin RJ, Pak J, Kunselman SJ, Cherniack RM. Assessment of the AirWatch lung function monitoring system.Asthma Clinical Research Network (ACRN). J Allergy Clin Immunol. Mar. 1999;103(3 Pt 1):535-536. Not an evaluation of a QI intervention. [pmid: 10069893].
Matthews B, Dickinson A, Cram F. Establishment and evaluation of a preschool asthma programme: a pilot study. Nurs Prax N Z. Nov. 1998;13(3):25-34. Ineligible study design. [pmid: 10481654].
McCarthy MJ, Herbert R, Brimacombe M, Hansen J, Wong D, Zelman M. Empowering parents through asthma education. Pediatr Nurs. Sep–Oct. 2002;28(5):465. No eligible outcomes. [pmid: 12424982].
McConnell R, Jones C, Milam J, et al. Cockroach counts and house dust allergen concentrations after professional cockroach control and cleaning. Ann Allergy Asthma Immunol. Dec. 2003;91(6):546-552. Not an evaluation of a QI intervention. [pmid: 14700438].
McDermott MF, Murphy DG, Zalenski RJ, et al. A comparison between emergency diagnostic and treatment unit and inpatient care in the management of acute asthma. Arch Intern Med. Oct 13. 1997;157:2055. Not an evaluation of a QI intervention. [pmid: 9382660].
McEwen M, Johnson P, Neatherlin J, Millard MW, Lawrence G. School-based management of chronic asthma among inner-city African-American schoolchildren in Dallas, Texas. J Sch Health. May. 1998;68(5):196-201. Ineligible study design. [pmid: 9672858].
McMullen AH, Yoos HL, Kitzman H. Peak flow meters in childhood asthma: parent report of use and perceived usefulness. J Pediatr Health Care. Mar–Apr. 2002;16(2):67-72. No eligible outcomes. [pmid: 11904640].
Meinert R, Frischer T, Kuehr J. The “healthy passive smoker”: relationship between bronchial hyper-reactivity in school children and maternal smoking. J Epidemiol Community Health. Jun. 1994;48(3):325-326. Not an evaluation of a QI intervention. [pmid: 8051538]. [pmcid: 1059970].
Meng A, McConnell S. Asthma education: special applications for the school-age child. Nurs Clin North Am. Dec. 2003;38(4):653-664. No eligible outcomes. [pmid: 14763367].
Meng A. A school-based asthma clinic: a partnership model for managing childhood asthma. Nurse Pract Forum. Mar. 2000;11(1):38-47. Ineligible study design. [pmid: 11219894].
Millard MW, Johnson PT, McEwen M, et al. A randomized controlled trial using the school for anti-inflammatory therapy in asthma. J Asthma. 2003;40(7):769-776. Reported data not usable. [pmid: 14626333].
Mitchell EA, Ferguson V, Norwood M. Asthma education by community child health nurses. Arch Dis Child. Dec. 1986;61(12):1184-1189. No eligible outcomes. [pmid: 3545094]. [pmcid: 1778203].
Molimard M. How to achieve good compliance and adherence with inhalation therapy. Curr Med Res Opin. 2005;21(Suppl 4):S33-37. Not an evaluation of a QI intervention. [pmid: 16138943].
Morice AH, Wrench C. The role of the asthma nurse in treatment compliance and self-monitoring or self-management following hospital admission. Respir Med. Nov. 2001;95(11):851-856. Excluded topic. [pmid: 11716197].
Morlion B, Verbandt Y, Paiva M, et al. A telemanagement system for home follow-up of respiratory patients. IEEE Eng Med Biol Mag. Jul–Aug. 1999;18(4):71-79. Ineligible study design. [pmid: 10429904].
Moscato G, Godnic-Cvar J, Maestrelli P, Malo JL, Burge PS, Coifman R. Statement on self-monitoring of peak expiratory flows in the investigation of occupational asthma. Subcommittee on Occupational Allergy of European Academy of Allergy and Clinical Immunology, American Academy of Allergy and Immunology, European Respiratory Society, American College of Allergy, Asthma and Immunology. Ann Allergy Asthma Immunol. Sep. 1995;75(3):233-238. Ineligible study design. [pmid: 7552924].
Moscato G, Godnic-Cvar J, Maestrelli P, Malo JL, Burge PS, Coifman R. Statement on self-monitoring of peak expiratory flows in the investigation of occupational asthma. Subcommittee on Occupational Allergy of the European Academy of Allergology and Clinical Immunology. American Academy of Allergy and Clinical Immunology. European Respiratory Society. American College of Allergy, Asthma and Immunology. Eur Respir J. Sep. 1995;8(9):1605-1610. Ineligible study design. [pmid: 8575590].
Moscato G, Godnic-Cvar J, Maestrelli P, Malo JL, Sherwood Burge P, Coifman R. Statement on self-monitoring of peak expiratory flow in the investigation of occupational asthma. Subcommittee on Occupational Allergy of the European Academy of Allergology and Clinical Immunology. Allergy. Sep. 1995;50(9):711-717. Ineligible study design. [pmid: 8546264].
Moscato G, Godnic-Cvar J, Maestrelli P. Statement on self-monitoring of peak expiratory flows in the investigation of occupational asthma. Subcommittee on Occupational Allergy of European Academy of Allergy and Clinical Immunology. J Allergy Clin Immunol. Sep. 1995;96(3):295-301. Ineligible study design. [pmid: 7560631].
Moudgil H, Marshall T, Honeybourne D. Asthma education and quality of life in the community: a randomised controlled study to evaluate the impact on white European and Indian subcontinent ethnic groups from socioeconomically deprived areas in Birmingham, UK. Thorax. Mar. 2000;55(3):177-183. Reported data not usable. [pmid: 10679534]. [pmcid: 1745690].
Murray MD, Loos B, Tu W, Eckert GJ, Zhou XH, Tierney WM. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225. No eligible outcomes. [pmid: 10030506].
Nair SJ, Daigle KL, DeCuir P, Lapin CD, Schramm CM. The influence of pulmonary function testing on the management of asthma in children. J Pediatr. Dec. 2005;147(6):797-801. Not an evaluation of a QI intervention. [pmid: 16356434].
Narhi U, Airaksinen M, Tanskanen P, Erlund H. Therapeutic outcomes monitoring by community pharmacists for improving clinical outcomes in asthma. J Clin Pharm Ther. Jun. 2000;25(3):177-183. Ineligible study design. [pmid: 10886462].
National Asthma Education and Prevention Program. Resolution on asthma management at school. School Nurse News. Nov 2002;19(5):16–17. Not an evaluation of a QI intervention
Neville R, Clark R. The Childhood Asthma Project 1990-93. A report on a controlled trial of an audit facilitator on the diagnosis and treatment of childhood asthma in general practice. 1995. Other
Nies MA, Bickes JT, Schim SM, Johnson AL. Model for community health nursing care: application to an integrated asthma intervention program. J Sch Nurs. Apr. 2002;18(2):74-78. Ineligible study design. [pmid: 12017249].
Niksic D, Saracevic E, Cemerlic-Kulic A, Kurspahic-Mujcic A, Bajraktarevic S, Niksic H. Evaluation of efficiency practical issues in the management of childhood asthma. Bosn J Basic Med Sci. Nov. 2005;5(4):40-45. Ineligible study design. [pmid: 16351597].
Oprehek J, Gayard P, Grimaud C, Charpin J. Patient error in use of bronchidilator metered aerosols. Br Med J. Jan 10. 1976;1(6001):76. Not an evaluation of a QI intervention. [pmid: 1244940].
Osman LM, Calder C, Godden DJ, et al. A randomised trial of self-monitoring or self-management planning for adult patients admitted to hospital with acute asthma. Thorax. Oct. 2002;57(10):869-874. Excluded topic. [pmid: 12324673]. [pmcid: 1746210].
Parcel GS, Nader PR, Tiernan K. A health education program for children with asthma. J Dev Behav Pediatr. Sep. 1980;1(3):128-132. No eligible outcomes. [pmid: 7229057].
Parcel GS, Nader PR. Evaluation of a pilot school health education program for asthmatic children. J Sch Health. Oct. 1977;47(8):453-456. Ineligible study design. [pmid: 243078].
Partridge MR, Fabbri LM, Chung KF. Delivering effective asthma care—how do we implement asthma guidelines?. Eur Respir J. Feb. 2000;15(2):235. Not an evaluation of a QI intervention. [pmid: 10706483].
Path inventory facilitates benchmarking care paths. Healthc Benchmarks. Nov 1997;4(11):159–161. Not an evaluation of a QI intervention
Patient/provider education is cornerstone of successful DM approach to asthma. Dis Manag Advis. Sep 2000;6(9):144–146, 132, suppl 141 p. Ineligible study design
Patterson EE, Brennan MP, Linskey KM, Webb DC, Shields MD, Patterson CC. A cluster randomised intervention trial of asthma clubs to improve quality of life in primary school children: the School Care and Asthma Management Project (SCAMP). Archives of Disease in Childhood. Aug. 2005;90(8):786-791. Ineligible study design. [pmid: 16040874]. [pmcid: 1720518].
Pauley TR, Magee MJ, Cury JD. Pharmacist-managed, physician-directed asthma management program reduces emergency department visits. Ann Pharmacother. Jan. 1995;29(1):5-9. Ineligible study design. [pmid: 7711346].
Peak flow-based compared to symptom-based written action plans. J Allergy Clin Immunol. Nov 2002;110(5 Suppl):S192–196. Not an evaluation of a QI intervention
Pearce MJ, Begg EJ. Encouraging consensus cost effective drug therapy: five years experience with a hospital drug utilisation review programme. N Z Med J. Mar 28. 1997;110(1040):92. Excluded topic. [pmid: 9137310].
Perry CS, Toole KA. Impact of school nurse case management on asthma control in school-aged children. J Sch Health. Sep. 2000;70(7):303-304. Ineligible study design. [pmid: 10981286].
Persky V, Coover L, Hernandez E, et al. Chicago community-based asthma intervention trial: feasibility of delivering peer education in an inner-city population. Chest. Oct. 1999;116(4 Suppl 1):216S-223S. Reported data not usable. [pmid: 10532497].
Petheram IS, Jones DA, Collins JV. Assessment and management of acute asthma in the elderly: a comparison with younger asthmatics. Postgrad Med J. Mar. 1982;58(677):149-151. Not an evaluation of a QI intervention. [pmid: 7100037]. [pmcid: 2426353].
Pharmacotherapy—add-on therapies. CMAJ. Sep 13 2005;173(6 Suppl):S37–38. Not an evaluation of a QI intervention
Pinnock H, Bawden R, Proctor S, et al. Accessibility, acceptability, and effectiveness in primary care of routine telephone review of asthma: pragmatic, randomised controlled trial. BMJ. Mar 1. 2003;326(7387):477. No eligible outcomes. [pmid: 12609944]. [pmcid: 150181].
Pituch M, Bruggeman J. Lungs unlimited: a self-care program for asthmatic children and their families. Child Today. Jul–Aug. 1982;11(4):6-10. Ineligible study design. [pmid: 7128237].
Poirier S, LeLorier J, Page V, Lacour A. The effect of a $2 co-payment on prescription refill rates of Quebec elderly and its relationship to socio-economic status. Can Pharm J. 1998;131(1):30. Not an evaluation of a QI intervention.
Poulsen SS, Petersen BN. Letter: Letter to the editor. Scand J Respir Dis. 1976;57(2):97-98. Not an evaluation of a QI intervention. [pmid: 781836].
Premaratne UN, Sterne JA, Marks GB, Webb JR, Azima H, Burney PG. Clustered randomised trial of an intervention to improve the management of asthma: Greenwich asthma study. BMJ. May 8. 1999;318(7193):1251. Reported data not usable. [pmid: 10231256].
Program succeeds tackling two diseases with one approach. Dis Manag Advis. Oct 2002;8(10):145–149. Ineligible study design
Rachelefsky GS, Lewis CE, de la Sota A, Lewis MA. ACT (asthma care training) for kids. A childhood asthma self-monitoring or self-management program. Chest. Jan. 1985;87(1 Suppl):98S-100S. Ineligible study design. [pmid: 3964743].
Rance K, Trent C. Broccoli and pixie stix. Profile of a pediatric asthma program. Adv Nurse Pract. Mar. 2004;12(3):47-48. Ineligible study design. [pmid: 15038184].
Rance KS, Trent CA. Profile of a primary care practice asthma program: improved patient outcomes in a high-risk population. J Pediatr Health Care. Jan–Feb. 2005;19(1):25-32. Ineligible study design. [pmid: 15662359].
Ratima MM, Fox C, Fox B, et al. Long-term benefits for Maori of an asthma self-monitoring or self-management program in a Maori community which takes a partnership approach. Aust N Z J Public Health. Dec. 1999;23(6):601-605. Ineligible study design. [pmid: 10641350].
Reddel HK, Toelle BG, Marks GB, Ware SI, Jenkins CR, Woolcock AJ. Analysis of adherence to peak flow monitoring when recording of data is electronic. BMJ. Jan 19. 2002;324(7330):146-147. Not an evaluation of a QI intervention. [pmid: 11799031].
Redline S, Gruchalla RS, Wolf RL, et al. Development and validation of school-based asthma and allergy screening questionnaires in a 4-city study. School Nurse News. Nov. 2004;21(5):12-14. Not an evaluation of a QI intervention. [pmid: 15624578].
Richards W, Church JA, Roberts MJ, Newman LJ, Garon MR. A self-help program for childhood asthma in a residential treatment center. Clin Pediatr (Phila). Jul. 1981;20(7):453-457. Ineligible study design. [pmid: 7237882].
Richardson CR. Homemade spacers useful in asthma treatment. J Fam Pract. Dec. 1999;48(12):997. Not an evaluation of a QI intervention. [pmid: 10628581].
Ringsberg KC, Timpka T. Clinical health education for patients with asthma-like symptoms but negative asthma tests. Allergy. 2001;56(11):1049-1054. Excluded topic. [pmid: 11703217].
Robichaud P, Laberge A, Allen MF, et al. Evaluation of a program aimed at increasing referrals for asthma education of patients consulting at the emergency department for acute asthma. Chest. Nov. 2004;126(5):1495-1501. No eligible outcomes. [pmid: 15539718].
Roemer W, Hoek G, Brunekreef B. Pollution effects on asthmatic children in Europe, the PEACE study. Clin Exp Allergy. Aug. 2000;30(8):1067-1075. Not an evaluation of a QI intervention. [pmid: 10931113].
Rohl BJ, Meyer LC, Lung CL. An individualized, comprehensive asthma care treatment program. Med Interface. Mar 1994;7(3):121–123, 134. Ineligible study design
Roque F, Walker L, Herrod P, Pyzik T, Clapp W. The Lawndale Christian Health Center Asthma Education Program. Chest. Oct. 1999;116(4 Suppl 1):201S-202S. Ineligible study design. [pmid: 10532490].
Ross DJ. Ten years of the SWORD project. Surveillance of Work-related and Occupational Respiratory Disease. Clin Exp Allergy. Jun. 1999;29(6):750-753. Not an evaluation of a QI intervention. [pmid: 10336589].
Ross S, Togger D, Desjardins D. Asthma disease management program cuts readmissions. Hosp Case Manag. Oct. 1998;6(10):197-200. Ineligible study design. [pmid: 10185918].
RTs, doctors team up to lead successful asthma program. Healthc Demand Dis Manag. Jun 1999;5(6):81–85. Ineligible study design
Rundall TG, Shortell SM, Wang MC, et al. As good as it gets? Chronic care management in nine leading US physician organisations. BMJ. Oct 26. 2002;325(7370):958-961. Excluded topic. [pmid: 12399351]. [pmcid: 1124449].
Rupp MT, McCallian DJ, Sheth KK. Developing and marketing a community pharmacy-based asthma management program. J Am Pharm Assoc (Wash). Nov–Dec. 1997;NS37(6):694-699. Ineligible study design. [pmid: 9425799].
Saini B, Krass I, Armour C. Development, implementation, and evaluation of a community pharmacy-based asthma care model. Ann Pharmacother. Nov. 2004;38(11):1954-1960. Reported data not usable. [pmid: 15479780].
Sauro A, Scalzitti F, Buono N, et al. Spirometry is really useful and feasible in the GP's daily practice but guidelines alone are not. Eur J Gen Pract. Mar. 2005;11(1):29-31. Reported data not usable. [pmid: 15841063].
Savage I, Goodyear L. Providing information on metered dose inhaler technique: Is multimedia as effective as print?. Family Practice. 2003;20(5):552-557. No eligible outcomes. [pmid: 14507797].
Schermer TR, Thoonen BP, van den Boom G, et al. Randomized controlled economic evaluation of asthma self-monitoring or self-management in primary health care. Am J Respir Crit Care Med. Oct 15. 2002;166(8):1062-1072. No eligible outcomes. [pmid: 12379549].
Schlosser M. Patient-education in asthma and COPD: differences and similarities [abstract]. Eur Respir J Suppl. 1995;8(Suppl 19):216S. Abstract.
Schmaling K, Blume A, Afari N. A randomized controlled pilot study of motivational interviewing to change attitudes about adherence to medications for asthma. J Clinl Psych Med Settings. 2001;8(3):167-172. No eligible outcomes.
Schneeweiss S, Maclure M, Carleton B, Glynn RJ, Avorn J. Clinical and economic consequences of a reimbursement restriction of nebulised respiratory therapy in adults: direct comparison of randomised and observational evaluations. BMJ. 2004;328(7439):560. Not an evaluation of a QI intervention. [pmid: 14982865]. [pmcid: 381049].
Schneider MR, Melton BH, Reisch JS. Effects of a progressive exercise program on absenteeism among school children with asthma. J Sch Health. Feb. 1980;50(2):92-95. Not an evaluation of a QI intervention. [pmid: 6898268].
Schonberger HJ, Dompeling E, Knottnerus JA, et al. The PREVASC study: the clinical effect of a multifaceted educational intervention to prevent childhood asthma. Eur Respir J. Apr. 2005;25(4):660-670. Excluded topic. [pmid: 15802340].
Schonberger HJ, Maas T, Dompeling E, Knottnerus JA, van Weel C, van Schayck CP. Compliance of asthmatic families with a primary prevention programme of asthma and effectiveness of measures to reduce inhalant allergens—a randomized trial. Clin Exp Allergy. Jul. 2004;34(7):1024-1031. No eligible outcomes. [pmid: 15248845].
Schreurs KM, Colland VT, Kuijer RG, de Ridder DT, van Elderen T. Development, content, and process evaluation of a short self-monitoring or self-management intervention in patients with chronic diseases requiring self-care behaviours. Patient Educ Couns. Oct. 2003;51(2):133-141. Reported data not usable. [pmid: 14572942].
Schulte A, Musolf J, Meurer JR, Cohn JH, Kelly KJ. Pediatric asthma case management: a review of evidence and an experimental study design. J Pediatr Nurs. Aug. 2004;19(4):304-310. Ineligible study design. [pmid: 15308981].
Serrier P, Muller D, Sevin C, Mechin H, Chanal I. Evaluation of an educational program on asthma for pharmacists. French. Presse Med. Nov 25. 2000;29(36):1987. Foreign language article language.
Shah S, Gibson PG, Wachinger S. Recognition and crisis management of asthma in schools. J Paediatr Child Health. Aug. 1994;30(4):312-315. Ineligible study design. [pmid: 7946541].
Shegog R, Bartholomew LK, Parcel GS, Sockrider MM, Masse L, Abramson SL. Impact of a computer-assisted education program on factors related to asthma self-monitoring or self-management behavior. J Am Med Inform Assoc. Jan–Feb. 2001;8(1):49-61. No eligible outcomes. [pmid: 11141512]. [pmcid: 134591].
Shelledy D, McCormick S, LeGrand T, Cardenas J, Peters J. The effect of a pediatric asthma management program provided by respiratory therapists on patient outcomes and cost. Heart & Lung. 2005;34(6):423-428. Ineligible study design. [pmid: 16324962].
Sly PD. Peak expiratory flow monitoring in pediatric asthma: is there a role?. J Asthma. 1996;33(5):277-287. Not an evaluation of a QI intervention. [pmid: 8827935].
Sly RM. Evaluation of a sound-slide program for patient education. Ann Allergy. Feb. 1975;34(2):94-97. No eligible outcomes. [pmid: 47724].
Smeele IJ, Van Schayck CP, Grol R, et al. Implementing national guidelines on asthma/COPD in general practice; the effects of continuous monitoring and feedback at patient level dissertation. 1998. Thesis/Dissertation
Smeele IJM, Grol R, Van Schayck CP, Van den Bosch W, Van den Hoogen HJM, Muris JWM. Can small group education and peer review improve care for patients with asthma/chronic obstructive pulmonary disease?. Qual Health Care. Jun. 1999;8(2):92. Reported data not usable. [pmid: 10557684]. [pmcid: 2483639].
Smeele IJM, Grol R, Van Schayck CP, Van den Bosch W, Van den Hoogen HJM, Muris JWM. Improving care for patients with asthma/COPD. A randomized experimental study on the effects of an intensive small group education and peer review programme on care provision and patient outcomes dissertation. 1998. Thesis/Dissertation
Smith BJ, McElroy HJ, Ruffin RE, et al. The effectiveness of coordinated care for people with chronic respiratory disease. comment. Med J Aust. 2002;177(9):481. Excluded topic. [pmid: 12405889].
Sommaruga M, Spanevello A, Migliori GB, Neri M, Callegari S, Majani G. The effects of a cognitive behavioural intervention in asthmatic patients. Monaldi Arch Chest Dis. Oct. 1995;50(5):398-402. Not an evaluation of a QI intervention. [pmid: 8541826].
Sondergaard J, Andersen M, Vach K, Kragstrup J, Maclure M, Gram LF. Detailed postal feedback about prescribing to asthma patients combined with a guideline statement showed no impact: a randomised controlled trial. Eur J Clin Pharmacol. May. 2002;58(2):127. Reported data not usable. [pmid: 12012145].
Sorrells VD, Chung W, Schlumpberger JM. The impact of a summer asthma camp experience on asthma education and morbidity in children. J Fam Pract. Nov. 1995;41(5):465-468. Ineligible study design. [pmid: 7595264].
Spector SL. Is your asthmatic patient really complying?. Ann Allergy. Oct. 1985;55(4):552-556. Not an evaluation of a QI intervention. [pmid: 4051261].
Sperber K, Ibrahim H, Hoffman B, Eisenmesser B, Hsu H, Corn B. Effectiveness of a specialized asthma clinic in reducing asthma morbidity in an inner-city minority population. J Asthma. 1995;32(5):335. Ineligible study design. [pmid: 7559274].
Steinwachs DM, Wu AW, Skinner EA. How will outcomes management work?. Health Aff (Millwood). Fall. 1994;13(4):153-162. No eligible outcomes. [pmid: 7988991].
Summaries for patients. The effects of a smoking cessation program on long-term survival in smokers with mild lung disease. Ann Intern Med. Feb 15 2005;142(4):I12. Excluded topic
Swartz LJ, Callahan KA, Butz AM, et al. Methods and issues in conducting a community-based environmental randomized trial. Environ Res. Jun. 2004;95(2):156-165. Reported data not usable. [pmid: 15147921].
Tai S, Nazareth I, Donegan C, Haines A. Evaluation of general practice computer templates: Lessons from a pilot randomised controlled trial. Methods Inf Med. Sep. 1999;38(3):177. No eligible outcomes. [pmid: 10522120].
Talabere L. The effects of an asthma education program on selected health behaviors of school-age children who have recently experienced an acute asthma episode. The Ohio State University ** Ph.D. (260 p). 1990. Thesis/Dissertation
Tamaoki J, Chiyotani A, Sakai A, Takemura H, Konno K. Effect of menthol vapour on airway hyperresponsiveness in patients with mild asthma. Respir Med. Aug. 1995;89(7):503-504. Not an evaluation of a QI intervention. [pmid: 7480981].
Tanyeli G, Demir R, Ozylimaz S, Kiyan E, Gurses N. Effects of a comprehensive rehabilitation program and patient education on posture and breathing patterns in asthmatics. Eur Respir J. 2001;18(Suppl 33):299s. Abstract.
Teo S, Hanson R, Van Asperen P, et al. Improving asthma documentation in a paediatric emergency department. J Paediatr Child Health. Apr. 1995;31(2):130. Ineligible study design. [pmid: 7794614].
Thoonen BP, Schermer TR, Jansen M, et al. Asthma education tailored to individual patient needs can optimise partnerships in asthma self-monitoring or self-management. Pat Educ Couns. Aug. 2002;47(4):355. No eligible outcomes.
Thoonen BP, Schermer TR, Van Den Boom G, et al. Self-monitoring or self-management of asthma in general practice, asthma control and quality of life: a randomised controlled trial. Thorax. Jan. 2003;58(1):30-36. Reported data not usable. [pmid: 12511716]. [pmcid: 1746452].
Tilly KF, Garvey NJ, Gold M, Powell E, Proudlock ML. Outcomes management and asthma education in a community hospital: ongoing monitoring of health status. Qual Manag Health Care. Spring. 1996;4(3):67-78. Ineligible study design. [pmid: 10159291].
Tinkelman D, Wilson S. Asthma disease management: regression to the mean or better?. Am J Manag Care. Dec. 2004;10(12):948-954. No eligible outcomes. [pmid: 15617370].
Tschopp JM, Frey JG, Janssens JP, et al. Asthma outpatient education by multiple implementation strategy. Outcome of a programme using a personal notebook. Respiratory Medicine. Mar. 2005;99(3):355-362. Ineligible study design. [pmid: 15733512].
Tschopp JM, Frey JG, Pernet R, et al. Bronchial asthma and self-monitoring or self-management education: implementation of Guidelines by an interdisciplinary programme in health network. Swiss Med Wkly. Feb 23. 2002;132(78):92-97. Ineligible study design. [pmid: 11971203].
Tsoukleris MG, Michocki RJ. Geriatrics for the clinician. Inhalation therapy and the elderly: what every physician should consider. Md Med J. Dec. 1995;44(12):1049-1052. Not an evaluation of a QI intervention. [pmid: 8544672].
Vafiadou M, Ranuro R. Managing asthma: a pediatric program that works. Caring. Nov. 1999;18(11):16-21. Ineligible study design. [pmid: 10661986].
Van Asperen P, Jandera E, De Neef J, Hill P, Law N. Education in childhood asthma: a preliminary study of need and efficacy. Aust Paediatr J. Feb. 1986;22(1):49-52. No eligible outcomes. [pmid: 3718369].
van Walraven C, Forster A. Effect of follow-up physician visits on emergency readmissions. comment. Am J Med. Sep. 2002;113(4):347. Ineligible study design. [pmid: 12361826].
Velsor-Friedrich B, Srof B. Asthma self-monitoring or self-management programs for children. Part II: Empiric evaluation of programs and recommendations. J Child Fam Nurs. May–Jun. 2000;3(3):173-190. quiz 191, 190. Ineligible study design. [pmid: 11905217].
Veninga CC, Lagerlov P, Wahlstrom R, et al. Evaluating an educational intervention to improve the treatment of asthma in four European countries. Drug Education Project Group. Am J Respir Crit Care Med. Oct. 1999;160(4):1254. Reported data not usable. [pmid: 10508816].
Veninga N. Improving prescribing in general practice dissertation. Thesis. 2000. Thesis/Dissertation
Verstappen WH, van der Weijden T, Sijbrandij J, et al. Effect of a practice-based strategy on test ordering performance of primary care physicians: a randomized trial. JAMA. May 14. 2003;289(18):2407. No eligible outcomes. [pmid: 12746365].
Vilar ME, Reddy BM, Silverman BA, et al. Superior clinical outcomes of inner city asthma patients treated in an allergy clinic. Ann Allergy Asthma Immunol. Mar. 2000;84(3):299-303. No eligible outcomes. [pmid: 10752913].
Wakefield M, Banham D, McCaul K, et al. Effect of feedback regarding urinary cotinine and brief tailored advice on home smoking restrictions among low-income parents of children with asthma: a controlled trial. Prev Med. Jan. 2002;34(1):58-65. No eligible outcomes. [pmid: 11749097].
Warburton CJ, Niven RM, Pickering CA, Fletcher AM, Hepworth J, Francis HC. Domiciliary air filtration units, symptoms and lung function in atopic asthmatics. Respir Med. Nov. 1994;88(10):771-776. Not an evaluation of a QI intervention. [pmid: 7846339].
Ward A, Willey C, Andrade S. Patient education provided to asthmatic children: a historical cohort study of the implementation of NIH recommendations. J Asthma. Apr. 2001;38(2):141-147. Ineligible study design. [pmid: 11321684].
Watson E, Young L. Re-engineering care delivery to improve the health outcome of asthmatics in Campbelltown, New South Wales. Medinfo. 1995;8(Pt 1):545. No eligible outcomes. [pmid: 8591259].
Webber MP, Carpiniello KE, Oruwariye T, Lo Y, Burton WB, Appel DK. Burden of asthma in inner-city elementary schoolchildren: do school-based health centers make a difference?. Arch Pediatr Adolesc Med. Feb. 2003;157(2):125-129. Not an evaluation of a QI intervention. [pmid: 12580680].
Weinberger M, Murray MD, Marrero DG, et al. Effectiveness of pharmacist care for patients with reactive airways disease: a randomized controlled trial. JAMA. Oct 2. 2002;288(13):1594-1602. Excluded topic. [pmid: 12350190].
White M, Michaud G, Pachev G, Lirenman D, Kolenc A, FitzGerald JM. Randomized trial of problem-based versus didactic seminars for disseminating evidence-based guidelines on asthma management to primary care physicians. J Contin Educ Health Prof. 2004;24(4):237-243. No eligible outcomes. [pmid: 15709563].
White PT, Pharoah CA, Anderson HR, Freeling P. Randomized controlled trial of small group education on the outcome of chronic asthma in general practice see comments. J R Coll Gen Pract. May. 1989;39(322):182. Not an evaluation of a QI intervention. [pmid: 2560000]. [pmcid: 1712027].
Wiegers TA, Kerkstra A. COPD home visit with children. Comparison of the quality of various models. Dutch. Verpleegkunde. Aug. 1993;8(2):80. Foreign language article language.
With little to go on but much to gain, small IPA starts asthma DM program. Healthc Demand Dis Manag. Jun 1998;4(6):94–95. Not an evaluation of a QI intervention
Witt K, Knudsen E, Ditlevsen S, Hollnagel H. Academic detailing has no effect on prescribing of asthma medication in Danish general practice: a 3-year randomized controlled trial with 12-monthly follow-ups. Family Practice. 2004;21(3):248. Reported data not usable. [pmid: 15128684].
Worth H, Dhein Y, Woehl A, Schacher C, Volmer T. Economic benefits of an outpatient education programme (AFAS) for adult asthmatics. Eur Respir J. 2001;18(Suppl 33):188s. Abstract.
Worth H. Patient education in asthmatic adults. Lung. 1990;168(Suppl):463-468. Ineligible study design. [pmid: 2117149].
Wraight JM, Cowan JO, Flannery EM, Town GI, Taylor DR. Adherence to asthma self-monitoring or self-management plans with inhaled corticosteroid and oral prednisone: A descriptive analysis. Respirology. Jun. 2002;7(2):133-139. Ineligible study design. [pmid: 11985736].
Written action plans compared to medical management alone. J Allergy Clin Immunol. Nov 2002;110(5 Suppl):S183–191. Ineligible study design
Yamada EG. Asthma—the shift from episodic treatment to ongoing prevention, education, and management. West J Med. Dec. 1998;169(6):377. Ineligible study design. [pmid: 9866442].
Yang M, Chiang C, Yao G, Wang K. Effect of medical education on quality of life in adult asthma patients. J Formos Med Assoc. 2003;102(11):768-774. No eligible outcomes. [pmid: 14724722].
Yawn BP, Algatt-Bergstrom PJ, Yawn RA, et al. An in-school CD-ROM asthma education program. J Sch Health. Apr. 2000;70(4):153-159. No eligible outcomes. [pmid: 10790839].
Yawn BP, Wollan P, Scanlon PD, Kurland M. Outcome results of a school-based screening program for undertreated asthma. Ann Allergy Asthma Immunol. May. 2003;90(5):508-515. Not an evaluation of a QI intervention. [pmid: 12775132].
Yoon R, McKenzie D, Bauman A. Randomised controlled trial evaluation of an asthma education program. Hosp Pharm. 1989;19(1):51. Abstract.
Yoon R, McKenzie DK, Miles DA, Bauman A. Characteristics of attenders and non-attenders at an asthma education programme. Thorax. Dec. 1991;46(12):886-890. No eligible outcomes. [pmid: 1792635]. [pmcid: 463493].
Yoos HL, McMullen A, Bezek S, et al. An asthma management program for urban minority children. J Pediatr Health Care. Mar–Apr. 1997;11(2):66-74. Ineligible study design. [pmid: 9155350].
Young NL, Foster AM, Parkin PC, et al. Assessing the efficacy of a school-based asthma education program for children: a pilot study. Can J Public Health. Jan–Feb. 2001;92(1):30-34. No eligible outcomes. [pmid: 11257986].
Zieve FJ, Ciesco E. Computer-focused modification of physician prescribing behavior. Proc Annu Symp Comput Appl Med Care. 1992:617. Excluded topic
Zimbro KMS. Explanatory power of the behavior model of utilization for pediatric asthma health care in an urban managed care setting. Old Dominion University. Ph.D. 2000(267 p). Thesis/Dissertation