# Search Strategies by Database

EPOC Database Search (for QI interventions directed at organizational change and at providers)

#1 Targets the clinical condition of asthma

All fields:

Asthma* OR Anti-asthmatic or Bronchial Hyperreactivity OR Respiratory Hypersensitivity or Reactive airway*

#2 Targets community-based programs/school-based programs

All fields:

“School health services” or “Adolescent Health Services” or “Child Care” or “school health” or “community health services” or “home care”

Title/abstract field:

School OR Community OR Home

#3 Targets self-monitoring or self-management, patient education, and care by others

MeSH terms:

Patient education OR Self care OR Consumer Participation OR Patient Participation OR

Peak expiratory flow rate OR Consumer Participation OR Patient care planning OR

Health promotion

Title/abstract terms:

Self-monitoring or self-management OR self management OR Patient education OR Self care OR Self-care

Parent* care OR Proxy care OR Peak flow OR Action plan OR Symptom diary OR Monitor OR

Publication type term:

Patient education handout

Cochrane Consumer Group Registry Search (for QI strategies directed at patients and non-providers)

#1: Targets the clinical condition of asthma

MeSH terms:

Asthma OR Anti-asthmatic agents OR Asthma/Drug Therapy OR Bronchial Hyperreactivity OR Respiratory Hypersensitivity

Title/abstract terms:

Asthma* OR Reactive airway*

#2: Targets self-monitoring or self-management, patient education, and care by others

MeSH terms:

Patient education OR Self care OR Consumer Participation OR Patient Participation OR

Peak expiratory flow rate OR Consumer Participation OR Patient care planning OR

Health promotion OR

Title/abstract terms:

Self-monitoring or self-management OR self management OR Patient education OR Self care OR Self-care

Parent* care OR Proxy care OR Peak flow OR Action plan OR Symptom diary OR Monitor

#3: Search terms for specific codes used in the registry

(asthma* or anti-asthmatic or “bronchial hyperactivity” or “respiratory hypersensitivity” or “reactive airway*”) and (Ca-m or Ca-t or N6* or N8g or “patient education” or “consumer participation” or “patient participation” or “patient care planning” or “health promotion” or self-monitoring or self-management or “self management” or self-care or “self care” or “peak expiratory flow rate” )

Medline Search Strategy for EPC Asthma Project

#1 Targets the clinical condition of asthma (yield 95,494)

Asthma [mh] OR Anti-asthmatic agents [mh] OR Asthma/Drug Therapy [mh] OR Bronchial Hyperreactivity [mh] OR Respiratory Hypersensitivity [mh] OR Asthma* [ti] OR Reactive airway* [ti] OR Wheez* [ti]

#2 Targets the location of the intervention (yield 223,075)

School Health Services [mh] OR Adolescent Health Services [mh] OR Child Care [mh] OR Home Care Services [mh] OR School [ti] OR Community [ti] OR Home [ti] OR Work[ti]

#3 Targets self-monitoring or self-management studies (yield 119,216)

Patient education [mh] OR Self care [mh] Consumer Participation [mh] OR patient compliance [mh] OR Patient Participation [mh] OR Peak expiratory flow rate [mh] OR Patient care planning [mh] OR Health Promotion [mh] OR Self medication [mh] OR Caregivers [mh] OR Self-monitoring or self-management [ti] OR self management [ti] OR Patient education [ti] OR Self care [ti] OR Self-care [ti] OR Parental care [ti] OR Peak flow [ti] OR Action plan [ti] OR Symptom diary [ti] OR Monitor [ti] OR Care give* [ti] OR Caregive* [ti] OR Self-medication [ti] OR self medication [ti] OR empowerment[ti] OR patient education handout [Publication Type]

#4 Combine Searches #1 AND (#2 OR #3) (yield 6,125)

#5 Systematic review search string (yield 48,084)

(meta-analysis [pt] OR meta-analysis [tw] OR metanalysis [tw]) OR ((review [pt] OR guideline [pt] OR consensus [ti] OR guideline* [ti] OR literature [ti] OR overview [ti] OR review [ti] OR Decision Support Techniques [mh]) AND ((Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw])) OR (handsearch* [tw] OR search* [tw] OR searching [tw]) AND (hand [tw] OR manual [tw] OR electronic [tw] OR bibliographi* [tw] OR database* OR (Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw]))))) OR ((synthesis [ti] OR overview [ti] OR review [ti] OR survey [ti]) AND (systematic [ti] OR critical [ti] OR methodologic [ti] OR quantitative [ti] OR qualitative [ti] OR literature [ti] OR evidence [ti] OR evidence-based [ti]))) BUTNOT (case reports [pt] OR case* [ti] OR report [ti] OR editorial [pt] OR comment [pt] OR letter [pt])

#6 Original research search string (yield 2,506,960)

Randomised [ti] OR Randomized [ti] OR Controlled [ti] OR intervention [ti] OR evaluation [ti] OR impact [ti] OR effectiveness [ti] OR Evaluation [ti] OR Studies [ti] OR study [ti] Comparative [ti] OR Feasibility [ti] OR Program [ti] OR Design [ti] OR Clinical Trial [pt] OR Randomized Controlled Trial [pt] OR Epidemiologic Studies [mh] OR Evaluation Studies [mh] OR Comparative Study [mh] OR Feasibility Studies [mh] OR Intervention Studies [mh] OR Program Evaluation [mh] OR Epidemiologic Research Design [mh]

#7 Commentaries and news reports search string (yield 1,890,529)

(editorial [pt] OR comment [pt] OR letter [pt] OR news [pt] OR newspaper article [pt] OR case reports[pt])

#8 Combine searches: #5 OR # 6 (yield 2,537,556)

#9 Combine searches: #4 AND #8 (yield 3,112)

#10 Combine searches: #9 BUTNOT #7 (yield 3,003)

#11 Limit to English language, Human (yield 2788)