# Appendixes

Appendix A Search Strategies by Database

Appendix B Data Abstraction Forms

Appendix C List of Excluded Studies

Appendix D Technical Expert Panel and Peer Reviewers