# Table References

1 Finkelstein JA, Davis RL, Dowell SF, et al. Reducing antibiotic use in children: a randomized trial in 12 practices. Pediatr. 2001;108:1-7.
2 Angunawela I, Diwan VK, Tomson G. Experimental evaluation of the effects of drug information on antibiotic prescribing: a study in outpatient care in an area of Sri lanka. International Journal of Epidemiology. 1991;20(2):558. [pmid: 1917265].
3 Angunawela I, Diwan VK, Tomson G. [Additional comparison 1] Experimental evaluation of the effects of drug information on antibiotic prescribing: a study in outpatient care in an area of Sri lanka. International Journal of Epidemiology. 1991;20(2):558. [pmid: 1917265].
4 Arroll B, Kenealy T, Kerse N. Do Delayed Prescriptions Reduce the Use of Antibiotics for the Common Cold?. J Fam Pract. 2002;51(4):324-328. [pmid: 11978254].
5 Belongia EA, Sullivan BJ, Chyou PH, Madagame E, Reed KD, Schwartz B. A community intervention trial to promote judicious antibiotic use and reduce penicillin-resistant Streptococcus pneumoniae carriage in children. Pediatrics. 2001;108(3):575. [pmid: 11533321].
6 Bexell A, Lwando E, von Hofsten B, Tembo S, Eriksson B, Diwan VK. Improving drug use through continuing education: a randomized controlled trial in Zambia. Journal of Clinical Epidemiology. 1996;49:355. [pmid: 8676185].
7 Christakis DA, Zimmerman FJ, Wright JA, Garrison MM, Rivara FP, Davis RL. A randomized controlled trial of point-of-care evidence to improve the antibiotic prescribing practices for otitis media in children. Pediatrics. 2001;107(2).
8 Dowell J, Pitkethly M, Bain J, Martin S. A randomised controlled trial of delayed antibiotic prescribing as a strategy for managing uncomplicated respiratory tract infection in primary care. Br J Gen Pract. 2001;51(3):200-205. [pmid: 11255901]. [pmcid: 1313951].
9 Flottorp S, Oxman AD, Havelsrud K, Treweek S, Herrin J. Cluster randomised controlled trial of tailored interventions to improve the management of urinary tract infections in women and sore throat. BMJ. 2002;325:7360.
10 Foxman B, Valdez RB, Lohr KN, Goldberg GA, Newhouse JP, Brook RH. The effect of cost sharing on the use of antibiotics in ambulatory care: results from a population-based randomized controlled trial. Journal of Chronic Diseases. 1987;40(5):429. [pmid: 3104386].
11 Gonzales R, Steiner JF, Lum A, Barrett PHJ. Decreasing antibiotic use in ambulatory practice: impact of a multidimensional intervention on the treatment of uncomplicated acute bronchitis in adults. JAMA. 1999;281(16):1512-1519. [pmid: 10227321].
12 Gonzales R, Steiner JF, Lum A, Barrett PHJ. [Additional comparison 1] Decreasing antibiotic use in ambulatory practice: impact of a multidimensional intervention on the treatment of uncomplicated acute bronchitis in adults. JAMA. 1999;281(16):1512-1519. [pmid: 10227321].
13 Gonzalez Ochoa E, Armas Perez L, Bravo Gonzalez JR, Cabrales Escobar J, Rosales Corrales R, Abreu Suarez G. Prescription of antibiotics for mild acute respiratory infections in children. Bulletin of the Pan American Health Organization. 1996;30(2):106. [pmid: 8704751].
14 Gonzalez Ochoa E, Armas Perez L, Bravo Gonzalez JR, Cabrales Escobar J, Rosales Corrales R, Abreu Suarez G. [Additional comparison 1] Prescription of antibiotics for mild acute respiratory infections in children. Bulletin of the Pan American Health Organization. 1996;30(2):106. [pmid: 8704751].
15 Gonzalez Ochoa E, Armas Perez L, Bravo Gonzalez JR, Cabrales Escobar J, Rosales Corrales R, Abreu Suarez G. [Additional comparison 2] Prescription of antibiotics for mild acute respiratory infections in children. Bulletin of the Pan American Health Organization. 1996;30(2):106. [pmid: 8704751].
16 Gutierrez G, Guiscafre H, Bronfman M, Walsh J, Martinez H, Munoz O. Changing physician prescribing patterns: evaluation of an educational strategy for acute diarrhea in Mexico City. Medical Care. 1994;32(5):436. [pmid: 8182972].
17 Hennessy TW, Petersen KL, Bruden D, et al. Changes in Antibiotic-Prescribing Practices and Carriage of Penicillin-Resistant Streptococcus pneumoniae: A Controlled Intervention Trial in Rural Alaska. Clin Infect Dis. 2002;34:1543-1550. [pmid: 12032887].
18 Hickman DE, Stebbins MR, Hanak JR, Guglielmo BJ. Pharmacy-based intervention to reduce antibiotic use for acute bronchitis. Annals of Pharmacotherapy. 2003;37(2):187. [pmid: 12549944].
19 Little P, Gould C, Williamson I, Moore M, Warner G, Dunleavey J. Pragmatic randomised controlled trial of two prescribing strategies for childhood acute otitis media. BMJ. 2001;322(7282):336-342. [pmid: 11159657]. [pmcid: 26576].
20 Macfarlane J, Holmes W, Gard P, et al. Reducing antibiotic use for acute bronchitis in primary care: blinded, randomised controlled trial of patient information leaflet * Commentary: More self reliance in patients and fewer antibiotics: still room for improvement. BMJ. 2002;324(7329):91. [pmid: 11786454].
21 Mainous AG 3rd, Hueston WJ, Love MM, Evans ME, Finger R. An evaluation of statewide strategies to reduce antibiotic overuse. Family Medicine. 2000;32(1):22. [pmid: 10645510].
22 Mainous AG 3rd, Hueston WJ, Love MM, Evans ME, Finger R. [Additional comparison 1] An evaluation of statewide strategies to reduce antibiotic overuse. Family Medicine. 2000;32(1):22. [pmid: 10645510].
23 Mainous AG 3rd, Hueston WJ, Love MM, Evans ME, Finger R. [Additional comparison 2] An evaluation of statewide strategies to reduce antibiotic overuse. Family Medicine. 2000;32(1):22. [pmid: 10645510].
24 McConnell TS, Cushing AH, Bankhurst AD, Healy JL, McIlvenna PA, Skipper BJ. Physician behavior modification using claims data: tetracycline for upper respiratory infection. West J Med. 1982;137(5):448-450. [pmid: 6891147]. [pmcid: 1274191].
25 McIsaac WJ, Goel V. Effect of an explicit decision-support tool on decisions to prescribe antibiotics for sore throat. Medical Decision Making. 1998;18(2):220. [pmid: 9566455].
26 McIsaac WJ, Goel V, To T, Permaul JA, Low DE. Effect on antibiotic prescribing of repeated clinical prompts to use a sore throat score: lessons from a failed community intervention study. Journal of Family Practice. 2002;51(4):339. [pmid: 11978257].
27 Melander E, Bjorgell A, Bjorgell P, Ovhed I, Molstad S. Medical audit changes physicians' prescribing of antibiotics for respiratory tract infections. Scandinavian Journal of Primary Health Care. 1999;17(3):180. [pmid: 10555249].
28 Meyer JC, Summers RS, Moller H. Randomized, controlled trial of prescribing training in a South African province. Med Educ. 2001;35(9):833-840. [pmid: 11555220].
29 O'Connell DL, Henry D, Tomlins R. Randomised controlled trial of effect of feedback on general practitioners' prescribing in Australia. BMJ. 1999;318(7182):507-511. [pmid: 10024260]. [pmcid: 27749].
30 Perz JF, Craig AS, Coffey CS, et al. Changes in antibiotic prescribing for children after a community-wide campaign. JAMA. 2002;287(23):3103. [pmid: 12069673].
31 Santoso B, Suryawati S, Prawaitasari JE. Small group intervention vs formal seminar for improving appropriate drug use published erratum appears in Soc Sci Med 1996 Jul;43(1):I. Social Science & Medicine. 1996;42(8):1163. [pmid: 8737434].
32 Santoso B, Suryawati S, Prawaitasari JE. [Additional comparison 1] Small group intervention vs formal seminar for improving appropriate drug use published erratum appears in Soc Sci Med 1996 Jul;43(1):I. Social Science & Medicine. 1996;42(8):1163. [pmid: 8737434].
33 Zwar N, Wolk J, Gordon J, Sanson-Fisher R, Kehoe L. Influencing antibiotic prescribing in general practice: A trial of prescriber feedback and management guidelines. Family Practice. 1999;16(5):495. [pmid: 10533946].
34 McNulty CA, Kane A, Foy CJ, Sykes J, Saunders P, Cartwright KA. Primary care workshops can reduce and rationalize antibiotic prescribing. Journal of Antimicrobial Chemotherapy. 2000;46(3):493. [pmid: 10980182].
35 Welschen I, Kuyvenhoven MM, Hoes AW, Verheij TJ. Effectiveness of a multiple intervention to reduce antibiotic prescribing for respiratory tract symptoms in primary care: randomised controlled trial. Bmj. 2004;329(7463):431. [pmid: 15297305]. [pmcid: 514206].
36 Molstad S, Hovelius. Reduction in antibiotic usage following an educational programme. Family Practice. 1989;6(1):33-37. [pmid: 2714542].
37 Cates C. An evidence based approach to reducing antibiotic use in children with acute otitis media: controlled before and after study. Bmj. 1999;318(7185):715-716. [pmid: 10074019]. [pmcid: 27785].
38 Pshetizky Y, Naimer S, Shvartzman P. Acute otitis media—a brief explanation to parents and antibiotic use. Fam Pract. 2003;20(4):417-419. [pmid: 12876113].
39 Smabrekke L, Berild D, Giaever A, et al. Educational intervention for parents and healthcare providers leads to reduced antibiotic use in acute otitis media. Scand J Infect Dis. 2002;34(9):657-659. [pmid: 12374355].
40 Wilson EJ, Nasrin D, Dear KB, Douglas RM. Changing GPs' antibiotic prescribing: a randomised controlled trial. Commun Dis Intell. 2003;27(Suppl):S32-38. [pmid: 12807271].
41 Coenen S, Van Royen P, Michiels B, Denekens J. Optimizing antibiotic prescribing for acute cough in general practice: a cluster-randomized controlled trial. J Antimicrob Chemother. 2004;54(3):661-672. [pmid: 15282232].
42 Avorn J, Soumerai SB. Improving drug-therapy decisions through educational outreach. A randomized controlled trial of academically based “detailing”. New England Journal of Medicine. 1983;308(24):1457-1463. [pmid: 6406886].
43 Avorn J, Soumerai SB. [Additional comparison 1] Improving drug-therapy decisions through educational outreach. A randomized controlled trial of academically based “detailing”. New England Journal of Medicine. 1983;308(24):1457-1463. [pmid: 6406886].
44 Braybrook S, Walker R. Influencing prescribing in primary care: a comparison of two different prescribing feedback methods. Journal of Clinical Pharmacy & Therapeutics. 1996;21(4):247. [pmid: 8933299].
45 Braybrook S, Walker R. [Additional comparison 1] Influencing prescribing in primary care: a comparison of two different prescribing feedback methods. Journal of Clinical Pharmacy & Therapeutics. 1996;21(4):247. [pmid: 8933299].
46 Bush PJ, Rabin DL, Spector KK. Evaluation of a drug therapy protocol in an HMO. Medical Care. 1979;17(6):566. [pmid: 449432].
47 Bush PJ, Rabin DL, Spector KK. [Additional comparison 1] Evaluation of a drug therapy protocol in an HMO. Medical Care. 1979;17(6):566. [pmid: 449432].
48 De Santis G, Harvey KJ, Howard D, Mashford ML, Moulds RF. Improving the quality of antibiotic prescription patterns in general practice. The role of educational intervention. Medical Journal of Australia. 1994;160(8):502. [pmid: 8170427].
49 Dolovich L, Levine M, Tarajos R, Duku E. Promoting optimal antibiotic therapy for otitis media using commercially sponsored evidence-based detailing: A prospective controlled trial. Drug Information Journal. 1999;33(4):1067.
50 Farris KB, Kirking DM, Shimp LA, Opdycke RA. Design and results of a group counter-detailing DUR educational program. Pharmaceutical Research. 1996;13(10):1445. [pmid: 8899833].
51 Friis H, Bro F, Mabeck CE, Vejlsgaard R. Changes in prescription of antibiotics in general practice in relation to different strategies for drug information. Danish Medical Bulletin. 1991;38(4):380. [pmid: 1914537].
52 Friis H, Bro F, Mabeck CE, Vejlsgaard R. [Additional comparison 1] Changes in prescription of antibiotics in general practice in relation to different strategies for drug information. Danish Medical Bulletin. 1991;38(4):380. [pmid: 1914537].
53 Hux JE, Melady MP, DeBoer D. Confidential prescriber feedback and education to improve antibiotic use in primary care: a controlled trial. CMAJ. 1999;161(4):388. [pmid: 10478162]. [pmcid: 1230539].
54 Ilett KF, Johnson S, Greenhill G, et al. Modification of general practitioner prescribing of antibiotics by use of a therapeutics adviser (academic detailer). British Journal of Clinical Pharmacology. 2000;49(2):168. [pmid: 10671912]. [pmcid: 2014897].
55 Klein LE, Charache P, Johannes RS. Effect of physician tutorials on prescribing patterns of graduate physicians. Journal of Medical Education. 1981;56(6):504. [pmid: 7346637].
56 Lagerlov P, Loeb M, Andrew M, Hjortdahl P. Improving doctors' prescribing behaviour through reflection on guidelines and prescription feedback: a randomised controlled study. Quality in Health Care. 2000;9(3):159. [pmid: 10980076]. [pmcid: 1743532].
57 Lundborg CS, Wahlstrom R, Oke T, Tomson G, Diwan VK. Influencing prescribing for urinary tract infection and asthma in primary care in Sweden: a randomized controlled trial of an interactive educational intervention. Journal of Clinical Epidemiology. 1999;52(8):801. [pmid: 10465325].
58 MacCara ME, Sketris IS, Comeau DG, Weerasinghe SD. Impact of a limited fluoroquinolone reimbursement policy on antimicrobial prescription claims. Annals of Pharmacotherapy. 2001;35(78):852. [pmid: 11485132].
59 McNulty CA, Kane A, Foy CJ, Sykes J, Saunders P, Cartwright KA. [Additional comparison 1] Primary care workshops can reduce and rationalize antibiotic prescribing. Journal of Antimicrobial Chemotherapy. 2000;46(3):493. [pmid: 10980182].
60 Peterson GM, Stanton LA, Bergin JK, Chapman GA. Improving the prescribing of antibiotics for urinary tract infection. Journal of Clinical Pharmacy & Therapeutics. 1997;22(2):147. [pmid: 9373814].
61 Raz R, Porat V, Ephros M. Can an educational program improve the diagnosis and treatment of pharyngotonsillitis in the ambulatory care setting?. Israel Journal of Medical Sciences. 1995;31(7):432. [pmid: 7607871].
62 Rokstad K, Straand J, Fugelli P. Can drug treatment be improved by feedback on prescribing profiles combined with therapeutic recommendations? A prospective, controlled trial in general practice. Journal of Clinical Epidemiology. 1995;48(8):1061-1068. [pmid: 7775993].
63 Schaffner W, Ray WA, Federspiel CF, Miller WO. Improving antibiotic prescribing in office practice. A controlled trial of three educational methods. JAMA. 1983;250(13):1728. [pmid: 6350633].
64 Schaffner W, Ray WA, Federspiel CF, Miller WO. [Additional comparison 1] Improving antibiotic prescribing in office practice. A controlled trial of three educational methods. JAMA. 1983;250(13):1728. [pmid: 6350633].
65 Schaffner W, Ray WA, Federspiel CF, Miller WO. [Additional comparison 2] Improving antibiotic prescribing in office practice. A controlled trial of three educational methods. JAMA. 1983;250(13):1728. [pmid: 6350633].
66 Schaffner W, Ray WA, Federspiel CF, Miller WO. [Additional comparison 3] Improving antibiotic prescribing in office practice. A controlled trial of three educational methods. JAMA. 1983;250(13):1728. [pmid: 6350633].
67 Sondergaard J, Andersen M, Stovring H, Kragstrup J. Mailed prescriber feedback in addition to a clinical guideline has no impact: a randomised, controlled trial. Scandinavian Journal of Primary Health Care. 2003;21(1):47. [pmid: 12718461].
68 Veninga CC, Denig P, Zwaagstra R, Haaijer-Ruskamp FM. Improving drug treatment in general practice. Journal of Clinical Epidemiology. 2000;53(7):762. [pmid: 10941955].
69 Melander E, Bjorgell A, Bjorgell P, Ovhed I, Molstad SAc. Medical audit changes physicians' prescribing of antibiotics for respiratory tract infections. Scandinavian Journal of Primary Health Care. 1999;17(3):180. [pmid: 10555249].
70 Harrison A, Karim SA, Floyd K, et al. Syndrome packets and health worker training improve sexually transmitted disease case management in rural South Africa: randomized controlled trial. AIDS. 2000;14(17):2769. [pmid: 11125896].
71 Zwar N, Wolk J, Gordon J, Sanson-Fisher R, Kehoe LAc. Influencing antibiotic prescribing in general practice: A trial of prescriber feedback and management guidelines. Family Practice. 1999;16(5):495. [pmid: 10533946].
72 Molstad S, Hovelius. [Additional comparison 1] Reduction in antibiotic usage following an educational programme. Family Practice. 1989;6(1):33-37. [pmid: 2714542].
73 Smabrekke L, Berild D, Giaever A, et al. [Additional comparison 1] Educational intervention for parents and healthcare providers leads to reduced antibiotic use in acute otitis media. Scand J Infect Dis. 2002;34(9):657-659. [pmid: 12374355].
74 Coenen S, Van Royen P, Michiels B, Denekens J. [Additional comparison 1] Optimizing antibiotic prescribing for acute cough in general practice: a cluster-randomized controlled trial. J Antimicrob Chemother. 2004;54(3):661-672. [pmid: 15282232].